# Studies Excluded at the Full-Text Level

## Excluded for Ineligible Publication Type

1 Andre C, Lelord F, Legeron P, et al. Effectiveness of early intervention on 132 bus drivers victims of aggressions: A controlled study. Encephale-Revue De Psychiatrie Clinique Biologique Et Therapeutique. Jan–Feb. 1997;23(1):65-71.
2 Cuijpers P, Van Straten A, Smit F. Preventing the incidence of new cases of mental disorders: a meta-analytic review. J Nerv Ment Dis. Feb. 2005;193(2):119-25. [pmid: 15684914].
3 Donovan JM, Bennett MJ, McElroy CM. The crisis group--an outcome study. Am J Psychiatry. Jul. 1979;136(7):906-10. [pmid: 453351].
4 Dreman S. Children of victims of terrorism in Israel: coping and adjustment in the face of trauma. Isr J Psychiatry Relat Sci. 1989;26(4):212-22. [pmid: 2632457].
5 Foa EB. Trauma and women: course, predictors, and treatment. J Clin Psychiatry. 1997;58(Supplement):25-8. [pmid: 9329448].
6 Hembree EA, Foa EB. Interventions for trauma-related emotional disturbances in adult victims of crime. J Trauma Stress. 2003;16(2):187-99. [pmid: 12699206].
7 Johnston SL, Dipp RD. Support of marines and sailors returning from combat: a comparison of two different mental health models. Mil Med. 2009;174(5):455-9. [pmid: 20731274].
8 Lieberman EJ, Wolin SJ. Family therapy and a physician’s suicide. Am J Psychiatry. Dec. 2004;161(12):2329-30. author reply 30–1. [pmid: 15569917].
9 Lundin T. THE TREATMENT OF ACUTE TRAUMA - POSTTRAUMATIC-STRESS-DISORDER PREVENTION. Psychiatr Clin North Am. Jun. 1994;17(2):385-91. [pmid: 7937365].
10 Pitman RK, Delahanty DL. Conceptually driven pharmacologic approaches to acute trauma. CNS Spectr. Feb. 2005;10(2):99-106. [pmid: 15685120].
11 Querques J. Can reading a diary improve psychological outcomes in the intensive care unit?. Crit Care Med. 2009;37(1):356-7. [pmid: 19112304].
12 Roberts Neil P, Kitchiner Neil J, Kenardy J, et al. Early psychological interventions to treat acute traumatic stress symptoms. Cochrane Database of Systematic Reviews. 2010;(3).
13 Steffgen G, de Boer C, Bollendorff C. Prevention of post-traumatic stress disorder in bank clerks after a bank robbery. Arbeitsmedizin Sozialmedizin Umweltmedizin. 2002;37(8):369-72.
14 van Dijk JA, Schoutrop MJ, Spinhoven P. Testimony therapy: treatment method for traumatized victims of organized violence. Am J Psychother. 2003;57(3):361-73. [pmid: 12961820].
15 Vinar O. An attempt to prevent the sequelae of the posttraumatic stress disorder: experience from the 1997 flood in Moravia. Homeost Health Dis. 1998;38(4):165-8.
16 Williams WV, Polak PR. Follow-up research in primary prevention: a model of adjustment in acute grief. J Clin Psychol. Jan. 1979;35(1):35-45. [pmid: 422729].
17 Zatzick D, Rivara F, Jurkovich G, et al. Enhancing the population impact of collaborative care interventions: mixed method development and implementation of stepped care targeting posttraumatic stress disorder and related comorbidities after acute trauma. Gen Hosp Psychiatry. Mar–Apr. 2011;33(2):123-34. WOS:000289183700006. [pmid: 21596205].

## Excluded for Ineligible Study Design

1 Alford JW. Can patients accurately predict how illness will change their lives?. R I Med. Oct. 1995;78(10):284-5. [pmid: 8541615].
2 Backer J. Perceived stressors of financially secure, community-residing older women. Geriatr Nurs. Jul–Aug. 1995;16(4):155-9. [pmid: 7628739].
3 Bober T, Regehr CD. Strategies for reducing secondary or vicarious trauma: do they work?. Brief Treatment and Crisis Intervention. 2006;6(1):1-9.
4 Bohl N. Measuring the effectiveness of CISD: A study. Fire Engineering. 1995;148:125-6.
5 Briere J, Evans D, Runtz M, et al. Symptomatology in men who were molested as children: a comparison study. Am J Orthopsychiatry. Jul. 1988;58(3):457-61. [pmid: 3407736].
6 Bryant RA, Creamer M, O’Donnell M, et al. A study of the protective function of acute morphine administration on subsequent posttraumatic stress disorder. Biol Psychiatry. 2009;65(5):438-40. [pmid: 19058787].
7 Carr VJ, Lewin TJ, Carter GL, et al. Patterns of service utilisation following the 1989 Newcastle earthquake: findings from phase 1 of the Quake Impact Study. Aust J Public Health. Dec. 1992;16(4):360-9. [pmid: 1296784].
8 Deahl MP, Gillham AB, Thomas J, et al. Psychological sequelae following the Gulf War. Factors associated with subsequent morbidity and the effectiveness of psychological debriefing. Br J Psychiatry. Jul. 1994;165(2):60-5. [pmid: 7953059].
9 Dyregrov A, Gjestad R. A maritime disaster: reactions and follow-up. Int J Emerg Ment Health. Winter. 2003;5(1):3-14. [pmid: 12722485].
10 Flannery RB Jr. Staff victims of elder patient abuse and the Assaulted Staff Action Program (ASAP): preliminary empirical inquiry. Am J Alzheimers Dis Other Demen. Mar–Apr. 2003;18(2):93-6. [pmid: 12708224].
11 Grainger C. Occupational violence: armed holdup - a risk management approach. International Journal of Stress Management. 1995;2(4):197-205.
12 Harris MB, Baloglu M, Stacks JR. MENTAL HEALTH OF TRAUMA-EXPOSED FIREFIGHTERS AND CRITICAL INCIDENT STRESS DEBRIEFING. Journal of Loss & Trauma. 2002;7(3):223-38. [pmid: 6790660].
13 Holbrook TL, Galarneau MR, Dye JL, et al. Morphine Use after Combat Injury in Iraq and Post-Traumatic Stress Disorder. N Engl J Med. Jan. 2010;362(2):110-7. [pmid: 20071700].
14 Irvine J, Firestone J, Ong L, et al. A randomized controlled trial of cognitive behavior therapy tailored to psychological adaptation to an implantable cardioverter defibrillator. Psychosom Med. Apr. 2011;73(3):226-33. [pmid: 21321256].
15 Jackson CT, Covell NH, Shear KM, et al. The road back: predictors of regaining preattack functioning among Project Liberty clients. Psychiatr Serv. Sep. 2006;57(9):1283-90. [pmid: 16968757].
16 Joseph S, Yule W, Williams R, et al. Crisis support in the aftermath of disaster: a longitudinal perspective. Br J Clin Psychol. May. 1993;32(Pt 2):177-85. [pmid: 8318935].
17 Kenardy JA, Webster RA, Lewin TJ, et al. Stress debriefing and patterns of recovery following a natural disaster. J Trauma Stress. Jan. 1996;9(1):37-49. [pmid: 8750450].
18 Kobayashi I, Sledjeski E, Fallon W Jr, et al. Effects of early albuterol (salbutamol) administration on the development of posttraumatic stress symptoms. Psychiatry Res. Jan. 30. 2011;185(1–2):296-8. [pmid: 20546929].
19 Kreitzer MJ, Gross CR, Ye X, et al. Longitudinal impact of mindfulness meditation on illness burden in solid-organ transplant recipients. Prog Transplant. Jun. 2005;15(2):166-72. [pmid: 16013466].
20 Matsuoka Y, Nishi D, Yonemoto N, et al. Omega-3 fatty acids for secondary prevention of posttraumatic stress disorder after accidental injury: an open-label pilot study. J Clin Psychopharmacol. Apr. 2010;30(2):217-9. [pmid: 20520307].
21 Matthews LR. Effect of staff debriefing on posttraumatic stress symptoms after assaults by community housing residents. Psychiatr Serv. Feb. 1998;49(2):207-12. [pmid: 9575006].
22 McGhee LL, Maani CV, Garza TH, et al. The effect of propranolol on posttraumatic stress disorder in burned service members. J Burn Care Res. Jan–Feb. 2009;30(1):92-7. [pmid: 19060728].
23 Miller-Burke J, Attridge M, Fass PM. Impact of traumatic events and organizational response. A study of bank robberies. J Occup Environ Med. Feb. 1999;41(2):73-83. [pmid: 10029951].
24 Mooren TT, de Jong K, Kleber RJ, et al. The efficacy of a mental health program in Bosnia-Herzegovina: impact on coping and general health. J Clin Psychol. Jan. 2003;59(1):57-69. [pmid: 12508331].
25 Nurmi LA. The sinking of the Estonia: the effects of critical incident stress debriefing (CISD) on rescuers. Int J Emerg Ment Health. Winter. 1999;1(1):23-31. [pmid: 11227750].
26 Quinn JF, Strelkauskas AJ. Psychoimmunologic effects of therapeutic touch on practitioners and recently bereaved recipients: a pilot study. ANS Adv Nurs Sci. Jun. 1993;15(4):13-26. [pmid: 8512301].
27 Ryding EL, Persson A, Onell C, et al. An evaluation of midwives’ counseling of pregnant women in fear of childbirth. Acta Obstetricia et Gynecologica Scandanavica. 2003;82(1):10-7.
28 Sullivan MJ, Stanish WD. Psychologically based occupational rehabilitation: the Pain-Disability Prevention Program. Clin J Pain. Mar–Apr. 2003;19(2):97-104. [pmid: 12616179].
29 Tan H. Debriefing after critical incidents for anaesthetic trainees. Anaesth Intensive Care. Dec. 2005;33(6):768-72. [pmid: 16398383].
30 Trusz SG, Wagner AW, Russo J, et al. Assessing Barriers to Care and Readiness for Cognitive Behavioral Therapy in Early Acute Care PTSD Interventions. Psychiatry-Interpersonal and Biological Processes. Fal. 2011;74(3):207-23.
31 Wee DF, Mills DM, Koehler G. The effects of critical incident stress debriefing (CISD) on emergency medical services personnel following the Los Angeles Civil Disturbance. International Journal of Emergency Mental Health. 1999;1(1):33-7. [pmid: 11227752].

## Excluded for Ineligible Population

1 Achterberg J, Kenner C, Casey D. Behavioral strategies for the reduction of pain and anxiety associated with orthopedic trauma. Biofeedback Self Regul. Jun. 1989;14(2):101-14. [pmid: 2675983].
2 Acierno RE, Resnick HS, Flood AM, et al. An acute post-rape intervention to prevent substance use and abuse. Addict Behav. 1701;28(9):1701-15. [pmid: 14656554].
3 Angell KL, Kreshka MA, McCoy R, et al. Psychosocial intervention for rural women with breast cancer: The Sierra-Stanford Partnership. J Gen Intern Med. Jul. 2003;18(7):499-507. [pmid: 12848832].
4 Arving C, Sjoden PO, Bergh J, et al. Satisfaction, utilisation and perceived benefit of individual psychosocial support for breast cancer patients--a randomised study of nurse versus psychologist interventions. Patient Educ Couns. Aug. 2006;62(2):235-43. [pmid: 16500071].
5 Bell KR, Hoffman JM, Temkin NR, et al. The effect of telephone counselling on reducing post-traumatic symptoms after mild traumatic brain injury: a randomised trial. J Neurol Neurosurg Psychiatry. Nov. 2008;79(11):1275-81. [pmid: 18469027].
6 Bisson JI, Jenkins PL, Alexander J, et al. Randomised controlled trial of psychological debriefing for victims of acute burn trauma. Br J Psychiatry. Jul. 1997;171:78-81. [pmid: 9328501].
7 Bisson JI, Shepherd JP, Joy D, et al. Early cognitive-behavioural therapy for post-traumatic stress symptoms after physical injury. Randomised controlled trial. Br J Psychiatry. Jan. 2004;184:63-9. [pmid: 14702229].
8 Boscarino JA, Adams RE, Figley CR. A prospective cohort study of the effectiveness of employer-sponsored crisis interventions after a major disaster. Int J Emerg Ment Health. Winter. 2005;7(1):9-22. [pmid: 15869077].
9 Boscarino JA, Adams RE, Foa EB, et al. A propensity score analysis of brief worksite crisis interventions after the World Trade Center disaster: implications for intervention and research. Med Care. May. 2006;44(5):454-62. [pmid: 16641664].
10 Carlier IV, Voerman AE, Gersons BP. The influence of occupational debriefing on post-traumatic stress symptomatology in traumatized police officers. Br J Med Psychol. Mar. 2000;73(Pt 1):87-98. [pmid: 10759053].
11 Carlsson M, Arman M, Backman M, et al. Coping in women with breast cancer in complementary and conventional care over 5 years measured by the mental adjustment to cancer scale. J Altern Complement Med. Jun. 2005;11(3):441-7. [pmid: 15992227].
12 Cedereke M, Monti K, Ojehagen A. Telephone contact with patients in the year after a suicide attempt: does it affect treatment attendance and outcome? A randomised controlled study. Eur Psychiatry. Apr. 2002;17(2):82-91. [pmid: 11973116].
13 Chan I, Kong P, Leung P, et al. Cognitive-behavioral group program for Chinese heterosexual HIV-infected men in Hong Kong. Patient Educ Couns. Jan. 2005;56(1):78-84. [pmid: 15590226].
14 Chesney MA, Chambers DB, Taylor JM, et al. Coping effectiveness training for men living with HIV: results from a randomized clinical trial testing a group-based intervention. Psychosom Med. Nov–Dec. 2003;65(6):1038-46. [pmid: 14645783].
15 Chierichetti SM, Moise G, Galeone M, et al. Beta-blockers and psychic stress: a double-blind, placebo-controlled study of bopindolol vs lorazepam and butalbital in surgical patients. Int J Clin Pharmacol Ther Toxicol. Sep. 1985;23(9):510-4. [pmid: 2865218].
16 Conlon L, Fahy TJ, Conroy R. PTSD in ambulant RTA victims: a randomized controlled trial of debriefing. J Psychosom Res. Jan. 1999;46(1):37-44. [pmid: 10088980].
17 Constantino RE, Sekula LK, Rubinstein EN. Group intervention for widowed survivors of suicide. Suicide Life Threat Behav. Winter. 2001;31(4):428-41. [pmid: 11775718].
18 Cook CA, Guerrerio JF, Slater VE. Healing touch and quality of life in women receiving radiation treatment for cancer: a randomized controlled trial. Altern Ther Health Med. May–Jun. 2004;10(3):34-41. [pmid: 15154151].
19 de Groot M, de Keijser J, Neeleman J, et al. Cognitive behaviour therapy to prevent complicated grief among relatives and spouses bereaved by suicide: cluster randomised controlled trial. BMJ. May. 12. 2007;334(7601):994. [pmid: 17449505].
20 de Groot M, Neeleman J, van der Meer K, et al. The effectiveness of family-based cognitive-behavior grief therapy to prevent complicated grief in relatives of suicide victims: the mediating role of suicide ideation. Suicide Life Threat Behav. Oct. 2010;40(5):425-37. [pmid: 21034206].
21 Duggan AK, Berlin LJ, Cassidy J, et al. Examining maternal depression and attachment insecurity as moderators of the impacts of home visiting for at-risk mothers and infants. J Consult Clin Psychol. Aug. 2009;77(4):788-99. [pmid: 19634970].
22 Duggan M, Dowd N, O’Mara D, et al. Benzodiazepine premedication may attenuate the stress response in daycase anesthesia: a pilot study. Can J Anaesth. Nov. 2002;49(9):932-5. [pmid: 12419719].
23 Ehlers A, Clark DM, Hackmann A, et al. A randomized controlled trial of cognitive therapy, a self-help booklet, and repeated assessments as early interventions for posttraumatic stress disorder. Arch Gen Psychiatry. 2003;60(10):1024-32. [pmid: 14557148].
24 Fava M, Littman A, Halperin P, et al. Psychological and behavioral benefits of a stress/type A behavior reduction program for healthy middle-aged army officers. Psychosomatics. Summer. 1991;32(3):337-42. [pmid: 1882025].
25 Fernandez-Hermida JR, Secades-Villa R, Fernandez-Ludena JJ, et al. Effectiveness of a therapeutic community treatment in Spain: a long-term follow-up study. Eur Addict Res. Jan. 2002;8(1):22-9. [pmid: 11818690].
26 Field T, Peck M, Scd, et al. Postburn itching, pain, and psychological symptoms are reduced with massage therapy. J Burn Care Rehabil. May–Jun. 2000;21(3):189-93. [pmid: 10850898].
27 Frasure-Smith N, Prince R. Long-term follow-up of the Ischemic Heart Disease Life Stress Monitoring Program. Psychosom Med. Sep–Oct. 1989;51(5):485-513. [pmid: 2798700].
28 Garand L, Buckwalter KC, Lubaroff D, et al. A pilot study of immune and mood outcomes of a community-based intervention for dementia caregivers: the PLST intervention. Arch Psychiatr Nurs. Aug. 2002;16(4):156-67. [pmid: 12143075].
29 Gatchel RJ, Gaffney FA, Smith JE. Comparative efficacy of behavioral stress management versus propranolol in reducing psychophysiological reactivity in post-myocardial infarction patients. J Behav Med. 1986;9(5):503-13. [pmid: 3540309].
30 Gerlock AA. Veterans’ responses to anger management intervention. Issues Ment Health Nurs. Jul–Aug. 1994;15(4):393-408. [pmid: 8056569].
31 Gilbar O, Iron G, Goren A. Adjustment to illness of cancer patients treated by complementary therapy along with conventional therapy. Patient Educ Couns. Sep. 2001;44(3):243-9. [pmid: 11553425].
32 Greenberg N, Langston V, Everitt B, et al. A cluster randomized controlled trial to determine the efficacy of Trauma Risk Management (TRiM) in a military population. J Trauma Stress. Aug. 2010;23(4):430-6. [pmid: 20690168].
33 Hagopian GA, Rubenstein JH. Effects of telephone call interventions on patients’ well-being in a radiation therapy department. Cancer Nurs. Dec. 1990;13(6):339-44. [pmid: 2276106].
34 Hill W, Weinert C, Cudney S. Influence of a computer intervention on the psychological status of chronically ill rural women: preliminary results. Nurs Res. Jan–Feb. 2006;55(1):34-42. [pmid: 16439927].
35 Hilliard RE. The effects of music therapy on the quality and length of life of people diagnosed with terminal cancer. J Music Ther. Summer. 2003;40(2):113-37. [pmid: 14505443].
36 Holmes DS, Frost RO, Bennett DH, et al. Effectiveness of skin resistance biofeedback for controlling arousal in non-stressful and stressful situations: two experiments. J Psychosom Res. 1981;25(3):205-11. [pmid: 7265024].
37 Irvine J, Stanley J, Ong L, et al. Acceptability of a Cognitive Behavior Therapy Intervention to Implantable Cardioverter Defibrillator Recipients. Journal of Cognitive Psychotherapy. 2010;24(4):246-64.
38 Jackson C, Trower P, Reid I, et al. Improving psychological adjustment following a first episode of psychosis: a randomised controlled trial of cognitive therapy to reduce post psychotic trauma symptoms. Behav Res Ther. Jun. 2009;47(6):454-62. [pmid: 19361782].
39 Jenkins SR. Social support and debriefing efficacy among emergency medical Workers After a Mass Shooting Incident. Journal of Social Behavior & Personality. 1996;11(3):477-92.
40 Jerram H, Raeburn J, Stewart A. The Strong Parents-Strong Children Programme: parental support in serious and chronic child illness. N Z Med J. Oct. 28. 2005;118(1224):U1700. [pmid: 16258576].
41 Johnson S, Nolan F, Hoult J, et al. Outcomes of crises before and after introduction of a crisis resolution team. Br J Psychiatry. Jul. 2005;187:68-75. [pmid: 15994574].
42 Jones C, Skirrow P, Griffiths RD, et al. Post-traumatic stress disorder-related symptoms in relatives of patients following intensive care. Intensive Care Med. Mar. 2004;30(3):456-60. [pmid: 14767589].
43 Jones C, Skirrow P, Griffiths RD, et al. Rehabilitation after critical illness: a randomized, controlled trial. Crit Care Med. Oct. 2003;31(10):2456-61. [pmid: 14530751].
44 Kazak AE, Simms S, Alderfer MA, et al. Feasibility and preliminary outcomes from a pilot study of a brief psychological intervention for families of children newly diagnosed with cancer. J Pediatr Psychol. Dec. 2005;30(8):644-55. [pmid: 16260434].
45 Knowles RE, Tarrier N. Evaluation of the effect of prospective patient diaries on emotional well-being in intensive care unit survivors: a randomized controlled trial. Crit Care Med. Jan. 2009;37(1):184-91. [pmid: 19050634].
46 Komesaroff PA, Fullerton M, Esler MD, et al. Oestrogen supplementation attenuates responses to psychological stress in elderly men rendered hypogonadal after treatment for prostate cancer. Clin Endocrinol (Oxf). Jun. 2002;56(6):745-53. [pmid: 12072043].
47 Lechner SC, Antoni MH, Lydston D, et al. Cognitive-behavioral interventions improve quality of life in women with AIDS. J Psychosom Res. Mar. 2003;54(3):253-61. [pmid: 12614835].
48 Lee C, Slade P, Lygo V. The influence of psychological debriefing on emotional adaptation in women following early miscarriage: a preliminary study. Br J Med Psychol. Mar. 1996;69(Pt 1):47-58. [pmid: 8829399].
49 Londborg PD, Hegel MT, Goldstein S, et al. Sertraline treatment of posttraumatic stress disorder: results of 24 weeks of open-label continuation treatment. J Clin Psychiatry. May. 2001;62(5):325-31. [pmid: 11411812].
50 Marchand A, Guay S, Boyer RB, et al. A randomized controlled trial of an adapted form of individual critical incident stress debriefing for victims of an armed robbery. Brief Treatment and Crisis Intervention. 2006;6(2):122-9.
51 Martenyi F, Brown EB, Zhang H, et al. Fluoxetine v. placebo in prevention of relapse in post-traumatic stress disorder. Br J Psychiatry. Oct. 2002;181:315-20. [pmid: 12356658].
52 Martinez-Marti ML, Avia MD, Hernandez-Lloreda MJ. The effects of counting blessings on subjective well-being: a gratitude intervention in a Spanish sample. Span J Psychol. Nov. 2010;13(2):886-96. [pmid: 20977036].
53 Mayou RA, Ehlers A, Hobbs M. Psychological debriefing for road traffic accident victims. Three-year follow-up of a randomised controlled trial. Br J Psychiatry. Jun. 2000;176:589-93. [pmid: 10974967].
54 McCrone P, Weeramanthri T, Knapp M, et al. Cost-effectiveness of individual versus group psychotherapy for sexually abused girls. Child and Adolescent Mental Health. 2005;(1):26-31.
55 Meyer EC, Coll CT, Lester BM, et al. Family-based intervention improves maternal psychological well-being and feeding interaction of preterm infants. Pediatrics. Feb. 1994;93(2):241-6. [pmid: 8121735].
56 Mizuno E, Hosak T, Ogihara R, et al. Effectiveness of a stress management program for family caregivers of the elderly at home. J Med Dent Sci. Dec. 1999;46(4):145-53. [pmid: 12160252].
57 Monti DA, Peterson C, Kunkel EJ, et al. A randomized, controlled trial of mindfulness-based art therapy (MBAT) for women with cancer. Psychooncology. May. 2006;15(5):363-73. [pmid: 16288447].
58 Moser DK, Dracup K. Impact of cardiopulmonary resuscitation training on perceived control in spouses of recovering cardiac patients. Res Nurs Health. Aug. 2000;23(4):270-8. [pmid: 10940952].
59 Neylan TC, Lenoci M, Samuelson KW, et al. No improvement of posttraumatic stress disorder symptoms with guanfacine treatment. Am J Psychiatry. Dec. 2006;163(12):2186-8. [pmid: 17151174].
60 Nugent NR, Christopher NC, Crow JP, et al. The efficacy of early propranolol administration at reducing PTSD symptoms in pediatric injury patients: A pilot study. J Trauma Stress. 2010;23(2):282-7. [pmid: 20419738].
61 Padilla GV, Grant MM, Rains BL, et al. Distress reduction and the effects of preparatory teaching films and patient control. Res Nurs Health. Dec. 1981;4(4):375-87. [pmid: 6173896].
62 Paivio SC, Hall IE, Holowaty KAM, et al. Imaginal confrontation for resolving child abuse issues. Psychotherapy Research. Win. 2001;11(4):433-53.
63 Paniak C, Toller-Lobe G, Reynolds S, et al. A randomized trial of two treatments for mild traumatic brain injury: 1 year follow-up. Brain Inj. Mar. 2000;14(3):219-26. [pmid: 10759039].
64 Perry S, Fishman B, Jacobsberg L, et al. Effectiveness of psychoeducational interventions in reducing emotional distress after human immunodeficiency virus antibody testing. Arch Gen Psychiatry. Feb. 1991;48(2):143-7. [pmid: 1989570].
65 Priest SR, Henderson J, Evans SF, et al. Stress debriefing after childbirth: a randomised controlled trial. Med J Aust. 2003;178(11):542-5. [pmid: 12765500].
66 Resnick H, Acierno R, Waldrop AE, et al. Randomized controlled evaluation of an early intervention to prevent post-rape psychopathology. Behav Res Ther. Oct. 2007;45(10):2432-47. [pmid: 17585872].
67 Resnick HS, Acierno R, Amstadter AB, et al. An acute post-sexual assault intervention to prevent drug abuse: updated findings. Addict Behav. Oct. 2007;32(10):2032-45. [pmid: 17275198].
68 Resnick HS, Acierno RE, Kilpatrick DG, et al. Description of an early intervention to prevent substance abuse and psychopathology in recent rape victims. Behav Modif. 2005;29(1):156-88. [pmid: 15557482].
69 Rice VH, Caldwell M, Butler S, et al. Relaxation training and response to cardiac catheterization: a pilot study. Nurs Res. Jan–Feb. 1986;35(1):39-43. [pmid: 3510422].
70 Robins JL, McCain NL, Gray DP, et al. Research on psychoneuroimmunology: tai chi as a stress management approach for individuals with HIV disease. Appl Nurs Res. Feb. 2006;19(1):2-9. [pmid: 16455435].
71 Robinson FP, Mathews HL, Witek-Janusek L. Psycho-endocrine-immune response to mindfulness-based stress reduction in individuals infected with the human immunodeficiency virus: a quasiexperimental study. J Altern Complement Med. Oct. 2003;9(5):683-94. [pmid: 14629846].
72 Ryding EL, Wijma K, Wijma B. Postpartum counselling after an emergency cesarean. Clinical Psychology & Psychotherapy. 1998;5(4):231-7. [pmid: 11820247].
73 Samarel N, Fawcett J, Tulman L. The effects of coaching in breast cancer support groups: a pilot study. Oncol Nurs Forum. Jun. 1993;20(5):795-8. [pmid: 8337172].
74 Scholes C, Turpin G, Mason S. A randomised controlled trial to assess the effectiveness of providing self-help information to people with symptoms of acute stress disorder following a traumatic injury. Behav Res Ther. Nov. 2007;45(11):2527-36. [pmid: 17662689].
75 Schure LM, van den Heuvel ET, Stewart RE, et al. Beyond stroke: description and evaluation of an effective intervention to support family caregivers of stroke patients. Patient Educ Couns. Jul. 2006;62(1):46-55. [pmid: 16023823].
76 Schwartz L, Drotar D. Effects of written emotional disclosure on caregivers of children and adolescents with chronic illness. J Pediatr Psychol. Mar. 2004;29(2):105-18. [pmid: 15096532].
77 Schwartz LP, Brenner ZR. Critical care unit transfer: reducing patient stress through nursing interventions. Heart Lung. May–Jun. 1979;8(3):540-6. [pmid: 254678].
78 Sedgwick AW, Paul B, Plooij D, et al. Follow-up of stress-management courses. Med J Aust. May. 1. 1989;150(9):485-6. 8. 9. [pmid: 2657351].
79 Sijbrandij M, Olff M, Reitsma JB, et al. Treatment of acute posttraumatic stress disorder with brief cognitive behavioral therapy: A randomized controlled trial. Am J Psychiatry. Jan. 2007;164(1):82-90. [pmid: 17202548].
80 Singh B, Raphael B. Postdisaster morbidity of the bereaved. A possible role for preventive psychiatry?. J Nerv Ment Dis. Apr. 1981;169(4):203-12. [pmid: 7217925].
81 Small R, Lumley J, Donohue L, et al. Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. Oct. 28. 2000;321(7268):1043-7. [pmid: 11053173].
82 Smith KR Jr, Goulding PM, Wilderman D, et al. Neurobehavioral effects of phenytoin and carbamazepine in patients recovering from brain trauma: a comparative study. Arch Neurol. Jul. 1994;51(7):653-60. [pmid: 8018037].
83 Snell FI, Padin-Rivera E. Group treatment for older veterans with post-traumatic stress disorder. J Psychosoc Nurs Ment Health Serv. Feb. 1997;35(2):10-6. [pmid: 9044175].
84 Sonderegger R, Rombouts S, Ocen B, et al. Trauma rehabilitation for war-affected persons in northern Uganda: a pilot evaluation of the EMPOWER programme. Br J Clin Psychol. Sep. 2011;50(3):234-49. [pmid: 21810104].
85 Tarsitani L, De Santis V, Mistretta M, et al. Treatment with β-blockers and incidence of post-traumatic stress disorder after cardiac surgery: a prospective observational study. Cardiothorac Vasc Anesth. 2012;26(2):265-9.
86 Taylor MK, Stanfill KE, Padilla GA, et al. Effect of psychological skills training during military survival school: a randomized, controlled field study. Mil Med. Dec. 2011;176(12):1362-8. [pmid: 22338349].
87 Taylor RD, Brady MP, Swank PR. Crisis intervention: long-term training effects. Psychol Rep. Apr. 1991;68(2):513-4. [pmid: 1862183].
88 Timmerman IG, Emmelkamp PM, Sanderman R. The effects of a stress-management training program in individuals at risk in the community at large. Behav Res Ther. Sep. 1998;36(9):863-75. [pmid: 9701861].
89 Trzcieniecka-Green A, Steptoe A. The effects of stress management on the quality of life of patients following acute myocardial infarction or coronary bypass surgery. Eur Heart J. Nov. 1996;17(11):1663-70. [pmid: 8922914].
90 Turpin G, Downs M, Mason S. Effectiveness of providing self-help information following acute traumatic injury: randomised controlled trial. Br J Psychiatry. Jul. 2005;187:76-82. [pmid: 15994575].
91 van Seventer R, Bach FW, Toth CC, et al. Pregabalin in the treatment of post-traumatic peripheral neuropathic pain: a randomized double-blind trial. Eur J Neurol. Aug. 2010;17(8):1082-9. [pmid: 20236172].
92 van Seventer R, Serpell M, Bach FW, et al. Relationships between changes in pain severity and other patient-reported outcomes: an analysis in patients with posttraumatic peripheral neuropathic pain. Health Qual Life Outcomes. 2011;9:17. [pmid: 21439051].
93 Wagner AW, Zatzick DF, Ghesquiere A, et al. Behavioral Activation as an Early Intervention for Posttraumatic Stress Disorder and Depression Among Physically Injured Trauma Survivors. Cognitive and Behavioral Practice. 2007;14(4):341-9.
94 Walker LG, Walker MB, Ogston K, et al. Psychological, clinical and pathological effects of relaxation training and guided imagery during primary chemotherapy. Br J Cancer. Apr. 1999;80(1–2):262-8. [pmid: 10390006].
95 Weiss JJ, Mulder CL, Antoni MH, et al. Effects of a supportive-expressive group intervention on long-term psychosocial adjustment in HIV-infected gay men. Psychother Psychosom. May–Jun. 2003;72(3):132-40. [pmid: 12707480].
96 Wilson RW, Taliaferro LA, Jacobsen PB. Pilot study of a self-administered stress management and exercise intervention during chemotherapy for cancer. Support Care Cancer. Sep. 2006;14(9):928-35. [pmid: 16625335].
97 Winter MJ, Paskin S, Baker T. Music reduces stress and anxiety of patients in the surgical holding area. J Post Anesth Nurs. Dec. 1994;9(6):340-3. [pmid: 7707258].
98 Zatzick D, Roy-Byrne P, Russo J, et al. A randomized effectiveness trial of stepped collaborative care for acutely injured trauma survivors. Arch Gen Psychiatry. 2004;(5):498-506. [pmid: 15123495].
99 Zatzick DF, Roy-Byrne P, Russo JE, et al. Collaborative interventions for physically injured trauma survivors: a pilot randomized effectiveness trial. Gen Hosp Psychiatry. May–Jun. 2001;23(3):114-23. [pmid: 11427243].
100 Ziemer MM. Effects of information on postsurgical coping. Nurs Res. Sep–Oct. 1983;32(5):282-7. [pmid: 6554617].

## Excluded for Ineligible or No Intervention

1 Bauer BA, Cutshall SA, Anderson PG, et al. Effect of the combination of music and nature sounds on pain and anxiety in cardiac surgical patients: a randomized study. Altern Ther Health Med. Jul–Aug. 2011;17(4):16-23. [pmid: 22314630].
2 Boscarino JA, Adams RE, Figley CR. Mental health service use after the World Trade Center disaster: utilization trends and comparative effectiveness. J Nerv Ment Dis. Feb. 2011;199(2):91-9. [pmid: 21278537].
3 Fauerbach JA, Richter L, Lawrence JW. Regulating acute posttrauma distress. J Burn Care Rehabil. Jul–Aug. 2002;23(4):249-57. [pmid: 12142577].
4 Foss OT. Mental first aid. Soc Sci Med. Feb. 1994;38(3):479-82. [pmid: 8153755].
5 Gidron Y, Gal R, Givati G, et al. Interactive effects of memory structuring and gender in preventing posttraumatic stress symptoms. J Nerv Ment Dis. 2007;195(2):179-82. [pmid: 17299308].
6 Han L, Li JP, Sit JW, et al. Effects of music intervention on physiological stress response and anxiety level of mechanically ventilated patients in China: a randomised controlled trial. J Clin Nurs. Apr. 2010;19(7–8):978-87. [pmid: 20492042].
7 Jones C, Backman C, Capuzzo M, et al. Intensive care diaries reduce new onset post traumatic stress disorder following critical illness: a randomised, controlled trial. Crit Care. 2010;14(5):R168. [pmid: 20843344].
8 Murphy SA. A bereavement intervention for parents following the sudden, violent deaths of their 12–28-year-old children: description and applications to clinical practice. Can J Nurs Res. Winter. 1997;29(4):51-72. [pmid: 9697435].
9 Richards D. The prevention of post-traumatic stress after armed robbery: The impact of a training programme within the Leeds Permanent Building Society. [Doctoral dissertation]. Leeds, England. Leeds Metropolitan University. 1997.
10 Rosenberg L. A qualitative investigation of the use of humor by emergency personnel as a strategy for coping with stress. J Emerg Nurs. Aug. 1991;17(4):197-202. discussion -3. [pmid: 1865612].
11 Solomon Z, Benbenishty R. The role of proximity, immediacy, and expectancy in frontline treatment of combat stress reaction among Israelis in the Lebanon War. Am J Psychiatry. May. 1986;143(5):613-7. [pmid: 3963249].

## Excluded for Ineligible or No Comparator(s)

1 Brewin CR, Fuchkan N, Huntley Z, et al. Outreach and screening following the 2005 London bombings: usage and outcomes. Psychol Med. Dec. 2010;40(12):2049-57. [pmid: 20178677].
2 Frank E, Anderson B, Stewart BD, et al. Efficacy of cognitive behavior therapy and systematic desensitization in the treatment of rape trauma. Behavior Therapy. 1988;19(3):403-20.
3 Hovens JE, van de W. Posttraumatic stress disorder in debriefed survivors of a bus accident. Psychol Rep. Jun. 1998;82(3 Pt 1):1075-81. [pmid: 9676518].
4 Robinson RC, Mitchell JT. Evaluation of psychological debriefings. J Trauma Stress. 1993;6(3):367-82.

## Excluded for Ineligible Outcome(s)

1 Belleau FP, Hagan L, Masse B. Effects of an educational intervention on the anxiety of women awaiting mastectomies. Can Oncol Nurs J. Fall. 2001;11(4):172-80. [pmid: 11842449].
2 Blaha J, Svobodova K, Kapounkova Z. Therapeutical aspects of using citalopram in burns. Acta Chir Plast. 1999;41(1):25-32. [pmid: 10394177].
3 Boesen EH, Ross L, Frederiksen K, et al. Psychoeducational intervention for patients with cutaneous malignant melanoma: a replication study. J Clin Oncol. Feb. 20. 2005;23(6):1270-7. [pmid: 15718325].
4 Bohl N. The effectiveness of brief psychological interventions in police officers after critical incidents. Reese JT, Horn JM, Dunning C, editors. Critical incidents in policing. Washington, DC. US Government Printing Office. 1991.
5 Cohen M, Fried G. Comparing relaxation training and cognitive-behavioral group therapy for women with breast cancer. Research on Social Work Practice. May. 2007;17(3):313-23.
6 Crossmann A, Schulz SM, Kuhlkamp V, et al. A randomized controlled trial of secondary prevention of anxiety and distress in a German sample of patients with an implantable cardioverter defibrillator. Psychosom Med. Jun. 2010;72(5):434-41. [pmid: 20410252].
7 Farchi M, Gidron Y. The effects of “psychological inoculation” versus ventilation on the mental resilience of Israeli citizens under continuous war stress. J Nerv Ment Dis. May. 2010;198(5):382-4. [pmid: 20458203].
8 Field T, Peck M, Krugman S, et al. Burn injuries benefit from massage therapy. J Burn Care Rehabil. May–Jun. 1998;19(3):241-4. [pmid: 9622469].
9 Frenay MC, Faymonville ME, Devlieger S, et al. Psychological approaches during dressing changes of burned patients: a prospective randomised study comparing hypnosis against stress reducing strategy. Burns. Dec. 2001;27(8):793-9. [pmid: 11718981].
10 Hernandez-Ruiz E. Effect of music therapy on the anxiety levels and sleep patterns of abused women in shelters. J Music Ther. Summer. 2005;42(2):140-58. [pmid: 15913391].
11 Hsiao FH, Jow GM, Kuo WH, et al. The effects of psychotherapy on psychological well-being and diurnal cortisol patterns in breast cancer survivors. Psychother Psychosom. 2012;81(3):173-82. [pmid: 22399076].
12 Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
13 Kim S, Kim J. The effects of group intervention for battered women in Korea. Arch Psychiatr Nurs. 2001;(6):257-64. [pmid: 11735076].
14 Lavender T, Walkinshaw SA. Can midwives reduce postpartum psychological morbidity? A randomized trial. Birth. Dec. 1998;25(4):215-9. [pmid: 9892887].
15 Livingston PM, White VM, Hayman J, et al. The psychological impact of a specialist referral and telephone intervention on male cancer patients: a randomised controlled trial. Psychooncology. Jun. 2010;19(6):617-25. [pmid: 19673008].
16 McQuellon RP, Wells M, Hoffman S, et al. Reducing distress in cancer patients with an orientation program. Psychooncology. May–Jun. 1998;7(3):207-17. [pmid: 9638782].
17 McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. Aug. 2011;26(12):2457-82. [pmid: 20889533].
18 Rogers OW. An examination of critical incident stress debriefing for emergency service providers: A quasi-experimental field survey. [9319842]. United States -- Maryland. University of Maryland, Baltimore. 1993.
19 Schelling G, Stoll C, Kapfhammer HP, et al. The effect of stress doses of hydrocortisone during septic shock on posttraumatic stress disorder and health-related quality of life in survivors. Crit Care Med. Dec. 1999;27(12):2678-83. [pmid: 10628609].
20 Sinnakaruppan I, Downey B, Morrison S. Head injury and family carers: a pilot study to investigate an innovative community-based educational programme for family carers and patients. Brain Inj. Apr. 2005;19(4):283-308. [pmid: 15832874].
21 Speca M, Carlson LE, Goodey E, et al. A randomized, wait-list controlled clinical trial: the effect of a mindfulness meditation-based stress reduction program on mood and symptoms of stress in cancer outpatients. Psychosom Med. Sep–Oct. 2000;62(5):613-22. [pmid: 11020090].
22 Telles S, Singh N, Joshi M, et al. Post traumatic stress symptoms and heart rate variability in Bihar flood survivors following yoga: a randomized controlled study. BMC Psychiatry. 2010;10:18. [pmid: 20193089].
23 Utriyaprasit K, Moore SM, Chaiseri P. Recovery after coronary artery bypass surgery: effect of an audiotape information programme. J Adv Nurs. Aug. 2010;66(8):1747-59. [pmid: 20557390].
24 Vazquez LD, Conti JB, Sears SF. Female-specific education, management, and lifestyle enhancement for implantable cardioverter defibrillator patients: the FEMALE-ICD study. Pacing Clin Electrophysiol. Sep. 2010;33(9):1131-40. [pmid: 20487354].
25 Wagner B, Brand J, Schulz W, et al. Online working alliance predicts treatment outcome for posttraumatic stress symptoms in Arab war-traumatized patients. Depress Anxiety. Jul. 2012;29(7):646-51. [pmid: 22678971].
26 Zoellner LA, Feeny NC, Eftekhari A, et al. Changes in negative beliefs following three brief programs for facilitating recovery after assault. Depress Anxiety. Jul. 2011;28(7):532-40. [pmid: 21721072].

## Ineligible Timing

1 Beatty L, Oxlad M, Koczwara B, et al. A randomised pilot of a self-help workbook intervention for breast cancer survivors. Support Care Cancer. Dec. 2010;18(12):1597-603. [pmid: 20669035].
2 Cohen L, Warneke C, Fouladi RT, et al. Psychological adjustment and sleep quality in a randomized trial of the effects of a Tibetan yoga intervention in patients with lymphoma. Cancer. May. 15. 2004;100(10):2253-60. [pmid: 15139072].
3 Donahue SA, Jackson CT, Shear KM, et al. Outcomes of enhanced counseling services provided to adults through Project Liberty. Psychiatr Serv. Sep. 2006;57(9):1298-303. [pmid: 16968759].
4 Ford JD, Greaves D, Chandler P, et al. Time-limited psychotherapy with Operation Desert Storm veterans. J Trauma Stress. 1997;10(4):655-64. [pmid: 9391948].
5 Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women’s response to a culturally informed intervention. J Consult Clin Psychol. Aug. 2010;78(4):449-58. [pmid: 20658802].
6 Knaevelsrud C, Maercker A. Internet-based treatment for PTSD reduces distress and facilitates the development of a strong therapeutic alliance: a randomized controlled clinical trial. BMC Psychiatry. 2007;7:13. [pmid: 17442125].
7 Lange A, Rietdijk D, Hudcovicova M, et al. Interapy: A controlled randomized trial of the standardized treatment of posttraumatic stress through the Internet. J Consult Clin Psychol. Oct. 2003;71(5):901-9. [pmid: 14516238].
8 Marx CE. Secondary Prevention With Paroxetine vs. Placebo in Subthreshold Posttraumatic Stress Disorder (PTSD). Under review. Retrieved at http://ClinicalTrials.gov/show/NCT00560612 on July 9, 2012. ClinicalTrials.gov identifier: NCT00560612.
9 McKibben ES, Britt TW, Hoge CW, et al. Receipt and rated adequacy of stress management training is related to PTSD and other outcomes among Operation Iraqi Freedom Veterans. Military Psychology. 2009;21(Supplement):S68-S81.
10 Mouilso ER, Calhoun KS, Gidycz CA. Effects of participation in a sexual assault risk reduction program on psychological distress following revictimization. J Interpers Violence. Mar. 2011;26(4):769-88. [pmid: 20448229].
11 Murphy SA. The use of research findings in bereavement programs: a case study. Death Stud. 2000;24(7):585-602. [pmid: 11503670].
12 Murphy SA, Johnson C, Cain KC, et al. Broad-spectrum group treatment for parents bereaved by the violent deaths of their 12- to 28-year-old children: a randomized controlled trial. Death Stud. 1998;22(3):209-35. [pmid: 10182433].
13 Resick PA, Schnicke MK. Cognitive processing therapy for sexual assault victims. J Consult Clin Psychol. Oct. 1992;60(5):748-56. [pmid: 1401390].
14 Scheck MM, Schaeffer JA, Gillette C. Brief psychological intervention with traumatized young women: The efficacy of eye movement desensitization and reprocessing. J Trauma Stress. Jan. 1998;11(1):25-44. [pmid: 9479674].
15 Schoutrop MJ, Lange A, Brosschot JF, et al. Structured writing in processing traumatic events: A comparison of self-confrontation and cognitive reappraisal. Dissertation. Amsterdam. Foundation Centrum. 2000.
16 Schoutrop MJ, Lange A, Hanewald G, et al. Structured writing and processing major stressful events: a controlled trial. Psychother Psychosom. May–Jun. 2002;71(3):151-7. [pmid: 12021557].
17 Schreiber S, Dolberg OT, Barkai G, et al. Primary intervention for memory structuring and meaning acquisition (PIMSMA): study of a mental health first-aid intervention in the ED with injured survivors of suicide bombing attacks. Am J Disaster Med. Nov–Dec. 2007;2(6):307-20. [pmid: 18297951].
18 Sharpley JG, Fear NT, Greenberg N, et al. Pre-deployment stress briefing: does it have an effect?. Occup Med. 2008;58(1):30-4.
19 Shemesh E, Koren-Michowitz M, Yehuda R, et al. Symptoms of posttraumatic stress disorder in patients who have had a myocardial infarction. Psychosomatics. May–Jun. 2006;47(3):231-9. [pmid: 16684940].
20 Simpson GK, Tate RL, Whiting DL, et al. Suicide prevention after traumatic brain injury: a randomized controlled trial of a program for the psychological treatment of hopelessness. J Head Trauma Rehabil. Jul–Aug. 2011;26(4):290-300. [pmid: 21734512].
21 Wilson SA, Becker LA, Tinker RH. Eye movement desensitization and reprocessing (EMDR) treatment for psychologically traumatized individuals. J Consult Clin Psychol. Dec. 1995;63(6):928-37. [pmid: 8543715].
22 Zlotnick C, Capezza NM, Parker D. An interpersonally based intervention for low-income pregnant women with intimate partner violence: a pilot study. Arch Womens Ment Health. Feb. 2011;14(1):55-65. [pmid: 21153559].