# Abstract and Full-Text Form Fields

The following are lists of fields used in the abstract and full-text review forms. Please see the Evidence Tables (Appendix E) for fields used in the data abstraction forms.

Table C1 Abstract review form fields

REF ID
Author
Year
Title
Abstract
Exclude (Select an option from the dropdown list)
Include
Background? (To suggest an abstract that would otherwise be excluded from the review for use as background information, mark it with BKG, along with EXC and the exclusion number/code. Use BKG judiciously!)
Comments: Please include a comment if you included an abstract, but did so do to a lack of clarity within the abstract. Explain why you think the FT will reveal that the study should be excluded.

Table C2 Full text review form fields

Ref ID
Authors
Year
Title
Inclusion/Exclusion Code
Should article be included as background? (‘X’)
Design
Subpopulations
Psychological Interventions (‘X’)
Pharmacological Interventions (‘X’)
CAM Interventions (‘X’)
Group 1 (Main treatment group)
Group 2 (First comparison group)
Group 3 (Second comparison group, if applicable)
Group 4 (Third comparison group, if applicable)
KQ 1 (‘X’)
KQ 2 (‘X’)
KQ 3 (‘X’)
KQ 4 (‘X’)
Comments
Does the study belong to a set of Companion Studies? (Yes/No)
Include citations of any Companion Studies here