# Literature Search Strategies

MEDLINE^®^

Search | Query | Items found
| Search “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 207835
| Search “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 21591
| Search “Social Problems/psychology”[Mesh] | 39134
| Search “Life Change Events”[Mesh] | 17145
| Search “Stress, Psychological”[Mesh] | 77741
| Search “Wounds and Injuries/psychology”[Mesh] | 12844
| Search “Disasters”[Mesh] | 53875
| Search “survival/psychology”[Mesh] | 367
| Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 | 390089
| Search #9 Limits: Humans, English, All Adult: 19+ years | 145273
| Search “Anesthetics, Dissociative”[Pharmacological Action] OR “Opiate Alkaloids”[Mesh] OR “Benzodiazepines”[MeSH] OR “Tranquilizing Agents”[Pharmacological Action] OR “Antipsychotic Agents”[Pharmacological Action] OR “Adrenergic Agents”[Pharmacological Action] OR “Anticonvulsants”[Pharmacological Action] OR “Monoamine Oxidase Inhibitors”[Pharmacological Action] OR “Antidepressive Agents”[Pharmacological Action] OR “Psychotropic Drugs”[Mesh] | 691213
| Search #10 AND #11 | 4622
| Search “Psychotherapy”[Mesh] OR “Complementary Therapies”[Mesh] OR “Therapeutics/psychology”[Mesh] OR “Adaptation, Psychological”[Mesh] OR “Mental Health Services”[Mesh] | 425466
| Search #10 AND #13 | 20742
| Search “prevention and control” [Subheading] | 890704
| Search “prevention”[tiab] OR “prevent”[tiab] OR “preventive”[tiab] OR “preventative”[tiab] | 567453
| Search “early intervention”[tiab] | 7594
| Search “Emergency Treatment/psychology”[Mesh] | 1043
| Search “Crisis Intervention”[Mesh] | 4917
| Search “Resilience, Psychological”[Mesh] | 667
| Search “Preventive Health Services”[MeSH] | 373860
| Search “Preventive Medicine”[Mesh] | 31385
| Search “immediate treatment”[tiab] | 1682
| Search #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 | 1517709
| Search (#12 OR #14) AND #24 | 5026
| Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 464580
| Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 52267
| Search “Comparative Study”[Publication Type] OR “comparative study” OR case control stud* OR “Case-Control Studies”[Mesh] | 2006988
| Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 45060
| Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] | 1210509
| Search #26 OR #27 OR #28 OR #29 OR #30 | 2970190
| Search #25 AND #31 | 1810
| Search “Stress Disorders, Post-Traumatic/prevention and control”[Mesh] | 834
| Search #31 AND #33 | 158
| Search #34 Limits: Humans, English, All Adult: 19+ years | 101
| Search #32 OR #35 | 1855

PILOTS Database Search
- PILOTS search done January 5, 2012 using the following search criteria; 188 unique results found.
  DE=“adults” and DE=“prevention” and DE=“ptsd”
  English Only

Cochrane

ID | Search | Hits
#1 | “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 9433
#2 | “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 1218
#3 | “Social Problems/psychology”[Mesh] | 2
#4 | “Life Change Events”[Mesh] | 381
#5 | “Stress, Psychological”[Mesh] | 2934
#6 | “Wounds and Injuries/psychology”[Mesh] | 33
#7 | “Disasters”[Mesh] | 104
#8 | “survival/psychology”[Mesh] | 4
#9 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8) | 12820
#10 | “Anesthetics, Dissociative”[Pharmacological Action] OR “Opiate Alkaloids”[Mesh] OR “Benzodiazepines”[MeSH] OR “Tranquilizing Agents”[Pharmacological Action] OR “Antipsychotic Agents”[Pharmacological Action] OR “Adrenergic Agents”[Pharmacological Action] OR “Anticonvulsants”[Pharmacological Action] OR “Monoamine Oxidase Inhibitors”[Pharmacological Action] OR “Antidepressive Agents”[Pharmacological Action] OR “Psychotropic Drugs”[Mesh] | 13154
#11 | (#1 AND #10) | 269
#12 | “Psychotherapy”[Mesh] OR “Complementary Therapies”[Mesh] OR “Therapeutics/psychology”[Mesh] OR “Adaptation, Psychological”[Mesh] OR “Mental Health Services”[Mesh] | 10506
#13 | (#1 AND #12) | 572
#14 | (#11 OR #13) | 777
#15 | “prevention”[tiab] OR “prevent”[tiab] OR “preventive”[tiab] OR “preventative”[tiab] | 100796
#16 | “early intervention”[tiab] | 1157
#17 | “Emergency Treatment/psychology”[Mesh] | 2
#18 | “Crisis Intervention”[Mesh] | 263
#19 | “Resilience, Psychological”[Mesh] | 21
#20 | “Preventive Health Services”[MeSH] | 443
#21 | “Preventive Medicine”[Mesh] | 2727
#22 | “immediate treatment”[tiab] | 246
#23 | (#15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22) | 101847
#24 | (#14 AND #23) | 266
#25 | “Adult”[Mesh] | 270874
#26 | (#24 AND #25) | 155
#27 | (#26) | 148

IPA, CINAHL, PsychINFO

# | Query | Limiters/Expanders | Results
S11 | S10 | Limiters - English Language; Human; Language: English; Age Groups: All Adult; Language: English; Articles about Human Studies; English; Language: English; Age Groups: Adulthood (18 yrs & older), Young Adulthood (18–29 yrs), Thirties (30–39 yrs), Middle Age (40–64 yrs), Aged (65 yrs & older), Very Old (85 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 124
S10 | S8 and S9 | Search modes - Boolean/Phrase | 456
S9 | “prevention” OR (MH “Early Intervention+”) | Search modes - Boolean/Phrase | 516323
S8 | S5 or S7 | Search modes - Boolean/Phrase | 2562
S7 | S3 and S6 | Search modes - Boolean/Phrase | 1672
S6 | DE “Drug Therapy” | Search modes - Boolean/Phrase | 96635
S5 | S3 and S4 | Search modes - Boolean/Phrase | 902
S4 | DE “Psychotherapeutic Techniques” OR DE “Animal Assisted Therapy” OR DE “Autogenic Training” OR DE “Cotherapy” OR DE “Dream Analysis” OR DE “Ericksonian Psychotherapy” OR DE “Guided Imagery” OR DE “Mirroring” OR DE “Morita Therapy” OR DE “Motivational Interviewing” OR DE “Mutual Storytelling Technique” OR DE “Paradoxical Techniques” OR DE “Psychodrama” | Search modes - Boolean/Phrase | 25870
S3 | S1 or S2 | Search modes - Boolean/Phrase | 163590
S2 | “Injuries” OR DE “Burns” OR DE “Electrical Injuries” OR DE “Head Injuries” OR DE “Spinal Cord Injuries” OR DE “Wounds” | Search modes - Boolean/Phrase | 119613
S1 | “Posttraumatic Stress Disorder” OR DE “Reactive Psychosis” OR DE “Stress Reactions” OR DE “Psychological Stress” OR DE “Acute Stress Disorder” OR DE “Emotional Trauma” | Search modes - Boolean/Phrase | 45455

EMBASE

No. | Query | Results
#1 | ‘posttraumatic stress disorder’/exp | 26,817
#2 | ‘psychotherapy’/exp | 174,672
#3 | ‘drug therapy’/exp | 1,526,816
#4 | #2 OR #3 | 1,688,791
#5 | #1 AND #4 | 5,638
#6 | ‘prevention’/exp OR ‘early intervention’/exp | 934,844
#7 | #5 AND #6 | 202
#8 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘systematic review’/exp OR ‘cohort analysis’/exp OR ‘meta analysis’/exp OR ‘comparative study’/exp OR ‘case control study’/exp | 1,448,799
#9 | #7 AND #8 | 37

Web of Science

Set | Results | Query
# 12 | 108 | #11 AND #8 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 11 | 336,240 | #10 OR #9 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 10 | 50,812 | (TS=(early intervention)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 9 | 291,955 | (TS=(prevention)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 8 | 1,418 | #7 AND #4 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 7 | 54,820 | #6 OR #5 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 6 | 15,172 | TS=(pharmacotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 41,223 | TS=(Psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 39,541 | #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 12,815 | TS=(“post trauma*”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 27,812 | TS=(posttraumatic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 1 | 11,784 | TS=(PTSD) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On

Total references identified by the main searches, minus duplicates = 2364

Total references from main and handsearches, minus duplicates = 2438

The following update searches were conducted on July 30, 2012

MEDLINE^®^

Search | Query | Items found
#1 | Search “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 215392
#2 | Search “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 22750
#3 | Search “Social Problems/psychology”[Mesh] | 40575
#4 | Search “Life Change Events”[Mesh] | 17610
#5 | Search “Stress, Psychological”[Mesh] | 80886
#6 | Search “Wounds and Injuries/psychology”[Mesh] | 13375
#7 | Search “Disasters”[Mesh] | 55059
#8 | Search “Survival/psychology”[Mesh] | 379
#9 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 | 403607
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 Filters: Humans | 342462
#11 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 Filters: Humans; English | 278680
#12 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 Filters: Humans; English; Adult: 19+ years | 151076
#13 | Search “Anesthetics, Dissociative”[Pharmacological Action] OR “Opiate Alkaloids”[Mesh] OR “Benzodiazepines”[MeSH] OR “Tranquilizing Agents”[Pharmacological Action] OR “Antipsychotic Agents”[Pharmacological Action] OR “Adrenergic Agents”[Pharmacological Action] OR “Anticonvulsants”[Pharmacological Action] OR “Monoamine Oxidase Inhibitors”[Pharmacological Action] OR “Antidepressive Agents”[Pharmacological Action] OR “Psychotropic Drugs”[Mesh] | 701274
#14 | Search #12 and #13 | 4732
#15 | Search “Psychotherapy”[Mesh] OR “Complementary Therapies”[Mesh] OR “Therapeutics/psychology”[Mesh] OR “Adaptation, Psychological”[Mesh] OR “Mental Health Services”[Mesh] | 438499
#16 | Search #12 and #15 | 21625
#17 | Search “prevention and control” [Subheading] | 919536
#18 | Search “prevention”[tiab] OR “prevent”[tiab] OR “preventive”[tiab] OR “preventative”[tiab] | 591226
#19 | Search “early intervention”[tiab] | 8083
#20 | Search “Emergency Treatment/psychology”[Mesh] | 1083
#21 | Search “Crisis Intervention”[Mesh] | 4974
#22 | Search “Resilience, Psychological”[Mesh] | 850
#23 | Search “Preventive Health Services”[MeSH] | 385136
#24 | Search “Preventive Medicine”[Mesh] | 31611
#25 | Search “immediate treatment”[tiab] | 1745
#26 | Search #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 | 1570081
#27 | Search (#14 OR #16) AND #26 | 5239
#28 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 481850
#29 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 57134
#30 | Search “Comparative Study”[Publication Type] OR “comparative study” OR case control stud* OR “Case-Control Studies”[Mesh] | 2059195
#31 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 49778
#32 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] | 1264820
#33 | Search #28 or #29 or #30 or #31 or #32 | 3065032
#34 | Search #27 and #33 | 1914
#35 | Search “Stress Disorders, Post-Traumatic/prevention and control”[Mesh] | 870
#36 | Search #33 and #35 | 170
#37 | Search #33 and #35 Filters: Humans | 167
#38 | Search #33 and #35 Filters: Humans; English | 163
#39 | Search #33 and #35 Filters: Humans; English; Adult: 19+ years | 108
#40 | Search #34 OR #39 | 1962
#41 | Search #40 AND (2011/12:2012/07[edat]) | 33

PILOTS
- PILOTS search limited to Date Range= 2011–2012 using the following search criteria; 40 unique results.
  DE=“adults” and DE=“prevention” and DE=“ptsd”
  English Only

Cochrane Library

ID | Search | Hits
#1 | “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 10124
#2 | “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 1304
#3 | “Social Problems/psychology”[Mesh] | 2
#4 | “Life Change Events”[Mesh] | 392
#5 | “Stress, Psychological”[Mesh] | 3096
#6 | “Wounds and Injuries/psychology”[Mesh] | 34
#7 | “Disasters”[Mesh] | 113
#8 | “Survival/psychology”[Mesh] | 4
#9 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8) | 13678
#10 | “Anesthetics, Dissociative”[Pharmacological Action] OR “Opiate Alkaloids”[Mesh] OR “Benzodiazepines”[MeSH] OR “Tranquilizing Agents”[Pharmacological Action] OR “Antipsychotic Agents”[Pharmacological Action] OR “Adrenergic Agents”[Pharmacological Action] OR “Anticonvulsants”[Pharmacological Action] OR “Monoamine Oxidase Inhibitors”[Pharmacological Action] OR “Antidepressive Agents”[Pharmacological Action] OR “Psychotropic Drugs”[Mesh] | 13673
#11 | (#1 AND #10) | 354
#12 | “Psychotherapy”[Mesh] OR “Complementary Therapies”[Mesh] OR “Therapeutics/psychology”[Mesh] OR “Adaptation, Psychological”[Mesh] OR “Mental Health Services”[Mesh] | 11130
#13 | (#1 AND #12) | 682
#14 | (#11 OR #13) | 939
#15 | “prevention”[tiab] OR “prevent”[tiab] OR “preventive”[tiab] OR “preventative”[tiab] | 105103
#16 | “early intervention”[tiab] | 1308
#17 | “Emergency Treatment/psychology”[Mesh] | 2
#18 | “Crisis Intervention”[Mesh] | 293
#19 | “Resilience, Psychological”[Mesh] | 25
#20 | “Preventive Health Services”[MeSH] | 462
#21 | “Preventive Medicine”[Mesh] | 2953
#22 | “immediate treatment”[tiab] | 276
#23 | (#15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22) | 106214
#24 | (#14 AND #23) | 392
#25 | “Adult”[Mesh] | 279877
#26 | (#24 AND #25) | 232
#27 | (#26), from 2011 to 2012 | 70

IPA, CINAHL, PsycINFO

Search ID# | Search Terms | Search Limits | Results
S1 | “Posttraumatic Stress Disorder” OR DE “Reactive Psychosis” OR DE “Stress Reactions” OR DE “Psychological Stress” OR DE “Acute Stress Disorder” OR DE “Emotional Trauma” | | 47098
S2 | “Injuries” OR DE “Burns” OR DE “Electrical Injuries” OR DE “Head Injuries” OR DE “Spinal Cord Injuries” OR DE “Wounds” | | 125584
S3 | S1 or S2 | | 171131
S4 | DE “Psychotherapeutic Techniques” OR DE “Animal Assisted Therapy” OR DE “Autogenic Training” OR DE “Cotherapy” OR DE “Dream Analysis” OR DE “Ericksonian Psychotherapy” OR DE “Guided Imagery” OR DE “Mirroring” OR DE “Morita Therapy” OR DE “Motivational Interviewing” OR DE “Mutual Storytelling Technique” OR DE “Paradoxical Techniques” OR DE “Psychodrama” | | 26493
S5 | S3 and S4 | | 918
S6 | DE “Drug Therapy” | | 100216
S7 | S3 and S6 | | 1748
S8 | S5 or S7 | | 2653
S9 | “prevention” OR (MH “Early Intervention+”) | | 539111
S10 | S8 and S9 | | 475
S11 | S10 | Limiters - English Language; Human; Language: English; Age Groups: Adult: 19–44 years, Middle Aged: 45–64 years, Aged: 65+ years, Aged, 80 and over, All Adult; Language: English; Articles about Human Studies; English; Language: English; Age Groups: Adulthood (18 yrs & older), Young Adulthood (18–29 yrs), Thirties (30–39 yrs), Middle Age (40–64 yrs), Aged (65 yrs & older), Very Old (85 yrs & older); Population Group: Human; Exclude Dissertations | 132
S12 | S11 | Limiters - Published Date from: 20111201–20120731 | 5

Note: The number of available results reflects the removal of duplicates.

EMBASE

No. | Query | Results
#1 | ‘posttraumatic stress disorder’/exp | 28,724
#2 | ‘psychotherapy’/exp | 180,063
#3 | ‘drug therapy’/exp | 1,606,636
#4 | #2 OR #3 | 1,773,200
#5 | #1 AND #4 | 6,041
#6 | ‘prevention’/exp OR ‘early intervention’/exp | 976,054
#7 | #5 AND #6 | 230
#8 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘systematic review’/exp OR ‘cohort analysis’/exp OR ‘meta analysis’/exp OR ‘comparative study’/exp OR ‘case control study’/exp | 1,516,832
#9 | #7 AND #8 | 44
#10 | #9 AND [1-12-2011]/sd NOT [30-7-2012]/sd | 8

Web of Science

Set | Results | Query
# 1 | 12,757 | TS=(PTSD) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 29,614 | TS=(posttraumatic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 13,588 | TS=(“post trauma*”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 42,065 | #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 42,555 | TS=(Psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 6 | 16,068 | TS=(pharmacotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 7 | 56,975 | #6 OR #5 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 8 | 1,546 | #7 AND #4 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 9 | 308,926 | (TS=(prevention)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 10 | 54,447 | (TS=(early intervention)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 11 | 356,307 | #10 OR #9 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 12 | 118 | #11 AND #8 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
#13 | 18 | #12 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On