# PTSD Outcome Measures and Instruments

Abbreviated Name | Complete Name | Description | Range/Meaning of Possible Scores | Improvement Indicated by
CAPS | Clinician-Administered PTSD Scale | Structured interview administered by a trained professional that assesses symptoms, impact on functioning, response validity, lifetime diagnosis, and overall PTSD severity. Includes 30 items that correspond to the DSM-IV diagnostic criteria for PTSD. Time frame for assessment includes past week, month, or worst month since trauma. | 0 to 136 | Decrease
CIDI-PTSD | PTSD module of the Composite International Diagnostic Interview | Structured diagnostic interview that based on ICD-10 and DSM-IV PTSD criteria. Once exposure to at least one such traumatic event is established, lifetime symptoms of PTSD are assessed. | CIDI-PTSD | PTSD module of the Composite International Diagnostic Interview
IES | Impact of Event Scale | 15-item self-report measure that assesses the frequency of experiences of intrusions, avoidance, and emotional numbing related to stressful events in the last week. A total distress score is calculated by summing all 15 item responses. | 0 to 75 | Decrease
IES-R | Impact of Event Scale-Revised | 22-item self-report measure of subjective distress caused by traumatic events. Includes 7 additional items regarding hyperarousal symptoms of PTSD. Items correspond directly to 14 of the 17 DSM-IV symptoms of PTSD. Subscale scores can be computed for Intrusion, Avoidance, and Hyperarousal. | 0 to 88 | Decrease
MINI-PTSD | PTSD module of the MINI International Neuropsychiatric | Structured interview includes 6 areas of diagnostic criteria corresponding to DSM-IV and ICD-10. The module begins with screening questions to determine if criterion A of the DSM-IV met and follows with questions about PTSD symptoms and interference. | NA | NA
PCL | PTSD Checklist | 17-item self-report measure of the 17 DSM-IV symptoms of PTSD. The PCL has been used to screen individuals for PTSD, diagnose PTSD, and monitor symptom change during and after treatment. There are three versions of the PCL: PCL-M (military), PCL-C (civilian), and PCL-S (specific). | 17 to 85 | Decrease
PDS or PTDS | Posttraumatic Diagnostic Scale | 49 item self-report measure of PTSD symptom severity related to a single identified traumatic event. Assesses all DSM-IV criteria (A-F) in the past month (time frame can be adjusted) using 4 sections: trauma checklist, description of traumatic event, assessment of 17 PTSD symptoms, and interference of symptoms. Total severity score reflecting frequency of 17 PTSD symptoms. | 0 to 51 | Decrease
PHSI-P | Post-Hospital Stress Index for Parents | A 20–item self-report questionnaire of symptoms based on DSM-IV PTSD criteria. | 0 to 20 | Decrease
PSS | PTSD Symptom Scale | 17-item semi-structured interview or scale that assesses the presence and severity of DSM-IV PTSD symptoms related to a single identified traumatic event in individuals with a known trauma history. Each item is assessed with a brief, single question. There are two versions of the PSS: PSS-I (interview that asks about symptoms experienced in the past 2 weeks) and PSS-SR (self-report). | 0 to 51 | Decrease
PTSS-10 | Posttraumatic Stress Symptom 10 Question Inventory | 10-item self-report questionnaire that assesses the presence and intensity of post-traumatic stress symptoms based on the DSM-III. Patients rate the presence and severity of each symptom during the past 7 days. | 10 to 70 | Decrease
SI-PTSD | Structured Interview for PTSD | Assesses the 17 PTSD symptoms as well as survival and behavioral guilt. For each item, the interviewer assigns a severity rating that reflects both frequency and intensity. Responses can be used to make a determination about whether client’s symptoms meet DSM criteria B, C, and D for PTSD | 0 to 68 | Decrease

Abbreviations: DSM-III-R= Diagnostic and Statistical Manual Criteria, third edition; DSM-IV= Diagnostic and Statistical Manual Criteria, fourth edition; ICD-10 = International Classification of Diseases, tenth revision; NA = not applicable; PTSD = posttraumatic stress disorder.