# Results

Of 510 retrieved references, we excluded 104 at screening as not relevant to pediatric migraine, and we reviewed full texts of 312 references (Figure 2). We ultimately included 24 references of randomized controlled clinical trials, two abstracts of randomized controlled clinical trials, and 16 nonrandomized studies. We did not rank strength of evidence for two RCTs of flunarizine because, despite being commonly used elsewhere, this drug is not approved by the FDA. We found one eligible FDA review that evaluated a clinical trial of divalproex sodium used to prevent migraine headache in adolescents.69

Figure 2 Study flow^*^ * References for RCTs included multiple publications and reanalyses of RCTs.

This figure depicts the study flow that contains the number of retrieved, included, and excluded studies. The investigators retrieved a total of 510 studies from Medline, the Cochrane library, the website of the Federal Drug Administration, manual searches of reference lists, and other sources. They included 42 references and excluded the rest of the references because excluded studies examined target populations, treatments, or outcomes not eligible for the report. The review authors synthesized the evidence from 22 randomized controlled clinical trials and 16 non randomized therapeutic studies.

Of 14 completed clinical trials registered in ClinicalTrials.gov, four were published. Publications occurred 1.8±1.2 years after study completion. Completion dates were missing for three completed unpublished studies of divalproex. Of the nine Phase III studies involving exclusively children, none posted the results on ClinicalTrials.gov. The results were not available for 4,001 subjects enrolled in studies involving children or 1,093 children enrolled in exclusive pediatric studies.

Appendix D provides evidence tables with the results from the included studies. Appendix E presents all excluded studies with exact reasons for exclusion.

## Study Overview

### Characteristics

The results from the eligible studies were applicable to the target population. Most trials were conducted in Western countries and recruited children and adolescents in clinics. Only two trials recruited participants from the community. We analyzed baseline characteristics of the included children and concluded that enrolled patients represented the epidemiology of migraine in the target population (Table 4 and Appendix Table D1). Caucasian girls made up more than half of all enrolled subjects. Many enrolled subjects were overweight according to the mean age and mean body mass index. Children had migraine for an average 3.6 years, and suffered from an average of eight migraine attacks per month. Most trials defined migraine according to diagnostic criteria of the International Headache Society (Appendix Table D2). Reporting other characteristics of children was poor. More than half the trials failed to report family history of migraine, children's socioeconomic status, baseline comorbidity, prior treatments, overuse of drugs for acute migraine, or adherence to assigned treatments.

Table 4 Subject characteristics in randomized controlled clinical trials that examined migraine prevention in children

Drugs References for RCTs^*^ | Age # RCTs / Mean [Min to Max] | % Female # RCTs / Mean [Min to Max] | Baseline Frequency of Migraine/Month # RCTs / Mean [Min to Max] | Duration of Migraine, Years # RCTs / Mean [Min to Max] | Obesity, BMI # RCTs / Mean [Min to Max] | Family History of Migraine, % # RCTs / Mean [Min to Max]
Topiramate81-87 | 7 / 12.6 [10.5 to 14.2] | 7 / 56.9 [31.0 to 71.4] | 5 / 9.6 [4.1 to 17.3] | 1 / 4.2 | 2 / 23.3 [21.7 to 24.9] | 0
Divalproex69,73,96 | 1 / 14.2 | 1 / 55.0 | 1 / 17.2 | 0 | 1 / 23.2 | 0
Valproate69,73,96 | 1 / 9.8 | 1 / 33.9 | 1 / 7.9 | 0 | 0 | 0
Propranolol77-80 | 2 / 9.5 [9.2 to 9.9] | 4 / 40.6 [33.0 to 46.2] | 3 / 10.3 [3.4 to 14.0] | 1 / 4.0 | 0 | 3 / 66.8 [13.0 to 100.0]
Metoprolol75 | 1 / 11.3 | 1 / 39.5 | 1 / 5.4 | 1 / 4.7 | 0 | 0
Trazodone70 | 1 / 12.6 | 1 / 45.0 | 1 / 3.8 | 1 / 4.5 | 0 | 1 / 67.5
Nimodipine76 | 1 /12.2 | 1 / 51.4 | 1 / 3.2 | 0 | 0 | 0
Clonidine71,72 | 1 / 11.0 | 2 / 41.4 [38.6 to 44.2] | 1 / 3.5 | 0 | 0 | 1 / 90.7
Magnesium74 | 1 / 12.0 | 1 68.6 | 1 / 10.5 | 1 / 3.5 | 0 | 0
Drug management89 | 1 / 12.7 | 1 / 54.6 | 1 / 4.0 | 1 / 2.8 | 0 | 0
Total | 17 / 11.8 [9.2 to 14.2] | 20 / 49.9 [31.0 to 71.4] | 16 / 8.4 [3.2 to 17.3] | 6 / 3.6 [2.2 to 4.7] | 3 / 23.3 [21.7 to 24.9] | 5 / 75.0 [13.0 to 100.0]

BMI = body mass index; RCT = randomized controlled trial

* Include multiple publications of RCTs.

Based on infrequently reported trial flows, we estimated that investigators had to screen one to four children to enroll one (Appendix Table D3). Because we based our estimate on rarely reported study flow information in the original studies, it may have low applicability. The trials lasted an average of 20 weeks (ranging from 6 to 35 weeks) (Table 5). Attrition rates with active treatments averaged around 6.5 percent.

Table 5 Sample, duration, length of followup, and attrition in randomized controlled clinical trials that examined migraine prevention in children

Drug References for RCTs^*^ | Duration of Run-In Period, Weeks # RCTs / Mean [Min to Max] | Total Sample Assigned to Treatment # RCTs / Mean [Min to Max] | Total Length of Followup, Weeks # RCTs / Mean [Min to Max] | Loss of Followup in Control Group, % # RCTs / Mean [Min to Max] | Loss of Followup in Active Group, % # RCTs / Mean [Min to Max]
Topiramate81-87 | 5 / 7.2 [4.0 to 9.0] | 7 / 75.4 [14.0 to 162.0] | 7 / 17.7 [12.0 to 26.0] | 3 / 12.3 [4.0 to 24.7] | 3 / 8.7 [4.5 to 11.4]
Divalproex69,73,96 | 1 / 6.0 | 1 / 305.0 | 1 / 12.0 | 1 / 5.5 | 1 / 3.9
Valproate88 | 0 | 1 / 120.0 | 1 / 12.0 | 0 | 0
Propranolol77-80 | 2 / 4.0 [4.0 to 4.0] | 4 / 45.3 [32.0 to 63.0] | 4 / 27.8 [24.0 to 35.0] | 2 / 4.4 [3.3 to 5.5] | 2 / 4.2 [3.3 to 5.1]
Metoprolol75 | 1 / 4.0 | 1 / 43.0 | 1 / 32.0 | 0 | 0
Trazodone70 | 1 / 4.0 | 1 / 40.0 | 1 / 28.0 | 0 | 0
Nimodipine76 | 0 | 1 / 37.0 | 1 / 28.0 | 0 | 0
Clonidine71,72 | 0 | 2 / 54.0 [51.0 to 57.0] | 2 / 16.0 [8.0 to 24.0] | 1 / 9.8 | 1 / 9.8
Magnesium74 | 1 / 4.0 | 1 / 118.0 | 1 / 16.0 | 0 | 0
Drug management89 | 0 | 1 / 68.0 | 1 / 6.0 | 0
Total | 11 / 5.5 [4.0 to 9.0] | 20 / 75.73 [14.0 to 305.0] | 20 / 19.9 [6.0 to 35.0] | 7 / 8.7 [3.3 to 24.7] | 7 / 6.5 [3.3 to 11.4]

RCT = randomized controlled trials

* include multiple publications of RCTs.

## Risk of Bias

Of all included trials, we concluded low risk of bias in nine RCTs, medium risk of bias in six RCTs, and unclear risk of bias in five RCTs (Table 6). Most trials were double blind (Appendix Table D4); however, randomization was adequate in just 12 trials. Trials lasted an average of 20 weeks after a run-in period of 5.5 weeks (Appendix Table D1). We concluded high risk of bias in nonrandomized studies that did not address selection bias in study design and analyses.

Table 6 Risk of bias in randomized controlled clinical trials that examined migraine prevention in children

Drugs References for RCTs^*^ | Masking of the Treatment Status | Allocation Concealment | Adequacy of Randomization | Planned Intention To Treat Analysis | Risk of Bias | Total
Topiramate81-87 | Double blind: 6 Open label: 1 | Adequate: 2 Not adequate: 1 Unclear: 4 | Adequate: 4 Not adequate: 3 Unclear: 0 | Yes: 5 No: 0 Unclear: 2 | Low: 4 Medium: 2 Unclear: 1 | 7
Divalproex69,73,96 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 1 Not adequate: 0 Unclear: 0 | Yes: 1 No: 0 Unclear: 0 | Low: 1 Medium: 0 Unclear: 0 | 1
Valproate88 | Double blind: 0 Open label: 1 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 1 Not adequate: 0 Unclear: 0 | Yes: 0 No: 1 Unclear: 0 | Low: 0 Medium: 0 Unclear: 1 | 1
Propranolol77-80 | Double blind: 3 Open label: 1 | Adequate: 0 Not adequate: 0 Unclear: 4 | Adequate: 2 Not adequate: 1 Unclear: 1 | Yes: 0 No: 1 Unclear: 3 | Low: 1 Medium: 2 Unclear: 1 | 4
Metoprolol75 | Double blind: 0 Open label: 1 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 0 Not adequate: 1 Unclear: 0 | Yes: 0 No: 0 Unclear: 1 | Low: 0 Medium: 0 Unclear: 1 | 1
Trazodone70 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 0 Not adequate: 0 Unclear: 1 | Yes: 0 No: 0 Unclear: 1 | Low: 1 Medium: 0 Unclear: 0 | 1
Nimodipine76 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 1 Not adequate: 0 Unclear: 0 | Yes: 0 No: 0 Unclear: 1 | Low: 1 Medium: 0 Unclear: 0 | 1
Clonidine71,72 | Double blind: 2 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 2 | Adequate: 1 Not adequate: 0 Unclear: 1 | Yes: 0 No: 1 Unclear: 1 | Low: 1 Medium: 1 Unclear: 0 | 2
Magnesium74 | Double blind: 1 Open label: 0 | Adequate: 1 Not adequate: 0 Unclear: 0 | Adequate: 0 Not adequate: 1 Unclear: 0 | Yes: 1 No: 0 Unclear: 0 | Low: 0 Medium: 1 Unclear: 0 | 1
Drug management89 | Double blind: 0 Open label: 1 | Adequate: 1 Not adequate: 0 Unclear: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Yes: 1 No: 0 Unclear: 0 | Low: 0 Medium: 0 Unclear: 1 | 1
Total | Double blind: 15 Open label: 5 | Adequate: 4 Not adequate: 1 Unclear: 15 | Adequate: 10 Not adequate: 6 Unclear: 4 | Yes: 8 No: 2 Unclear: 10 | Low: 9 Medium: 6 Unclear: 5 | 20

RCT = randomized controlled trial

* Include multiple publications of RCTs.

Risk of bias differed depending on where the study was published. Some journals published RCTs with poorly reported trial design and conduct (Appendix Table D5). Most RCTs were published in the journal Headache; only half percent of all published RCTs in this journal had low risk of bias.

Risk of bias was associated with funding of the trials (Appendix Table D5). Industry-funded RCTs had lower risk of bias than trials funded by grants, combined, or other sources.

Trials enrolled in average 76 children (ranging from 14 to 305) and aimed to examine prevention of episodic migraine and adverse effects. Trials rarely reported statistical power to detect statistically significant differences in outcomes.

## Key Question 1 What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in children?

### Key Question 1a How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to placebo or no active treatment?

Efficacy RCTs examined migraine prevention with drugs versus placebo (Appendix Table D6).70-88

Half of the RCTs did not report ethical approval by institutional review boards or consent of the participants (Appendix Table D7). Most RCTs used a double-blind design (Appendix Table D8). Eligible trials defined clinically important migraine prevention as a complete cessation of migraine attacks and a reduction in monthly migraine frequency by ≥50 or 75 percent.

#### Off-Label Pharmacologic Agents

Table 7 summarizes the effectiveness of off-label pharmacologic agents for patient-centered outcomes. Here we present the effects of the drugs for both patient-centered and intermediate outcomes.

Table 7 Effects of preventive pharmacologic treatments on reduction in monthly migraine attacks

Outcome | Active | Control | RCTs Reference | Children | Rate Active, % | Rate Control, % | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence (Reason for Lowering)
Complete cessation of headache attacks | Propranolol * | Placebo | 1 79 | 28 | 84.6 | 13.0 | 6.3 (1.7 to 23.5) | 0.71 (0.45 to 0.97) | 1 (1 to 2) | 713 (452 to 974) | Low (imprecision in relative risk)
Complete cessation of headache attacks | Clonidine | Placebo | 1^71^ | 57 | 10.7 | 24.1 | 0.4 (0.1 to 1.5) | -0.13 (-0.33 to 0.06) | NS | NS | Low (imprecision)
Complete cessation of headache attacks | Sodium valproate | Propranolol | 2^78,88^ | 183 | 17.1 | 15.4 | 1.2 (0.6 to 2.2) | 0.02 (-0.09 to 0.12) | NS | NS | Low (medium risk of bias, imprecision)
Reduction by ≥50% in migraine attack frequency | Topiramate | Placebo | 2^81,86^ | 298 | 58.2 | 45.7 | 1.3 (0.9 to 1.8) | 0.15 (-0.06 to 0.37) | NS | NS | Moderate (medium risk of bias)
Reduction by ≥50% in migraine attack frequency | Divalproex sodium | Placebo | 1^73^ | 305 | 49.0 | 45.0 | 1.1 (0.8 to 1.5) | 0.04 (-0.12 to 0.20) | NS | NS | Low (imprecision)
Reduction by ≥75% in migraine attack frequency | Propranolol | Placebo | 1^79^ | 28 | 7.7 | 0.0 | 3.4 (0.2 to 77.6) | 0.08 (-0.11 to 0.26) | NS | NS | Low (imprecision)
1-2 migraine frequency/month | Clonidine | Placebo | 1^71^ | 57 | 32.1 | 27.6 | 1.2 (0.5 to 2.6) | 0.05 (-0.19 to 0.28) | NS | NS | Low (imprecision)
Reduction by ≥50% in migraine attack frequency | Sodium valproate | Propranolol | 2^88^ | 183 | 69.5 | 74.3 | 0.9 (0.7 to 1.2) | -0.07 (-0.30 to 0.15) | NS | NS | Low (medium risk of bias, imprecision)
Reduction by ≥50% in the headache index^**^ | Metoprolol * | Progressive relaxation training + stress management | 1 75 | 28 | 38.5 | 80.0 | 0.5 (0.2 to 1.0) | -0.42 (-0.75 to -0.08) | -2 (-12 to -1) | -415 (-748 to -82) | Low (unclear risk of bias, imprecision)
Reduction by ≥50% in the headache index^**^ | Metoprolol | Cephalic vasomotor feedback + stress management | 1^75^ | 28 | 38.5 | 53.3 | 0.7 (0.3 to 1.7) | -0.15 (-0.51 to 0.22) | NS | NS | Low (unclear risk of bias, imprecision)
Reduction for need for temporary drug therapy for single attacks | Clonidine | Placebo | 1^71^ | 57 | 50.0 | 34.5 | 1.5 (0.8 to 2.7) | 0.16 (-0.10 to 0.41) | NS | NS | Low (imprecision)
Improvement in Pediatric Migraine Disability Assessment Score | Topiramate | Sodium valproate | 1^85^ | 48 | NA | NA | Mean difference -0.9 (-5.6 to 3.8) | | NS | NS | Low (unclear risk of bias, imprecision)

CI = confidence interval; NA = not applicable; NS = not significant (number needed to treat and number of attributable events were calculated for statistically significant differences); RCT = randomized controlled trial

* Bold = significant differences at 95% confidence level when 95% CI of attributable events does not include 0.

** Intensity of headache episodes.

##### Antiepileptic Drugs

###### Topiramate

Topiramate, 50 to 200 mg/day, was no more effective than placebo in reducing monthly migraine attacks by ≥50 percent (two RCTs of 298 children, moderate-strength evidence) (Appendix Tables D9 and D10).81,86 Topiramate, 100 mg/day, increased the likelihood of ≥50 percent reduction in migraine attacks in one of two RCTs that examined this association.86 Topiramate increased the likelihood of ≥75 percent reduction in migraine days more often than placebo in a single double-blind RCT (Appendix Table D11).81

Using this statistically significant risk difference, we estimated that 181 children per 1,000 treated (95% CI, 52 to 311) would experience ≥75 percent reduction in migraine days due to topiramate, 200 mg/day.81 Absolute reduction in migraine days with topiramate, 50 to 200 mg/day, was not better than with placebo in a pooled analysis of two double-blind RCTs (Appendix Table D12).

###### Divalproex

Divalproex sodium, 250 to 1,000 mg/day, was no more effective than placebo in reducing monthly migraine by ≥50 percent in one low-risk-of-bias RCT (305 children, low-strength evidence) (Appendix Table D13).69,73

Divalproex sodium in doses of 250, 500, or 1,000 mg/day was not better than placebo in reducing the number of migraine attacks, decreasing migraine days, or decreasing acute drug use (Appendix Tables D14-D16).69,73

##### Beta Blockers

Propranolol resulted in a complete cessation of migraine attacks more often than placebo (one RCT of 28 children, low-strength evidence) (Appendix Table D17).79

Two small RCTs examined the efficacy of propranolol. One small double-blind low-risk-of-bias RCT demonstrated that children experienced a complete cessation of migraine attacks more often with propranolol than with placebo (Appendix Table D18).79 We estimated that 713 children per 1,000 treated would experience complete cessation of migraine with propranolol.79 The same study separately examined reduction of migraine attacks by 50 percent and found no difference between propranolol and placebo.

In a second small crossover RCT, propranolol failed to show a significant reduction in migraine days compared with placebo (Appendix Table D19).77

##### Antidepressants

Compared with placebo, trazodone more effectively reduced the frequency and duration of migraine attacks by 1.6 per month and reduced duration of migraine attacks by 8.2 hours per attack (one RCT of 40 children, low-strength evidence).70 A single small double-blind crossover RCT examined the efficacy of trazodone versus placebo (Appendix Table D20).70 No studies examined reducing monthly migraine attacks by ≥50 percent or other patient-centered outcomes.

##### Calcium Channel Antagonists

Nimodipine was better than placebo in decreasing the number of migraine days (one RCT of 37 children, low-strength evidence). Nimodipine decreased the number of migraine days (mean difference 0.9, 95% CI, 0.5 to 1.3) (Appendix Table D21) but not the duration of migraine attacks.76 No studies examined reducing monthly migraine attacks by ≥50 percent or other patient-centered outcomes.

##### Antiadrenergic Drugs

Clonidine was no more effective than placebo in reducing migraine duration or severity or reducing the use of drugs for acute treatment (one RCT of 57 children, low-strength evidence) (Appendix Table D22). The efficacy of the anti-adrenergic drug clonidine was examined in one small double-blind low-risk-of-bias RCT (Appendix Table D23).71

##### Magnesium Oxide

A single RCT demonstrated no significant differences with magnesium oxide and placebo in migraine frequency.74 Magnesium oxide reduced severity of migraine attacks compared with placebo.74 No studies examined reducing monthly migraine attacks by ≥50 percent or other patient-centered outcomes.

### Key Question 1b How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to active pharmacologic treatments?

Limited evidence from individual RCTs suggested no differences in migraine prevention with examined drugs including propranolol, valproate, and topiramate.

Three RCTs examined comparative effectiveness of drugs for migraine prevention in children (Appendix Tables D24 and D25).78,85,88 The trials had medium78 or unclear risk of bias85,88 (Appendix Table D26).

Two RCTs examined the comparative effectiveness of sodium valproate versus propranolol; the drugs did not differ significantly for achieving complete cessation of headache attacks or reduction by ≥50 percent from baseline frequency of migraine attacks (low-strength evidence) (Appendix Table D27).78,88 Sodium valproate, 15 to 30 mg/kg/day, was more effective than propranolol, 2 to 3 mg/kg/day, in reducing baseline headache frequency by >70 percent in a single RCT (Appendix Table D28).78 The drugs did not differ in effects for reducing migraine severity or use of acute drugs for migraine attacks.

One RCT of 48 children examined the comparative effectiveness of topiramate versus sodium valproate (low-strength evidence). The two drugs did not differ in their effects on migraine frequency, intensity, duration, or Pediatric Migraine Disability Assessment Score (Appendix Table D29).85

### Key Question 1c How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to active nonpharmacologic treatments?

Limited evidence from individual RCTs suggested that the beta blockers propranolol and metoprolol were less effective than certain nonpharmacologic treatments, such as self-administered stress management and relaxation techniques, for preventing migraine in children. Two small RCTs compared drugs with active nonpharmacologic treatments (Appendix Tables D30 and D31).75,77 We concluded unclear risk of bias in both trials because the authors provided insufficient details about methodology (Appendix Table D32).

One RCT examined comparative effectiveness of metoprolol versus a combined treatment involving stress management and either progressive relaxation training or stress management training that used specific relaxation exercises in response to usual migraine triggers such as an intrusively noisy radio program or specific tasks demanding cognitive effort. Stress management training also included objective measurements of changes in brain blood volume taken via photoplethysmograph. This RCT found no significant differences in the percentage of children who improved by ≥50 percent in the headache index (low-strength evidence) (Appendix Table D33).75 In fact, metoprolol tended to be less effective in preventing migraine or reducing migraine severity than stress management combined with either progressive relaxation training or cephalic vasomotor feedback (Appendix Table D34).75 The differences, however, did not achieve statistical significance.

One RCT (low-strength evidence) examined the comparative effectiveness of propranolol versus nonpharmacologic treatment (Appendix Table D35).77 The trial found more frequent migraine with the drug than with self-hypnosis (mean difference of nine monthly migraine attacks, 95% CI, 4 to 14) (Appendix Table D35).77

### Key Question 1d How do preventive pharmacologic treatments combined with nondrug treatments affect patient-centered and intermediate outcomes when compared to pharmacologic treatments alone?

No studies compared combined pharmacologic and nondrug preventive treatments with monodrug therapy in children.

### Key Question 1e1 How might dosing regimens or duration of treatments influence the effects of the treatments on patient-centered outcomes?

Four RCTs published in five articles69,73,84,86,87 and one pooled analysis of three RCTs82 examined the dose-response effects of preventive antiepileptic drugs in children (Appendix Tables D36 and D37). All RCTs were double blind with low risk of bias (Appendix Table D38).

#### Topiramate

The evidence did not support a dose-response association between increased doses of topiramate and reduction in migraine frequency or disability. A higher dose of topiramate compared to a lower dose (100 versus 25 mg) demonstrated no consistent significant difference in migraine prevention (Appendix Table D39).84,86

Higher doses of topiramate resulted in no greater reduction in disability score or migraine duration (Appendix Table D40).84,86

#### Divalproex Sodium

Higher doses of divalproex sodium (500 to 1,000 versus 250 mg/day) resulted in no significantly better migraine prevention in a single RCT that examined this association (Appendix Table D41). Higher doses of divalproex sodium resulted in no greater reduction in migraine days or acute drug use (Appendix Table D42).69,73

### Key Question 1e2 How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

Multidisciplinary migraine drug management, including cognitive-behavioral training, was more effective than a combination of usual care and education in preventing migraine in children and adolescents (one RCT of 68 children, low-strength evidence).89

A single RCT of 68 children and adolescents 10 to 18 years old examined internet-based multimodal drug management, including cognitive-behavioral training (CBT) or applied relaxation, compared to usual care (Appendix Table D43).89

The multimodal CBT intervention focused on stress management (perception of own stress symptoms, coping with stress), progressive relaxation techniques, cognitive restructuring (identification of dysfunctional cognitions regarding headache and self-assurance strategies such as being proactive and sensitive to one's own needs), and problem solving. The participants communicated through email with a multidisciplinary team of trial coordinators.89 The applied relaxation included progressive relaxation, cue-controlled (triggered by key word or an image) relaxation, and differential relaxation.89 Multimodal CBT was more effective than education in reducing migraine frequency by ≥50 percent (relative risk 4.0, 95% CI 1.0 to 16.0) (Appendix Table D44).89 We estimated that 310 children per 1,000 treated with multimodal CBT would experience ≥50 percent reduction in migraine frequency (95% CI, 70 to 550). The effect, however, was not sustained at 6 months of followup.89 Migraine frequency (Appendix Table D45) and quality of life did not differ with internet-based self-management versus an education program (Appendix Table D46).89

## Key Question 2 What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults and children?

### Key Question 2a What are the harms from preventive pharmacologic treatments when compared to placebo or no active treatment?

Divalproex sodium resulted in treatment discontinuation due to adverse effects (Table 8). Topiramate significantly increased risk of weight loss, paresthesia, and upper respiratory tract infection.

Table 8 Evidence of treatment discontinuation due to adverse effects with migraine preventive drugs versus placebo in children

Drug | RCTs Reference | Children | Conclusion | Strength of evidence
Divalproex sodium, 1,000 mg | 1^69,73^ | 148 | Divalproex sodium 1,000 mg resulted in greater treatment discontinuation rates vs. placebo | Low (imprecision)
Topiramate, 50-200 mg | 2^81,86,87^ | 298 | Topiramate 50-200 mg, did not result in greater treatment discontinuation rates vs. placebo | Low (imprecision, medium risk of bias)
Clonidine | 1^71^ | 57 | Clonidine 25-50 μg did not result in greater rates of treatment discontinuation vs. placebo; the data is sparse | Insufficient
Magnesium | 1^74^ | 118 | Magnesium did not result in greater rates of treatment discontinuation vs. placebo | Low (medium risk of bias, imprecision)

Ten publications of randomized trials and one pooled analysis of three RCTs82 examined the safety of drugs for migraine prevention in children (Appendix Table D47).70-74,80-82,86,87 The trials included 1,046 children 12.6 years old with in average 10 monthly migraine attacks (Table 9). Half of the enrolled subjects were girls.

Table 9 Subject characteristics in randomized controlled clinical trials that examined harms with interventions for migraine prevention in children

Drugs References for RCTs^*^ | Age # RCTs / Mean [Min to Max] | % Females # RCTs / Mean [Min to Max] | Baseline Frequency of Migraine/Month # RCTs / Mean [Min to Max] | Duration of Migraine, Years # RCTs / Mean [Min to Max] | Obesity, BMI # RCTs / Mean [Min to Max] | Family History of Migraine, % # RCTs / Mean [Min to Max]
Topiramate81,82,86,87 | 4 / 13.4 [11.1 to 14.2] | 4 / 60.4 [48.4 to 71.0] | 2 / 4.7 [4.1 to 5.2] | 0 | 2 / 23.3 [21.7 to 24.9] | 0
Divalproex69,73,96 | 1 / 14.2 | 1 / 55.0 | 1 / 17.2 | 0 | 1 / 23.2 | 0
Propranolol80 | 0 | 1 / 46.2 | 1 / 14.0 | 0 | 0 | 1 / 13.0
Trazodone70 | 1 / 12.6 | 1 / 45.0 | 1 / 3.8 | 1 / 4.5 | 0 | 1 / 67.5
Clonidine71,72 | 1 / 11.0 | 2 / 41.4 [38.6 to 44.2] | 1 / 3.5] | 0 | 0 | 1 / 90.7
Magnesium74 | 1 / 12.0 | 1 / 68.6 | 1 / 10.5 | 1 / 3.5 | 0 | 0
Total | 8 / 12.6 [11.0 to 14.2] | 10 / 49.9 [38.6 to 71.0] | 7 / 10.1 [3.5 to 17.2] | 2 / 4.0 [3.5 to 4.5] | 3 / 23.3 [21.7 to 24.9] | 3 / 57.1 [13.0 to 67.5]

BMI = body mass index; RCT = randomized controlled trial

* Includes multiple publications of RCTs.

All RCTs were double blind (Table 10). Based on all risk of bias criteria, we concluded that six RCTs had low risk of bias and four RCTs had medium risk of bias.74,80,81 Trials followed children for 19 weeks to assess harms (Table 11). Means of attrition rates were 10 percent with active treatments and 7 percent with control treatments.

Table 10 Risk of bias in randomized controlled clinical trials that examined harms with interventions for migraine prevention in children

Drugs References for RCTs^*^ | Masking of the Treatment Status | Allocation Concealment | Adequacy of Randomization | Planned Intention To Treat Analysis | Risk of Bias | Total
Topiramate81,82,86,87 | Double blind: 4 Open label: 0 | Adequate: 2 Not adequate: 0 Unclear: 2 | Adequate: 2 Not adequate: 2 Unclear: 0 | Yes: 4 No: ITT: 0 Unclear: 0 | Low: 3 Medium: 1 Unclear: 0 | 4
Divalproex69,73,96 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 1 Not adequate: 0 Unclear: 0 | Yes: 1 No: ITT: 0 Unclear: 0 | Low: 1 Medium: 0 Unclear: 0 | 1
Propranolol80 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 0 Not adequate: 1 Unclear: 0 | Yes: 0 No: ITT: 0 Unclear: 1 | Low: 0 Medium: 1 Unclear: 0 | 1
Trazodone70 | Double blind: 1 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 1 | Adequate: 0 Not adequate: 0 Unclear: 1 | Yes: 0 No: ITT: 0 Unclear: 1 | Low: 1 Medium: 0 Unclear: 0 | 1
Clonidine71,72 | Double blind: 2 Open label: 0 | Adequate: 0 Not adequate: 0 Unclear: 2 | Adequate: 1 Not adequate: 0 Unclear: 1 | Yes: 0 No: ITT: 1 Unclear: 1 | Low: 1 Medium: 1 Unclear: 0 | 2
Magnesium74 | Double blind: 1 Open label: 0 | Adequate: 1 Not adequate: 0 Unclear: 0 | Adequate: 0 Not adequate: 1 Unclear: 0 | Yes: 1 No: ITT: 0 Unclear: 0 | Low: 0 Medium: 1 Unclear: 0 | 1
Total | Double blind: 10 Open label: 0 | Adequate: 3 Not adequate: 0 Unclear: 7 | Adequate: 4 Not adequate: 4 Unclear: 2 | Yes: 6 No: ITT: 1 Unclear: 3 | Low: 6 Medium: 4 Unclear: 0 | 10

ITT = intention to treat; RCT = randomized controlled trial

* Includes multiple publications of RCTs.

Table 11 Sample, duration, length of followup, and attrition in randomized controlled clinical trials that examined harms with interventions for migraine prevention in children

Drugs References for RCTs^*^ | Duration of Run-In Period, Weeks # RCTs / Mean [Min to Max] | Total Sample Assigned to Treatment # RCTs / Mean [Min to Max] | Total Length of Followup, Weeks # RCTs / Mean [Min to Max] | Loss of Followup Control Group, % # RCTs / Mean [Min to Max] | Loss of Followup in Active Group, % # RCTs / Mean [Min to Max]
Topiramate81,82,86,87 | 4 / 8.0 [6.0 to 9.0] | 4 / 105.5 [51.0 to 162.0] | 4 / 21.0 [16.0 to 26.0] | 3 / 12.3 [4.0 to 24.7] | 3 / 8.7 [4.5 to 11.4]
Divalproex69,73,96 | 1 / 6.0 | 1 / 305.0 | 1 / 12.0 | 1 / 5.5 | 1 / 3.9
Propranolol80 | 1 / 4.0 | 1 / 53.0 | 1 / 26.0 | 1 / 3.3 | 1 / 3.3
Trazodone70 | 1 / 4.0 | 1 / 40.0 | 1 / 28.0 | 0 | 0
Clonidine71,72 | 0 | 2 / 54.0 [51.0 to 57.0] | 2 / 16.0 [8.0 to 24.0] | 1 / 9.8 | 1 / 9.8
Magnesium74 | 1 / 4.0 | 1 / 118.0 | 1 / 16.0 | 0 | 0
Total | 8 / 6.3 [4.0 to 9.0] | 10 / 103.9 [40.0 to 305.0] | 10 / 18.8 [8.0 to 28.0] | 6 / 9.5 [3.3 to 24.7] | 6 6.6 [3.3 to 11.4]

RCT = randomized controlled trial

* Includes multiple publications of RCTs.

Sixteen nonrandomized studies reported harms with migraine preventive drugs in children (Appendix Table D48).

#### Adverse Effects of Antiepileptic Drugs

##### Topiramate

Treatment discontinuation due to adverse effects was not greater with topiramate than placebo in a pooled analysis of two RCTs (low-strength evidence) (Table 12, Appendix Tables D49 and D50).81,82,86,87Nonrandomized studies suggested that 19 percent of children discontinued topiramate treatments due to bothersome adverse effects.90

Table 12 Treatment discontinuation due to adverse effects with migraine preventive drugs versus placebo in children

Drug | RCTs References^*^ | Children | Rate With Drug, % | Rate With Placebo, % | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence (Reason for Lowering)
Divalproex sodium, 1,000 mg ** | 1^69,73^ | 148 | 9.3 | 1.4 | 6.8 (0.9 to 54) | 0.08 (0.01 to 0.16) | 13 (7 to 111) | 80 (9 to 151) | Low (imprecision)
Topiramate, 50-100 mg | 2^81,86,87^ | 298 | 7 | 3.5 | 2.1 (0.7 to 6.3) | 0.04 (-0.02 to 0.1) | NS | NS | Low (imprecision, medium risk of bias)
Clonidine | 1^71^ | 57 | 3.5 | 0 | 3.1 (0.1 to 73.1) | 0.04 (-0.06 to 0.13) | NS | NS | Insufficient
Magnesium | 1^74^ | 118 | 5.2 | 1.7 | 3.1 (0.3 to 29.0) | 0.04 (-0.03 to 0.10) | NS | NS | Low (medium risk of bias, imprecision)

CI = confidence interval; NS = not significant (number needed to treat and number of attributable events were calculated for statistically significant differences)

* Includes multiple publications of RCTs.

** Bold = significant differences at 95% confidence level when 95% CI of absolute risk difference do not include 0. The entire line is bold.

A single RCT reported that 260 children per 1,000 treated with topiramate (95% CI, 30 to 480) experienced adverse effects (Appendix Table D51).86 Our pooled analysis of individual adverse effects (Appendix Table D52) demonstrated a significant increase in risk of weight loss, paresthesia, and upper respiratory tract infection with topiramate. We estimated that of 1,000 treated with topiramate, 87 experienced unintended weight loss (95% CI, 24 to 150), and 105 were diagnosed with upper respiratory tract infection (95% CI, 29 to 182) (Table 13).81,82,86

Table 13 Adverse effects with antiepileptic drugs for migraine prevention in children

Adverse Effect | Drug | References for RCTs^*^ | Children in Analyses | Rate With Drug, % | Rate With Placebo, % | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat To Harm (95% CI) | Attributable Events per 1,000 Treated (95% CI)
Any adverse event ** | Divalproex sodium | 1^73,97^ | 305 | 66.6 | 57.8 | 1.2 (1.0 to 1.3) | 0.09 (0.01 to 0.18) | 11 (5 to 200) | 94 (5 to 183)
Abdominal pain | Topiramate | 3^81,82,86^ | 373 | 10.4 | 9.9 | 1.0 (0.6 to 1.9) | 0.00 (-0.06 to 0.06) | NS | NS
Anorexia | Topiramate | 3^81,82,86,87^ | 373 | 11.8 | 5.9 | 1.8 (0.9 to 3.8) | 0.05 (0.00 to 0.11) | NS | NS
Dizziness | Topiramate | 2^82,86,87^ | 531 | 4.6 | 5.9 | 0.7 (0.1 to 3.7) | -0.03 (-0.14 to 0.08) | NS | NS
Fatigue | Topiramate | 3^81,82,86,87^ | 373 | 6.8 | 8.6 | 0.8 (0.4 to 1.6) | -0.02 (-0.08 to 0.04) | NS | NS
Injury | Topiramate | 3^81,82,86^ | 373 | 8.1 | 8.6 | 0.9 (0.5 to 1.8) | 0.00 (-0.06 to 0.06) | NS | NS
Nausea | Topiramate | 2^81,86^ | 298 | 6.0 | 6.0 | 1.0 (0.4 to 2.6) | 0.00 (-0.06 to 0.06) | NS | NS
Paresthesia ** | Topiramate | 3^81,82,86^ | 373 | 14.5 | 5.3 | 2.6 (1.2 to 5.6) | 0.09 (0.05 to 0.14) | 11 (7 to 22) | 92 (45 to 140)
Sinusitis | Topiramate | 3^81,82,86^ | 373 | 8.1 | 5.3 | 1.2 (0.5 to 2.5) | 0.02 (-0.03 to 0.07) | NS | NS
Somnolence | Topiramate | 3^81,82,86,87^ | 305 | 8.1 | 5.0 | 1.4 (0.6 to 3.6) | 0.03 (-0.02 to 0.09) | NS | NS
Treatment discontinuation | Topiramate | 3^81,82,86,87^ | 490 | 19.6 | 25.8 | 0.8 (0.5 to 1.2) | -0.03 (-0.11 to 0.05) | NS | NS
Upper respiratory tract infection ** | Topiramate | 3^81,82,86^ | 373 | 21.7 | 11.2 | 1.8 (1.1 to 3.1) | 0.11 (0.03 to 0.18) | 10 (5 to 34) | 105 (29 to 182)
Weight decrease ** | Topiramate | 3^81,82,86^ | 373 | 20.8 | 12.5 | 2.0 (1.2 to 3.2) | 0.09 (0.02 to 0.15) | 11 (7 to 42) | 87 (24 to 150)

CI = confidence interval; NS = not significant (number needed to treat and number of attributable events were calculated for statistically significant differences); RCT = randomized controlled trial

* Includes multiple publications which contributed to meta-analyses only once.

** Bold = significant differences at 95% confidence level when 95% CI of absolute risk difference do not include 0.

Rates of the adverse effects did not differ between 50, 100, and 200 mg topiramate per day (Appendix Table D53). The results remain statistically nonsignificant from different statistical models (relative risk, absolute risk difference, arcsine transformed risk difference).

A single case report described development of the “Alice in Wonderland syndrome”91 in which the treated girl described a distortion in her body image and a perception of disproportional body, arms, and head size. This event was associated with a dose of 75 mg/day of topiramate, but not with lower doses of the drug (Appendix Table D48).91

##### Divalproex Sodium

Treatment discontinuation due to adverse effects with divalproex sodium compared to placebo was greater with 1,000 mg/day but not with 250 mg/day in one RCTs (low-strength evidence) (Table 12).69,73

Treatment discontinuation due to treatment failure did not differ between divalproex sodium and placebo (Appendix Table D54).73 A single RCT demonstrated that 80 children per 1,000 treated with divalproex sodium, 1,000 mg/day, would stop taking the drug due to intolerable adverse effects (95% CI, 9 to 151)69,73 (Appendix Table D55).69,73

Nonrandomized studies suggested that 84 percent of children experienced adverse effects with divalproex,92 and 17 percent discontinued treatment due to bothersome adverse effects.93

A single RCT examined risk of individual adverse effects and found no significant differences with divalproex versus placebo (Appendix Table D56).73 This double-blind trial had low risk of bias but lacked power to detect significant differences in rare adverse events with the drug versus placebo (sparse data).73 Upper respiratory tract infections were more common with larger doses of divalproex (Appendix Table D57).73 The results differed depending on the statistical model used. Viral infections were more common with larger doses of divalproex in the models that obtained arcsine transformed risk difference (Appendix Table D57).73

#### Adverse Effects With Beta Blockers

A single RCT offered low-strength evidence that risk of any adverse effects did not differ between propranolol and placebo (Appendix Table D58).80

#### Adverse Effects With Antidepressants

A single low-risk-of-bias RCT offered low-strength evidence that treatment discontinuation for any reason did not differ between the antidepressant trazodone and placebo in 40 children with migraine (Appendix Table D59).70 One retrospective chart review demonstrated that of 14 patients taking amitriptyline, 36 percent discontinued it at 16 weeks because of side effects.94

#### Adverse Effects With Antiadrenergic Drugs

Two RCTs reported treatment discontinuation due to adverse effects. One RCT demonstrated that risk of treatment discontinuation due to adverse effects did not differ between the anti-adrenergic drug clonidine and placebo (Table 12).71 This double-blind RCT demonstrated that clonidine significantly increased risk of fatigue (Appendix Table D60).71 We estimated that 220 children of 1,000 treated became fatigued (95% CI, 30 to 410) with clonidine.71 Other adverse effects, including drowsiness or difficulty in reading, did not differ between clonidine and placebo.72 A second small RCT failed to demonstrate any statistically significant increase in risk of adverse effects.72

#### Adverse Effects With Magnesium Oxide

A single RCT demonstrated no difference between magnesium oxide and placebo for risk of treatment discontinuation or for treatment discontinuation due to treatment failure or adverse effects (Appendix Table D61).74

#### Adverse Effects With Onabotulinumtoxin A

One small nonrandomized study demonstrated that 8 percent of adolescents treated with onabotulinumtoxin A 100U every 3 months experienced blurred vision and ptosis, and burning sensations at all injection sites95 (Appendix Table D48).

### Key Question 2b What are the harms from preventive pharmacologic treatments when compared to active pharmacologic treatments?

#### Comparative Safety of Topiramate Versus Sodium Valproate

A single RCT (low-strength evidence) found no differences in any adverse effects with topiramate and sodium valproate administered for 12 weeks in 48 children with migraine (Appendix Table D62).85

### Key Question 2c How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

We found no studies that examined how drug management can improve safety of migraine preventive medications in children.

## Key Question 3 Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in children and adults?

We found no studies that examined how specific characteristics of children could affect the effectiveness or safety of migraine preventive medications.