# References

1 Diamond S, Bigal ME, Silberstein S, et al. Patterns of diagnosis and acute and preventive treatment for migraine in the United States: results from the American Migraine Prevalence and Prevention study. Headache. Mar. 2007;47(3):355-63. [pmid: 17371352].
2 Lipton RB, Scher AI, Kolodner K, et al. Migraine in the United States: epidemiology and patterns of health care use. Neurology. Mar. 26. 2002;58(6):885-94. [pmid: 11914403].
3 Bigal ME, Lipton RB, Winner P, et al. Migraine in adolescents: association with socioeconomic status and family history. Neurology. Jul. 3. 2007;69(1):16-25. [pmid: 17606878].
4 Hernandez-Latorre MA, Roig M. Natural history of migraine in childhood. Cephalalgia. Jul. 2000;20(6):573-9. [pmid: 11075841].
5 Lewis DW. Pediatric migraine. Neurol Clin. May. 2009;27(2):481-501. [pmid: 19289227].
6 Goadsby PJ, Raskin NH. Chapter 15 Headache. Fauci AS, Braunwald E, Kasper DL, Hauser SL, Longo DL, Jameson JL, et al., editors. Harrison's principles of internal medicine. 17th ed. New York. The McGraw-Hill Co mpanies. 2008.
7 Headache Classification Subcommittee of the International Headache Society. The International Classification of Headache Disorders: 2nd edition. Cephalalgia. Suppl 1. 2004;24:9-160. [pmid: 14979299].
8 Silberstein SD. Preventive migraine treatment. Neurol Clin. May. 2009;27(2):429-43. [pmid: 19289224].
9 Lipton RB, Manack A, Ricci JA, et al. Prevalence and burden of chronic migraine in adolescents: results of the chronic daily headache in adolescents study (C-dAS). Headache. May. 2011;51(5):693-706. [pmid: 21521206].
10 Bille B. A 40-year follow-up of school children with migraine. Cephalalgia. Jun. 1997;7(4):488-91. discussion 7. [pmid: 9209767].
11 Guidetti V, Galli F. Evolution of headache in childhood and adolescence: an 8-year follow-up. Cephalalgia. Sep. 1998;18(7):449-54. [pmid: 9793696].
12 Lipton RB, Stewart WF, Diamond S, et al. Prevalence and burden of migraine in the United States: data from the American Migraine Study II. Headache. Jul-Aug. 2001;41(7):646-57. [pmid: 11554952].
13 Damen L, Bruijn JK, Verhagen AP, et al. Symptomatic treatment of migraine in children: a systematic review of medication trials. Pediatrics. Aug. 2005;116(2):e295-302. [pmid: 16061583].
14 Sprenger T, Goadsby PJ. Migraine pathogenesis and state of pharmacological treatment options. BMC Medicine. 2009;7:71. [pmid: 19917094].
15 Sanchez-Del-Rio M, Reuter U, Moskowitz MA. New insights into migraine pathophysiology. Curr Opin Neurol. Jun. 2006;19(3):294-8. [pmid: 16702838].
16 Rapoport AM. Acute and prophylactic treatments for migraine: present and future. Neurol Sci. May. Suppl 1. 2008;29:S110-22. [pmid: 18545911].
17 Stafford RS. Regulating off-label drug use--rethinking the role of the FDA. N Engl J Med. Apr. 3. 2008;358(14):1427-9. [pmid: 18385495].
18 Fraguas D, Merchan-Naranjo J, Laita P, et al. Metabolic and hormonal side effects in children and adolescents treated with second-generation antipsychotics. Journal of Clinical Psychiatry. Jul. 2008;69(7):1166-75. [pmid: 18588363].
19 Correll CU, Carlson HE. Endocrine and metabolic adverse effects of psychotropic medications in children and adolescents. J Am Acad Child Adolesc Psychiatry. Jul. 2006;45(7):771-91. [pmid: 16832314].
20 Pappagallo M, Silva R. The effect of atypical antipsychotic agents on prolactin levels in children and adolescents. J Child Adolesc Psychopharmacol. Fall. 2004;14(3):359-71. [pmid: 15650493].
21 Kumra S, Oberstar JV, Sikich L, et al. Efficacy and tolerability of second-generation antipsychotics in children and adolescents with schizophrenia. Schizophr Bull. Jan. 2008;34(1):60-71. [pmid: 17923452].
22 Dubois D. Toxicology and overdose of atypical antipsychotic medications in children: does newer necessarily mean safer?. Curr Opin Pediatr. Apr. 2005;17(2):227-33. [pmid: 15800418].
23 Silberstein S, Tfelt-Hansen P, Dodick DW, et al. Guidelines for controlled trials of prophylactic treatment of chronic migraine in adults. Cephalalgia. May. 2008;28(5):484-95. [pmid: 18294250].
24 Schroeder BM. AAFP/ACP-ASIM release guidelines on the management and prevention of migraines. Am Fam Physician. Mar. 15. 1392. 2003;67(6):5-7. [pmid: 12674472].
25 Olesen J, Bousser MG, Diener HC, et al. New appendix criteria open for a broader concept of chronic migraine. Cephalalgia. Jun. 2006;26(6):742-6. [pmid: 16686915].
26 Lewis D, Ashwal S, Hershey A, et al. Practice parameter: pharmacological treatment of migraine headache in children and adolescents: report of the American Academy of Neurology Quality Standards Subcommittee and the Practice Committee of the Child Neurology Society. Neurology. Dec. 28. 2004;63(12):2215-24. [pmid: 15623677].
27 Gunner KB, Smith HD, Ferguson LE. Practice guideline for diagnosis and management of migraine headaches in children and adolescents: Part two. J Pediatr Health Care. Jan-Feb. 2008;22(1):52-9. [pmid: 18174091].
28 Geraud G, Lanteri-Minet M, Lucas C, et al. French guidelines for the diagnosis and management of migraine in adults and children. Clin Ther. Aug. 2004;26(8):1305-18. [pmid: 15476911].
29 Evers S, Afra J, Frese A, et al. EFNS guideline on the drug treatment of migraine--revised report of an EFNS task force. Eur J Neurol. Sep. 2009;16(9):968-81. [pmid: 19708964].
30 Dowson AJ, Lipscombe S, Sender J, et al. New guidelines for the management of migraine in primary care. Curr Med Res Opin. 2002;18(7):414-39. [pmid: 12487508].
31 Morey SS. Guidelines on migraine: part 4. General principles of preventive therapy. Am Fam Physician. 2000. Nov. 15. 2000;62(10):2359-60. [pmid: 11126860].
32 Silberstein SD. Practice parameter: evidence-based guidelines for migraine headache (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. Sep. 26. 2000;55(6):754-62. [pmid: 10993991].
33 Schuurmans A, van Weel C. Pharmacologic treatment of migraine. Comparison of guidelines. Can Fam Physician. Jun. 2005;51:838-43. [pmid: 15986940].
34 Solomon S. New appendix criteria open for a broader concept of chronic migraine (Comment on: Cephalagia 2006 Jun:26(6):742-6). Cephalalgia. May. 2007;27(5):469. author reply -70. [pmid: 17448186].
35 U.S. Food and Drug Administration. FDA News Release: FDA Approves Botox to Treat Chronic Migraine. 2010. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm229782.htm. July 25 2012.
36 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
37 Slutsky J, Atkins D, Chang S, et al. AHRQ series paper 1: comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):481-3. [pmid: 18834715].
38 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):484-90. [pmid: 19716268].
39 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Annals of Internal Medicine. Aug. 18. 2009;151(4):W65-94. [pmid: 19622512].
40 White CM, Ip S, McPheeters ML, et al. Chapter 11. Using existing systematic reviews to replace de novo processes in conducting comparative effectiveness reviews. Methods Guide for Effectiveness and Comparative Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Resarch and Quality. March. 2009. 2011:136-51. Available at www.effectivehealthcare.ahrq.gov.
41 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
42 Rothner AD. Complicated migraine and migraine variants. Curr Pain Headache Rep. Jun. 2002;6(3):233-9. [pmid: 12003695].
43 Hansen JM, Thomsen LL, Olesen J, et al. Calcitonin gene-related peptide does not cause the familial hemiplegic migraine phenotype. Neurology. Sep. 9. 2008;71(11):841-7. [pmid: 18779512].
44 Norris S, Atkins D, Bruening W, et al. Chapter 4. Selecting observational studies for comparing medical interventions. Methods Guide for Effectiveness and Comparative Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011:56-68. Available at: www.effectivehealthcare.ahrq.gov.
45 Higgins J, Green S, editors. Cochrane handbook for systematic reviews of interventions. Version 5.1.0. London. The Cochrane Collaboration. 2011.
46 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. Sep. 25. 2008;63(5):502-12. [pmid: 18823754].
47 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
48 Viswanathan M, Berkman ND. Development of the RTI Item Bank on Risk of Bias and Precision of Observational Studies AHRQ Methods for Effective Health Care. 2011. Sep. Studies. Rockville (MD). Agency for Healthcare Research and Quality (US). (Report No.: 11-EHC028-EF). [pmid: 22191112].
49 van der Velde G, van Tulder M, Cote P, et al. The sensitivity of review results to methods used to appraise and incorporate trial quality into data synthesis. Spine (Phila Pa 1976). Apr. 1. 2007;32(7):796-806. [pmid: 17414916].
50 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. Dec. 2006;59(12):1249-56. [pmid: 17098567].
51 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
52 Egger M, Smith GD, Altman DG. Systematic reviews in health care: meta-analysis in context. 2nd ed. London. BMJ Books. 2001.
53 Fu R, Gartlehner G, Grant M, et al. Chapter 9. Conducting quantitative synthesis when comparing medical interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011:104-19. Available at: http://effectivehealthcare.ahrq.gov.
54 Rucker G, Schwarzer G, Carpenter J, et al. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Stat Med. Feb. 28. 2009;28(5):721-38. [pmid: 19072749].
55 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. Jan. 15. 2007;26(1):53-77. [pmid: 16596572].
56 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. May. 15. 2004;23(9):1351-75. [pmid: 15116347].
57 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
58 Friedrich JO, Adhikari NK, Beyene J. Ratio of means for analyzing continuous outcomes in meta-analysis performed as well as mean difference methods. Journal of Clinical Epidemiology. May. 2011;64(5):556-64. [pmid: 21447428].
59 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
60 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. Jan. 15. 2007;26(1):37-52. [pmid: 16463355].
61 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
62 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
63 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
64 Altman DG. Confidence intervals for the number needed to treat. BMJ. Nov. 7. 1998;317(7168):1309-12. [pmid: 9804726].
65 Guyatt G, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence-imprecision. J Clin Epidemiol. 2011. Aug. 10. [pmid: 21839614].
66 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
67 Guyatt GH, Oxman AD, Santesso N, et al. GRADE guidelines 12. Preparing Summary of Findings tables-binary outcomes. J Clin Epidemiol. 2012. May. 18. [pmid: 22609141].
68 Aschengrau A, Seage GR. Essentials of epidemiology in public health. Sudbury, MA. Jones and Bartlett. 2003.
69 U.S. Food and Drug Administration. Clinical Review of Divalproex Sodium. 2008.
70 Battistella PA, Ruffilli R, Cernetti R, et al. A placebo-controlled crossover trial using trazodone in pediatric migraine. Headache. Jan. 1993;33(1):36-9. [pmid: 8436497].
71 Sillanpää M. Clonidine prophylaxis of childhood migraine and other vascular headache. A double blind study of 57 children. Headache. 1977:28-31. [pmid: 321395].
72 Sills M, Congdon P, Forsythe I. Clonidine and childhood migraine: a pilot and double-blind study. Dev Med Child Neurol. Dec. 1982;24(6):837-41. [pmid: 6218003].
73 Apostol G, Cady RK, Laforet GA, et al. Divalproex extended-release in adolescent migraine prophylaxis: results of a randomized, double-blind, placebo-controlled study. Headache. Jul. 2008;48(7):1012-25. [pmid: 18705027].
74 Wang F, Van Den Eeden SK, Ackerson LM, et al. Oral magnesium oxide prophylaxis of frequent migrainous headache in children: a randomized, double-blind, placebo-controlled trial. Headache. Jun. 2003;43(6):601-10. [pmid: 12786918].
75 Sartory G, Muller B, Metsch J, et al. A comparison of psychological and pharmacological treatment of pediatric migraine. Behav Res Ther. Dec. 1998;36(12):1155-70. [pmid: 9745800].
76 Battistella PA, Ruffilli R, Moro R, et al. A placebo-controlled crossover trial of nimodipine in pediatric migraine. Headache. Apr. 1990;30(5):264-8. [pmid: 2191938].
77 Olness K, MacDonald JT, Uden DL. Comparison of self-hypnosis and propranolol in the treatment of juvenile classic migraine. Pediatrics. Apr. 1987;79(4):593-7. [pmid: 3822681].
78 Bidabadi E, Mashouf M. A randomized trial of propranolol versus sodium valproate for the prophylaxis of migraine in pediatric patients. Paediatric Drugs. Aug. 1. 2010;12(4):269-75. [pmid: 20593910].
79 Ludvigsson J. Propranolol used in prophylaxis of migraine in children. Acta neurologica Scandinavica. 1974:109-15. [pmid: 4839065].
80 Forsythe WI, Gillies D, Sills MA. Propanolol ('Inderal') in the treatment of childhood migraine. Developmental medicine and child neurology. 1984:737-41. [pmid: 6519358].
81 Winner P, Pearlman EM, Linder SL, et al. Topiramate for migraine prevention in children: a randomized, double-blind, placebo-controlled trial. Headache. Nov-Dec. 2005;45(10):1304-12. [pmid: 16324162].
82 Winner P, Gendolla A, Stayer C, et al. Topiramate for migraine prevention in adolescents: a pooled analysis of efficacy and safety. Headache. Nov-Dec. 2006;46(10):1503-10. [pmid: 17115983].
83 Lakshmi CV, Singhi P, Malhi P, et al. Topiramate in the prophylaxis of pediatric migraine: a double-blind placebo-controlled trial. J Child Neurol. Jul. 2007;22(7):829-35. [pmid: 17715274].
84 Lewis D, Paradiso E. A double-blind, dose comparison study of topiramate for prophylaxis of basilar-type migraine in children: a pilot study. Headache. Nov-Dec. 2007;47(10):1409-17. [pmid: 18052950].
85 Unalp A, Uran N, Ozturk A. Comparison of the effectiveness of topiramate and sodium valproate in pediatric migraine. J Child Neurol. Dec. 2008;23(12):1377-81. [pmid: 19073842].
86 Lewis D, Winner P, Saper J, et al. Randomized, double-blind, placebo-controlled study to evaluate the efficacy and safety of topiramate for migraine prevention in pediatric subjects 12 to 17 years of age. Pediatrics. Mar. 2009;123(3):924-34. [pmid: 19255022].
87 Pandina GJ, Ness S, Polverejan E, et al. Cognitive effects of topiramate in migraine patients aged 12 through 17 years. Pediatr Neurol. Mar. 2010;42(3):187-95. [pmid: 20159428].
88 Ashrafi MR, Shabanian R, Zamani GR, et al. Sodium Valproate versus Propranolol in paediatric migraine prophylaxis. Eur J Paediatr Neurol. 2005;9(5):333-8. [pmid: 16120482].
89 Trautmann E, Kroner-Herwig B. A randomized controlled trial of Internet-based self-help training for recurrent headache in childhood and adolescence. Behav Res Ther. Jan. 2010;48(1):28-37. [pmid: 19782343].
90 Cruz MJ, Valencia I, Legido A, et al. Efficacy and tolerability of topiramate in pediatric migraine. Pediatric Neurology. Sep. 2009;41(3):167-70. [pmid: 19664530].
91 Jurgens TP, Ihle K, Stork JH, et al. “Alice in Wonderland syndrome” associated with topiramate for migraine prevention. J Neurol Neurosurg Psychiatry. Feb. 2011;82(2):228-9. [pmid: 20571045].
92 Apostol G, Lewis DW, Laforet GA, et al. Divalproex sodium extended-release for the prophylaxis of migraine headache in adolescents: results of a stand-alone, long-term open-label safety study. Headache. Jan. 2009;49(1):45-53. [pmid: 19040679].
93 Pakalnis A, Greenberg G, Drake ME Jr, et al. Pediatric migraine prophylaxis with divalproex. Journal of Child Neurology. Oct. 2001;16(10):731-4. [pmid: 11669346].
94 Sorge F, Barone P, Steardo L. Amitriptyline as a prophylactic for migraine in children. Acta Neurologica. 1982;4(5):362-7. [pmid: 7158453].
95 Chan VW, McCabe EJ, MacGregor DL. Botox treatment for migraine and chronic daily headache in adolescents. Journal of Neuroscience Nursing. Oct. 2009;41(5):235-43. [pmid: 19835236].
96 Apostol G, Pakalnis A, Laforet GA, et al. Safety and tolerability of divalproex sodium extended-release in the prophylaxis of migraine headaches: results of an open-label extension trial in adolescents. Headache. Jan. 2009;49(1):36-44. [pmid: 19040678].
97 Sorge F, De Simone R, Marano E, et al. Flunarizine in prophylaxis of childhood migraine. A double-blind, placebo-controlled, crossover study. Cephalalgia. 1988:1-6. [pmid: 3282670].
98 Victor S, Ryan SW. Drugs for preventing migraine headaches in children. Cochrane Database of Systematic Reviews. 2003;(4):CD002761. [pmid: 14583952].
99 Damen L, Bruijn J, Koes BW, et al. Prophylactic treatment of migraine in children. Part 1. A systematic review of non-pharmacological trials. Cephalalgia. Apr. 2006;26(4):373-83. [pmid: 16556238].
100 Larsson B, Carlsson J, Fichtel A, et al. Relaxation treatment of adolescent headache sufferers: results from a school-based replication series. Headache. Jun. 2005;45(6):692-704. [pmid: 15953302].
101 Fichtel A, Larsson B. Relaxation treatment administered by school nurses to adolescents with recurrent headaches. Headache. Jun. 2004;44(6):545-54. [pmid: 15186298].
102 Jayapal S, Maheshwari N. Question 3. Topiramate for chronic migraine in children. Arch Dis Child. Mar. 2011;96(3):318-21. [pmid: 21317129].
103 Damen L, Bruijn J, Verhagen AP, et al. Prophylactic treatment of migraine in children. Part 2. A systematic review of pharmacological trials. Cephalalgia. May. 2006;26(5):497-505. [pmid: 16674757].
104 Connock M, Frew E, Evans BW, et al. The clinical effectiveness and cost-effectiveness of newer drugs for children with epilepsy. A systematic review. Health Technol Assess. Mar. 2006;10(7):iii-ix-118. [pmid: 16545206].
105 Bridge JA, Iyengar S, Salary CB, et al. Clinical response and risk for reported suicidal ideation and suicide attempts in pediatric antidepressant treatment: a meta-analysis of randomized controlled trials. JAMA. Apr. 18. 2007;297(15):1683-96. [pmid: 17440145].
106 Breslau N. Psychiatric comorbidity in migraine. Cephalalgia. Aug. Suppl 22. 1998;18:56-8. discussion 8-61. [pmid: 9793713].
107 Tfelt-Hansen P, Bjarnason NH, Dahl, et al. Evaluation and registration of adverse events in clinical drug trials in migraine. Cephalalgia. Jul. 2008;28(7):683-8. [pmid: 18498392].
108 Wasiewski WW. Preventive therapy in pediatric migraine. Journal of Child Neurology. Feb. 2001;16(2):71-8. [pmid: 11292228].
109 Sorge F, Marano E. Flunarizine v. placebo in childhood migraine. A double-blind study. Cephalalgia. May. Suppl 2. 1985;5:145-8. [pmid: 2861907].
110 Sinha IP, Altman DG, Beresford MW, et al. Standard 5: Selection, Measurement, and Reporting of Outcomes in Clinical Trials in Children. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S146-S52. [pmid: 22661761].
111 van der Tweel I, Askie L, Vandermeer B, et al. Standard 4: Determining Adequate Sample Sizes. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S138-S45. [pmid: 22661760].
112 Ellenberg S, Fernandes RM, Saloojee H, et al. Standard 3: Data Monitoring Committees. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S132-S7. [pmid: 22661759].
113 Hartling L, Hamm M, Klassen T, et al. Standard 2: Containing Risk of Bias. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S124-S31. [pmid: 22661758].
114 Caldwell PHY, Dans L, de Vries MC, et al. Standard 1: Consent and Recruitment. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S118-S23. [pmid: 22661757].
115 Hartling L, Wittmeier KDM, Caldwell P, et al. StaR Child Health: Developing Evidence-Based Guidance for the Design, Conduct, and Reporting of Pediatric Trials. Pediatrics. June. 1. 2012. 2012;129(Supplement 3):S112-S7. [pmid: 22661756].
116 van de Vrie-Hoekstra NW, de Vries TW, van den Berg PB, et al. Antiepileptic drug utilization in children from 1997-2005--a study from the Netherlands. Eur J Clin Pharmacol. Oct. 2008;64(10):1013-20. [pmid: 18618103].
117 Bazzano AT, Mangione-Smith R, Schonlau M, et al. Off-label prescribing to children in the United States outpatient setting. Acad Pediatr. Mar-Apr. 2009;9(2):81-8. [pmid: 19329098].
118 Choonara I, Conroy S. Unlicensed and off-label drug use in children: implications for safety. Drug Safety. 2002;25(1):1-5. [pmid: 11820908].
119 Horen B, Montastruc JL, Lapeyre-Mestre M. Adverse drug reactions and off-label drug use in paediatric outpatients. Br J Clin Pharmacol. Dec. 2002;54(6):665-70. [pmid: 12492616].
120 Ufer M, Kimland E, Bergman U. Adverse drug reactions and off-label prescribing for paediatric outpatients: a one-year survey of spontaneous reports in Sweden. Pharmacoepidemiol Drug Saf. Mar. 2004;13(3):147-52. [pmid: 15072113].
121 Shamliyan T, Kane RL. Clinical research involving children: registration, completeness, and publication. Pediatrics. May. 2012;129(5):e1291-300. [pmid: 22529271].