# Methods

We followed an a priori research protocol that we developed with the clinical and methodological input of the TEP. The protocol followed the Effective Health Care Program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”

## Literature Search Strategy

We searched for published studies in several databases, including MEDLINE^®^ (via Ovid and PubMed^®^), the Cochrane Library, and the SCIRUS bibliographic database. We searched the FDA Web site for medical and statistical reviews of the eligible drugs. We searched clinical trial registries including ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry to find ongoing, completed, and published trials of migraine prevention. We requested Scientific Information Packets from appropriate manufacturers (shown in Appendix A) per usual procedures. To find relevant unpublished studies, we reviewed the reference lists of identified guidelines, textbooks, and systematic reviews. We searched for the studies published in English up to May 20, 2012. We did not contact the investigators of the primary studies for missing data or clarifications.

The EPC developed a search strategy based on relevant medical subject heading (MeSH^®^) terms, text words, and weighted word-frequency algorithms to identify related articles. Exact search strategies can be found in Appendix A. Ongoing completed studies are shown in Appendix B.

Searches for relevant literature involved several steps: (1) evaluating previously published systematic reviews,40 (2) conducting a comprehensive literature search in the above databases to retrieve identified references, (3) screening abstracts against the inclusion/exclusion criteria, and (4) reviewing full-text articles of eligible studies to determine potential inclusion in the synthesis.

### Inclusion Criteria

We defined the target population, eligible preventive treatments, outcomes, time, and setting following the PICOTS framework (Population, Intervention, Comparator, Outcome, Timing, and Setting) (Appendix C Analytical framework). We defined the target population as community-dwelling children with episodic migraine, chronic daily headache, or chronic migraine defined according to criteria set by the International Headache Society.25 In order to synthesize the evidence from trials published before the most recent International Headache Society diagnostic criteria for migraine, we included trials that used previous definitions of chronic daily headache.

We formulated a list of eligible interventions after discussions with key informants and technical experts, and after consideration of public comments. Eligible comparators included pharmacologic, nonpharmacologic, and combined preventive treatments. We defined eligible intermediate and patient-centered outcomes (presented in the analytical framework, Figure 1).

Figure 1 Analytical framework37,38,41

KQ = Key Question

Key Question 1: What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in children?

Key Question 2: What are the comparative harms from pharmacologic treatments for preventing migraine attacks in children?

Key Question 3: Which characteristics of children predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks?

This figure presents a conceptual model and the analytical framework for the key questions within the context of the Population, Interventions, Comparators, Outcomes, and Settings. The framework includes eight headers: target population for question 1 as children with migraine, pharmacological and nonpharmacological treatments for children with migraine, intermediate outcomes such as number of monthly headache days, and clinical outcomes such as quality of life, prevention of migraine attacks, reduction in frequency of migraine attack by at least 50% from baseline, patient satisfaction, emergency visits, and loss of school days. In general, the figure illustrates pharmacological or combined modalities versus placebo, regular care, or active control may result in intermediate outcomes and clinical outcomes. Adverse events may occur at any point after treatment is received. Treatment effects may be modified by gender, race, aura, prior treatment, comorbidity, family history, and access to care. The figure also gives information about the research questions. Key Question 1: What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in children? Key Question 2: What are the comparative harms from pharmacologic treatments for preventing migraine attacks in children? Key Question 3: Which characteristics of children predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks?

Our inclusion criteria were:

1. Original epidemiologic studies that aimed to examine preventive pharmacologic treatments for migraine.
2. Publication in English.
3. Target population of community-dwelling children with episodic migraine, chronic daily headache, or chronic migraine defined according to International Headache Society criteria for chronic migraine.25
4. Eligible intermediate and patient-centered outcomes as listed in the analytical framework (Figure 1).

We reviewed original clinical studies that included children with migraine, comorbid headache disorders, or tension headache as long as they examined prevention of migraine. Episodic or chronic migraine as defined by the Headache Classification Committee of the International Headache Society25 does not include migraine variants or migraine equivalents with atypical symptomatic pain in regions other than the head.7,42 Therefore, we exclude these studies.

### Exclusion Criteria

1. Studies of treatments aimed at acute migraine attacks.
2. Studies that involved patients with migraine variants, such as basilar migraine, childhood periodic syndromes, retinal migraine, complicated migraines, and ophthalmoplegic migraine, hospitalized patients, or patients in emergency rooms.7,42,43 We also excluded hemiplegic migraine, a pathophysiologically distinct disorder with its own classification.43
3. Studies of short-term prevention of migraine, including menstrual migraines.
4. Studies that included some pediatric patients with migraine but did not separately report those outcomes.
5. Studies that involved surgical treatments for migraine.
6. Preclinical pharmacokinetic studies of eligible drugs; studies that examined the pathophysiology of migraine reporting instrumental measurements or biochemical outcomes.
7. Studies that did not test the associative hypotheses.
8. Studies that examined eligible drugs on populations with other diseases.
9. Studies evaluating the efficacy of nonpharmacologic treatments or economic outcomes were beyond the scope of this review.

## Study Selection

We followed the AHRQ Methods Guide to select evidence from controlled trials and observational studies.44 Three investigators independently determined study eligibility resolving disagreement in discussions until consensus was achieved, as recommended by the “Cochrane Handbook for Systematic Reviews of Interventions.”45 To assess treatment benefits, we included randomized controlled trials (RCTs). To assess treatment harms, we included all available evidence from RCTs and observational studies.44,46 We defined harms as a totality of all possible adverse consequences of an intervention.46 We analyzed harms regardless of how authors perceived causality of treatments.

## Data Extraction

Researchers used standardized forms to extract data (available at https://netfiles.umn.edu/xythoswfs/webui/_xy-21041343_1-t_zdhvSpvy). For each trial, one reviewer abstracted an article and a second reviewer checked the abstracted data for accuracy. We assessed errors by comparing established ranges for each variable with data charts from the original articles. Detected discrepancies were discussed. We abstracted the information relevant to the PICOTS framework. We abstracted minimum datasets to reproduce the results presented by the authors. For categorical variables, we abstracted the number of events among treatment groups to calculate rates, relative risk, and absolute risk differences. We abstracted means and standard deviations of continuous variables to calculate mean differences with a 95% confidence interval (CI).

For RCTs in the quantitative analysis set, we abstracted the number randomized to each treatment group as the denominator to calculate estimates by applying intention-to-treat principles. We abstracted the time when the outcomes were assessed as weeks from randomization and the time of followup after treatments.

We abstracted inclusion and exclusion criteria, drug regimen and doses, and patient characteristics including demographics, baseline frequency, severity, and prior treatment status as factors that could modify treatment effects. We abstracted migraine definitions used in each study. We abstracted sponsorship of the studies and conflict of interest by the authors.

## Risk of Bias Assessment

We evaluated the risk of bias in individual studies according to recommendations from the “Cochrane Handbook for Systematic Reviews of Interventions.”45 First, we classified the study design as interventional (an RCT, a nonrandomized controlled clinical trial, or a nonrandomized uncontrolled clinical trial) or observational (cohort or case-control studies, cross-sectional studies, or case series).

Then, using the criteria from the Cochrane risk of bias tool in interventional studies,47 we evaluated:

- Random allocation of the subjects to the treatment groups.
- Masking of the treatment status.
- Adequacy of allocation concealment.
- Adequacy of randomization according to baseline similarity of the subjects in treatment groups by demographics, migraine frequency and severity, and response to previous treatments.
- Intention-to-treat principles.
- Selective outcome reporting when compared to the posted protocols (when trials were registered) or methods section in the articles.

We assumed a low risk of bias when RCTs met all the risk of bias criteria; a medium risk of bias if at least one risk of bias criterion was not met; and a high risk of bias if two or more risk of bias criteria were not met. We concluded an unknown risk of bias for the studies with poorly reported risk of bias criteria. Since all outcomes in the review are self-reported, masking of outcome assessment was not essential in evaluating risk of bias, but masking of treatment was. Masking of treatment status was not feasible for RCTs that examined nondrug therapies as comparators. Therefore, for these RCTs we did not include masking in our risk of bias assessments. We appraised risk of bias in nonrandomized studies according to selection, attrition, and detection biases.48

We evaluated disclosure of conflict of interest by the authors of individual studies and funding sources but did not use this information to downgrade quality of individual studies.

## Data Synthesis

We summarized the results into evidence tables. We focused on the patient-centered outcomes of reduction in migraine attacks by ≥50 percent from baseline, quality of life, patient satisfaction, and composite outcomes that included migraine frequency and severity. We incorporated risk of bias in individual studies into the synthesis of evidence by using individual risk of bias criteria rather than a global score or a ranking category of overall risk of bias.49,50 Our evidence synthesis about comparative benefits and safety with drugs from individual RCTs was restricted to studies with low or medium risk of bias.23

We synthesized the evidence according to population characteristics that could modify treatment effects, including age, sex, and race; duration of migraine; baseline frequency and severity of acute migraine attacks; presence of aura; previous drug treatments; history of drug overuse; and other patient characteristics described in the PICOTS framework. We addressed the role of comorbidities and concomitant treatments in association with patient-centered outcomes. When possible, based on the reporting in original studies, we conducted subgroup and sensitivity analyses according to patient characteristics, drug dose, and timing of followup.

Using Meta-Analyst51 and STATA^®^52 software, we calculated the relative risk and absolute risk difference from the abstracted events and the mean differences in continuous variables from the reported means and standard deviations. We evaluated statistical significance at a 95% confidence level.

We analyzed adjusted relative risk from observational studies that examined the association between treatments and patient-centered outcomes. We used correction coefficients (0.5 as a default in statistical software) and enforced intention to treat as recommended calculations for missing data.45 We synthesized sparse data (defined as rates less than 2 percent) on adverse effects of the drugs using Peto odds ratio53 and arcsine transformed absolute risk.51,54-57 We evaluated the robustness of adverse effects estimates by comparing the results from described statistical models.

Pooling criteria for Key Questions 1 and 2 included the same active drug treatments and comparators and the same definitions of the outcomes.

For continuous outcomes we calculated mean difference and Cohen standardized mean differences for different continuous measures of the same outcome. To address clinical importance of the changes in continuous outcomes we also calculated means ratio.58 The means ratios clarified clinical interpretations of the differences in means.

We tested consistency in the results by comparing the direction and strength of the association,59 and we assessed heterogeneity in results with Chi-square and I-square tests.60,61 We explored heterogeneity with meta-regression and sensitivity analysis, reporting the results from random effects models only.62 Using the random effects model, we incorporated into the pooled analysis any differences between trials in patient populations, baseline rates of the outcomes, dosage of drugs, and other factors.53 We explored heterogeneity by risk of bias criteria, disclosed conflicts of interest, study sponsorship, dose and duration of drug treatments, time of followup, inclusion of minorities, and other patient characteristics described above. To avoid ecological fallacy, we did not use patient level variables (for example, mean age or body mass index) in meta-regression.62 We focused on direct comparisons and synthesized evidence from head-to-head comparative effectiveness studies. We did not attempt to conduct network meta-analysis of sparse data.

The number needed to treat to achieve one event of a patient-centered outcome was calculated as the reciprocal of statistically significant absolute risk differences (ARD) in rates of outcome events in the active and control groups.52,63 We calculated means and 95% CIs for the number needed to treat as reciprocal of pooled ARD when ARD is significant.64 The number of avoided or excess events (respectively) per population of 1,000 is the difference between the two events rates multiplied by 1,000. We calculated Bayesian odds ratios51,57 with 95% credible intervals. All calculations were performed at a 95% confidence level.

## Grading the Evidence for Each Key Question

We assessed strength of evidence according to risk of bias, consistency, directness, and precision for each patient-centered outcome including 100 percent or ≥50 percent reduction in monthly migraine frequency, patient global assessment of treatment success, and rates of clinically important improvement in migraine-related disability and quality of life, and treatment discontinuation due to harms.59 We defined treatment effect estimates as precise when pooled estimates had reasonably narrow 95% CIs, or pooled sample had ≥300 events.65 We did not include justification of the sample size into grading of the evidence, nor did we conduct post hoc statistical power analysis.

We defined reporting bias as publication bias, selective outcomes reporting, and multiple publication bias. We did not perform formal statistical tests to quantify the biases.66

In assessing strength of evidence, we also looked at dose-response association and strength of association in nonrandomized studies. We evaluated the strength of the association, defining a priori as a large effect when relative risk was >2 or <0.5 and a very large effect when relative risk was >5 or <0.2.^45^ We defined low magnitude of effect when the relative risk was significant but <2.

We defined a high strength of evidence on the basis of consistent findings from well-designed RCTs (Table 3). We downgraded strength of evidence to moderate if at least one of the four strength of evidence criteria (risk of bias, directness, consistency, and precision) was not met; for example, the studies had medium risk of bias or the results were not consistent or precise. We downgraded strength of evidence to low if two or more criteria were not met. We assigned a low level of evidence to nonrandomized studies and upgraded strength of evidence for strong or dose-response associations. We defined evidence as insufficient when a single study with high risk of bias examined treatment effects or associations. To better inform decisionmaking, our presentation of results includes estimates of treatment effects and our strength of evidence evaluations.67 Because insufficient evidence does not aid decisionmaking, we do not present it.

Table 3 Criteria to rank strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit a conclusion.

### Assessing Applicability

We estimated applicability of the sample by evaluating the selection of children with migraine in observational studies and clinical trials.68 Studies of community-dwelling children with 6 months or more followup with drug treatments had high applicability, as did large observational cohorts based on national registries, population-based effectiveness trials, and nationally representative administrative and clinical databases.

### Peer Review and Public Commentary

We invited experts in migraine management fields and individuals representing stakeholder and user communities to provide external peer review of this report. AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments and revised the text as appropriate. We documented all comments and our responses to them in a disposition of comments report that will be made available 3 months after the Agency posts the final review on the AHRQ Web site.