# Introduction

In the United States, migraine affects a significant number of children: 5 percent of boys1,2 and 7.7 percent of girls (Table 1).3,4 The American Migraine Prevalence and Prevention study of 32,015 adolescents found that childhood migraine is more prevalent in lower income families.3 The same study reported that among adolescents, migraine is more prevalent in Whites than African Americans.3

Table 1 Prevalence of migraine headache through childhood5

| 3–7 Years of Age | 7–11 Years of Age | 15 Years of Age
Prevalence | 1.2%–3.2% | 4%–11% | 8%–23%
Ratio by Sex | Boys > girls | Boys = girls | Girls > boys

According to the International Classification of Headache Disorders (second edition) (ICHD-II), migraine is a common disabling primary headache disorder manifesting in attacks that last from 4 to 72 hours.6,7 Migraine pain results primarily from increased activity of several agents that regulate blood vessels and sensory function of the brain.6 Migraine headaches range from moderate to very severe8 and are sometimes debilitating.

Migraine frequency is classified as either episodic or chronic based on the number of monthly migraine days7 (episodic is <15 days, and chronic is ≥15 days). Chronic migraine affects 2 percent of children and adolescents (Table 2).9

Table 2 Chronic migraine prevalence rates, from the Chronic Daily Headache in Adolescents Study (C-dAS)^*^

Characteristic | Population Category | Prevalence^†^ | Prevalence^‡^
All adolescents | 12-17 | 0.79 (0.00 to 1.70) | 1.75 (0.62 to 2.89)
Age, years | 12-13 | 0.09 (0.00 to 0.19) | 0.30 (0.12 to 0.48)
Age, years | 14-15 | 0.22 (0.06 to 0.38) | 1.04 (0.52 to 1.57)
Age, years | 16-17 | 2.02 (0.00 to 4.71) | 3.86 (0.45 to 7.26)
Sex | Male | 0.15 (0.05 to 0.26) | 0.55 (0.22 to 0.88)
Sex | Female | 1.39 (0 to 2.87) | 3.11 (0.70 to 5.53)

ICHD-IIR = International Classification of Headache Disorders, second edition, revised

* Prevalence estimates adjusted for nonresponse/noncoverage and benchmarked to U.S. Census data9.

† Adapted ICHD-IIR criteria (>15 headache days per month, >8 days of ICHD-II pediatric migraine, or most frequent headache medication was a triptan or ergot; >5 lifetime attacks of ICHD-II pediatric migraine; and no medication overuse).

‡ Adapted ICHD-IIR criteria used for CM and including individuals with (+) and without (-) medication overuse.

Migraine is further classified by whether or not it involves aura. Migraine with aura is characterized by episodes of intense disabling headache with visual symptoms or distortions that begin gradually and last for several minutes.5 Approximately 15 to 30 percent of children and adolescents with migraine experience aura.5 The diagnostic criteria for migraine with aura include brief duration (1 to 72 hours), bilateral or bifrontal location (age <15 years), and the inference of photophobia and phonophobia by behavioral response rather than verbal report.5 The most frequent forms of aura are binocular visual impairment with scotoma (77 percent), distortion or hallucinations (16 percent), and monocular visual impairment or scotoma (7 percent).5 Other accompanying symptoms may include photophobia (excessive sensitivity to light), phonophobia (fear of loud sounds), osmophobia (hypersensitivity to smells), nausea, or vomiting.8

Migraine significantly affects children's physical, psychological, and social well-being. It can impose serious lifestyle restrictions.9 Indeed, the majority of adolescents with chronic migraine have migraine-related disability.9 Yet, according to the Chronic Daily Headache in Adolescents Study, fewer than half of adolescents with chronic migraine had visited a healthcare provider. Fewer than one in five had taken medications to prevent headaches during the previous month.9

Prospective epidemiologic studies that followed children with migraine for decades demonstrated that around 20 percent became migraine free before the age of 25 (boys significantly more often than girls).10,11 However, more than half of children with migraine experienced attacks through middle and older age.10

Childhood migraine, whether chronic or episodic, can have a serious detrimental impact on daily life. Approximately 31 percent of children with migraine missed at least 1 day of school in the previous 3 months because of the condition.12 Childhood migraine has also been shown to impair learning and school productivity by ≥50 percent.12 Many children with frequent or severe attacks need treatment, which may aim either to ameliorate acute attacks or to prevent attacks. Drugs used to treat acute migraine attacks in children include nonsteroid anti-inflammatory agents, triptans, and antiepileptics.13 Our review focuses on preventive pharmacologic treatments for childhood migraine.

Preventive medications are presumed to address the pathophysiology of migraine.14,15 The four drugs approved by the U.S. Food and Drug Administration (FDA) for migraine prevention in adults come from different drug classes and include propranolol, timolol, topiramate, and divalproex sodium.16 The FDA has approved no drugs for migraine prevention in children; therefore, pediatricians prescribe either drugs approved for adults or off-label drugs (approved for clinical conditions other than migraine prevention).16,17 These drug classes cause common and serious adverse effects, including metabolic and hormonal abnormalities.18-22 Therefore, migraine preventive drug choices should be based on efficacy and safety of the available drugs, whether approved for adults or used off label.23-30

Preventive treatment aims to eliminate headache pain.23,24,31 Often, however, some pain persists; therefore, treatment success is usually defined by a decrease in migraine frequency by ≥50 percent after 3 months.8 In addition to pain relief, preventive drugs can also decrease severity of migraine attacks and reduce restrictions in daily activities and schooling.32,33 Some guidelines recommend preventive treatments for patients who have five or more migraine attacks per month,6 while others suggest it for those who experience a headache on most days of the month.25,34,35 No studies have examined outcomes of preventive treatments for long-term migraine frequency and adverse effects.8

Gaps remain in the published literature on preventive treatments for migraine in children. Published systematic reviews have focused on the efficacy of specific drugs rather than comparative effectiveness of all available pharmacologic and nonpharmacologic treatments, including multidisciplinary migraine management programs. Furthermore, evidence syntheses have neither consistently assessed risk of bias in individual studies nor evaluated strength of evidence about benefits and harms with available treatments.

Our review focuses on the comparative effectiveness and safety of drugs for preventing migraine attacks in children in ambulatory care settings; our results will help inform related treatment recommendations.

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing medical professional societies/clinicians in the areas of neurology, primary care, consumers, scientific experts, and payers, to help define the Key Questions (KQs).36 The KQs were then posted for public comment for 4 weeks from April 12, 2012, to May 10, 2012, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP) comprising clinical, content, and methodological experts to provide input in defining populations, interventions, comparisons, and outcomes and in identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP performed analysis of any kind, nor did any of them contribute to the writing of this report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Website.

We chose not to synthesize studies of flunarizine, because it lacks FDA approval. Efficacy of nonpharmacologic preventive treatments was beyond our scope. We conducted a comprehensive literature review following the principles in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter Methods Guide) developed by the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) Program37,38 and PRISMA guidelines (protocol registration number is CRD42011001858, available at http://www.crd.york.ac.uk/prospero/display_record.asp?ID=CRD42011001858 ).39

### Key Questions

Key Question 1. What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in children?

a. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to placebo or no active treatment?
b. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to active pharmacologic treatments?
c. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared to active nonpharmacologic treatments?
d. How do preventive pharmacologic treatments combined with nondrug treatments affect patient-centered and intermediate outcomes when compared to pharmacologic treatments alone?
e. How might dosing regimens or duration of treatments influence the effects of the treatments on patient-centered outcomes? How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

Key Question 2. What are the comparative harms from pharmacologic treatments for preventing migraine attacks in children?

a. What are the harms from preventive pharmacologic treatments when compared to placebo or no active treatment?
b. What are the harms from preventive pharmacologic treatments when compared to active pharmacologic treatments?
c. How might approaches to drug management (such as patient care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) improve safety of the treatments?

Key Question 3. Which characteristics of children predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks?