# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. We would like to thank the librarians, Judy Stanke, M.A., and Delbert Reed, Ph.D., for their contributions to the literature search; Jae-Young Choi, M.H.P.A., Ph.D., Jennifer Biggs Miller, P.T., M.P.H., C.W.S., and Shi-Yi Wang, M.D., M.S., Ph.D., for their assistance with the literature search and data abstraction; Jeannine Ouellette for her help in writing the report; Marilyn Eells for editing and formatting the report; and Christa Prodzinski, R.N., and Kirsten Johnson, B.S., for assistance with data entry, quality control, and formatting tables. We would like to thank Thomas Trikalinos, M.D., Ph.D., and Gerta Rücker, Ph.D., for their statistical advice in arcsine transformation of the data.