# Excluded Studies

1 Why do placebos work in some kids with migraine. Child Health Alert. Apr. 2008;26:5. Comment. [pmid: 18828187].
2 Adam EI, Gore SM, Price WH. Double blind trial of clonidine in the treatment of migraine in a general practice. J R Coll Gen Pract. Oct. 1978;28(195):587-90. Not eligible target population. [pmid: 368333].
3 Adelman J, Freitag FG, Lainez M, et al. Analysis of safety and tolerability data obtained from over 1,500 patients receiving topiramate for migraine prevention in controlled trials. Pain Med. Mar. 2008;9(2):175-85. Not eligible target population. [pmid: 18298700].
4 Ahonen K, Hamalainen ML, Eerola M, et al. A randomized trial of rizatriptan in migraine attacks in children. Neurology. Oct. 10. 2006;67(7):1135-40. Not eligible exposure. [pmid: 16943370].
5 Ahonen K, Hamalainen ML, Rantala H, et al. Nasal sumatriptan is effective in treatment of migraine attacks in children: A randomized trial. Neurology. Mar. 23. 2004;62(6):883-7. Not eligible target population. [pmid: 15037686].
6 Albsoul-Younes AM, Salem HA, Ajlouni SF, et al. Topiramate slow dose titration: improved efficacy and tolerability. Pediatr Neurol. Nov. 2004;31(5):349-52. Not eligible target population. [pmid: 15519117].
7 Altinok D, Agarwal A, Ascadi G, et al. Pediatric hemiplegic migraine: susceptibility weighted and MR perfusion imaging abnormality. Pediatr Radiol. Dec. 2010;40(12):1958-61. Not eligible target population. [pmid: 20821201].
8 Anonymous. Prochlorperazine more effective than ketorolac for pediatric migraine. Journal of Family Practice. 2004:444. Not eligible target population.
9 Arnold LE, Amato A, Bozzolo H, et al. Acetyl-L-carnitine (ALC) in attention-deficit/hyperactivity disorder: a multi-site, placebo-controlled pilot trial. Journal of child and adolescent psychopharmacology. 2007:791-802. Not eligible target population. [pmid: 18315451].
10 Arruda MA, Guidetti V, Galli F, et al. Primary headaches in childhood--a population-based study. Cephalalgia. Sep. 2010;30(9):1056-64. Not eligible exposure. [pmid: 20713556].
11 Arthur GP, Hornabrook RW. The treatment of migraine with BC 105 (pizotifen): a double blind trial. The New Zealand medical journal. 1971:5-9. Not eligible exposure. [pmid: 4925988].
12 Aydin M, Kabakus N, Bozdag S, et al. Profile of children with migraine. Indian Journal of Pediatrics. Nov. 2010;77(11):1247-51. Not eligible target population. [pmid: 20886317].
13 Bademosi O, Osuntokun BO. Pizotifen in the management of migraine. Practitioner. Feb. 1978;220(1316):325-7. Not eligible exposure. [pmid: 345259].
14 Bakker MK, Kerstjens-Frederikse WS, Buys CH, et al. First-trimester use of paroxetine and congenital heart defects: a population-based case-control study. Birth Defects Res A Clin Mol Teratol. Feb. 2010;88(2):94-100. Not eligible exposure. [pmid: 19937603].
15 Barry J, von Baeyer CL. Brief cognitive-behavioral group treatment for children's headache. Clin J Pain. Sep. 1997;13(3):215-20. Not eligible exposure. [pmid: 9303253].
16 Baser O, Palmer L, Stephenson J. The estimation power of alternative comorbidity indices. Value in Health. Sep-Oct. 2008;11(5):946-55. Not eligible exposure. [pmid: 18489502].
17 Behan PO. Pizotifen in the treatment of severe recurrent headache single and divided dose therapy compared. The British journal of clinical practice. 1982:13-7. Not eligible exposure. [pmid: 7082549].
18 Besser RE, Stern CM. Raynaud phenomena and migraine in two children: inclusion within a family of related disorders. Acta Paediatrica. Dec. 2005;94(12):1860-2. Not eligible exposure. [pmid: 16421056].
19 Bigal ME, Borucho S, Serrano D, et al. The acute treatment of episodic and chronic migraine in the USA. Cephalalgia. Aug. 2009;29(8):891-7. Not eligible target population. [pmid: 19222509].
20 Bigal ME, Lipton RB, Winner P, et al. Migraine in adolescents: association with socioeconomic status and family history. Neurology. Jul. 3. 2007;69(1):16-25. Not eligible outcomes. [pmid: 17606878].
21 Bigal ME, Rapoport AM, Sheftell FD, et al. Transformed migraine and medication overuse in a tertiary headache centre--clinical characteristics and treatment outcomes. Cephalalgia. Jun. 2004;24(6):483-90. Not eligible exposure. [pmid: 15154858].
22 Bigal ME, Sheftell FD, Tepper SJ, et al. Migraine days decline with duration of illness in adolescents with transformed migraine. Cephalalgia : an international journal of headache. 2005:482-7. Not eligible target population. [pmid: 15955034].
23 Bigal ME, Tsang A, Loder E, et al. Body mass index and episodic headaches: a population-based study. Archives of Internal Medicine. Oct. 8. 2007;167(18):1964-70. Not eligible target population. [pmid: 17923596].
24 Bille B, Ludvigsson J, Sanner G. Prophylaxis of migraine in children. Headache. 1977:61-3. Not eligible exposure. [pmid: 324951].
25 Boccia G, Del Giudice E, Crisanti AF, et al. Functional gastrointestinal disorders in migrainous children: efficacy of flunarizine. Cephalalgia. Oct. 2006;26(10):1214-9. Not eligible exposure. [pmid: 16961789].
26 Bottini F, Celle ME, Calevo MG, et al. Metabolic and genetic risk factors for migraine in children. Cephalalgia : an international journal of headache. 2006:731-7. Not eligible exposure. [pmid: 16686913].
27 Brandes JL, Saper JR, Diamond M, et al. Topiramate for migraine prevention: a randomized controlled trial. JAMA. Feb. 25. 2004;291(8):965-73. Not eligible target population. [pmid: 14982912].
28 Briars GL, Travis SE, Anand B, et al. Weight gain with pizotifen therapy. Archives of Disease in Childhood. Jul. 2008;93(7):590-3. Not eligible exposure. [pmid: 18381348].
29 Brousseau D, Duffy S, Anderson A, et al. Migraines in the pediatric emergency department: A randomized, double blind trial of IV ketorolac versus IV prochlorperazine. Pediatric research. 2002:101a. Not eligible target population.
30 Brousseau DC, Duffy SJ, Anderson AC, et al. Treatment of pediatric migraine headaches: a randomized, double-blind trial of prochlorperazine versus ketorolac. Ann Emerg Med. Feb. 2004;43(2):256-62. Not eligible target population. [pmid: 14747817].
31 Bruni O, Galli F, Guidetti V. Sleep hygiene and migraine in children and adolescents. Cephalalgia. Dec. Suppl 25. 1999;19:57-9. Not eligible target population. [pmid: 10668125].
32 Burns C. Migraine in a rural practice (1958-1963). A five-year study of a controlled clinical trial. J Coll Gen Pract. 1965:230-8. Not eligible exposure. [pmid: 4378868].
33 Campos L, Diaz Gomez M, Ondiviela R, et al. Naproxen sodium in the treatment of otitis. Atencion Primaria. 6. 1992:314-7. Not eligible target population. [pmid: 1600064].
34 Caruso JM, Brown WD, Exil G, et al. The efficacy of divalproex sodium in the prophylactic treatment of children with migraine. Headache. Sep. 2000;40(8):672-6. Not eligible outcomes. [pmid: 10971664].
35 Castellana M, Carini C, Caprici G, et al. Calcium entry blockers in the treatment of primary headached in childhood: our experiecne with flunarizine and nimodipine. Paper presented at, 1989; Headache in children and adolescents. Proceedings of the First International Symposium on Headache in Children and Adolescents. 1988 May 19-20. Pavia Italy. Not eligible exposure.
36 Chang CL, Donaghy M, Poulter N. Migraine and stroke in young women: case-control study. The World Health Organisation Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. BMJ (Clinical research ed.). 1999:13-8. Not eligible target population.
37 Christensen MF. Double blind placebo controlled trial of pizotifen syrup in the treatment of abdominal migraine. Archives of disease in childhood. 1995:183. Not eligible exposure. [pmid: 7574874].
38 Christensen ML, Eades SK, Fuseau E, et al. Pharmacokinetics of naratriptan in adolescent subjects with a history of migraine. Journal of Clinical Pharmacology. Feb. 2001;41(2):170-5. Not eligible outcomes. [pmid: 11210397].
39 Christensen ML, Mottern RK, Jabbour JT, et al. Pharmacokinetics of sumatriptan nasal spray in children. Journal of Clinical Pharmacology. Apr. 2004;44(4):359-67. Not eligible outcomes. [pmid: 15051742].
40 Chun-Fai-Chan B, Koren G, Fayez I, et al. Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol. Mar. 2005;192(3):932-6. Not eligible exposure. [pmid: 15746694].
41 Cianchetti C, Serci MC, Pisano T, et al. Compression of superficial temporal arteries by a handmade device: a simple way to block or attenuate migraine attacks in children and adolescents. Journal of Child Neurology. Jan. 2010;25(1):67-70. Not eligible exposure. [pmid: 19525492].
42 Cohen D, Huinink S. Atypical antipsychotic-induced diabetes mellitus in child and adolescent psychiatry. CNS Drugs. 2007;21(12):1035-8. Comment. [pmid: 18020482].
43 Cologno D, Torelli P, Manzoni GC. Migraine with aura: a review of 81 patients at 10-20 years' follow-up. Cephalalgia : an international journal of headache. 1998:690-6. Not eligible exposure. [pmid: 9950627].
44 Conte Hr, K TB. Psychotherapy for medically ill patients: review and critique of controlled studies. Review 35 refs. Psychosomatics. 1981:285-90. Not eligible target population. [pmid: 7015400].
45 Cunnington M, Ephross S, Churchill P. The safety of sumatriptan and naratriptan in pregnancy: what have we learned?. Headache. Nov-Dec. 2009;49(10):1414-22. Not eligible exposure. [pmid: 19804390].
46 Cupini LM, Santorelli FM, Iani C, et al. Cyclic vomiting syndrome, migraine, and epilepsy: a common underlying disorder?. Headache. Apr. 2003;43(4):407-9. Not eligible exposure. [pmid: 12656714].
47 Cuvellier J-C, Donnet A, Gu, et al. Treatment of primary headache in children: a multicenter hospital-based study in France. Journal of Headache & Pain. Dec. 2009;10(6):447-53. Not eligible exposure. [pmid: 19771388].
48 D'Andrea G, Cananzi AR, Grigoletto F, et al. The effect of dopamine receptor agonists on prolactin secretion in childhood migraine. Headache. 1988:354-9. Not eligible exposure. [pmid: 3403257].
49 Danesch U, Rittinghausen R. Safety of a patented special butterbur root extract for migraine prevention. Headache. 2003:76-8. Animal studies. [pmid: 12864764].
50 de Almeida R x00E, o F, et al. Migraine with persistent visual aura: response to furosemide. Clinics (Sao Paulo, Brazil). 2009;64(4):375-6. Not eligible exposure. [pmid: 19488599].
51 De Ciantis A, Muti M, Piccolini C, et al. A functional MRI study of language disturbances in subjects with migraine headache during treatment with topiramate. Neurological Sciences. May. Suppl 1. 2008;29:S141-3. Not eligible outcomes. [pmid: 18545916].
52 De Sanctis S, Grieco GS, Breda L, et al. Prolonged sporadic hemiplegic migraine associated with a novel de novo missense ATP1A2 gene mutation. Headache. Mar. 2011;51(3):447-50. Not eligible target population. [pmid: 21352219].
53 Del Bene E, Poggioni M, Michelacci S. Lisuride as a migraine prophylactic in children: an open clinical trial. Int J Clin Pharmacol Res. 1983;3(2):137-41. Not eligible exposure. [pmid: 6679514].
54 Di Rosa G, Attin x00E, et al. Efficacy of folic acid in children with migraine, hyperhomocysteinemia and MTHFR polymorphisms. Headache. Oct. 2007;47(9):1342-4. Not eligible exposure. [pmid: 17927652].
55 Di Rosa G, Span x00F, et al. Alternating hemiplegia of childhood successfully treated with topiramate: 18 months of follow-up. Neurology. Jan. 10. 2006;66(1):146. Not eligible target population. [pmid: 16401872].
56 Diener HC. Placebo effects in treating migraine and other headaches. Current Opinion in Investigational Drugs. Jul. 2010;11(7):735-9. Comment. [pmid: 20597189].
57 Dikel W, Olness K. Self-hypnosis, biofeedback, and voluntary peripheral temperature control in children. Pediatrics. 1980:335-40. Not eligible target population. [pmid: 7422423].
58 Ebinger F. Exteroceptive suppression of masseter muscle activity in juvenile migraineurs. Cephalalgia : an international journal of headache. 2006:722-30. Not eligible exposure. [pmid: 16686912].
59 Egger J, Carter C, Wilson J, et al. Food allergies and migraine in children. Monatsschrift fur Kinderheilkunde. 1983:686. Language.
60 Egger J, Carter CH, Soothill JF, et al. Effect of diet treatment on enuresis in children with migraine or hyperkinetic behavior. Clin Pediatr (Phila). May. 1992;31(5):302-7. Not eligible target population. [pmid: 1582098].
61 Egger J, Carter CM, Soothill JF, et al. Oligoantigenic diet treatment of children with epilepsy and migraine. The Journal of pediatrics. 1989:51-8. Not eligible target population. [pmid: 2909707].
62 Egger J, Carter CM, Wilson J, et al. Is migraine food allergy? A double-blind controlled trial of oligoantigenic diet treatment. Lancet. Oct. 15. 1983;2(8355):865-9. Not eligible exposure. [pmid: 6137694].
63 Egger J, McEwen L. Controlled study on the effectivity of hyposensitisation in children with food-induced migraine. Monatsschrift fur Kinderheilkunde. 1997:S21. Language.
64 Egger J, Stolla A, McEwen L. Controlled study on the effectivity of hyposensibilisation due to enzyme potency in children with food-induced migraine. Monatsschrift fur Kinderheilkunde. 1992:707. Language.
65 Elkind AH, Wade A, Ishkanian G. Pharmacokinetics of frovatriptan in adolescent migraineurs. Journal of Clinical Pharmacology. Oct. 2004;44(10):1158-65. Not eligible outcomes. [pmid: 15342617].
66 Elser Jm, W RC. Migraine headache in the infant and young child. Headache. 1990:366-8. Not eligible exposure. [pmid: 2370139].
67 Esposito SB, Gherpelli JL. Chronic daily headaches in children and adolescents: a study of clinical characteristics. Cephalalgia : an international journal of headache. 2004:476-82. Not eligible exposure. [pmid: 15154857].
68 Evers S, Rahmann A, Kraemer C, et al. Treatment of childhood migraine attacks with oral zolmitriptan and ibuprofen. Neurology. Aug. 8. 2006;67(3):497-9. Not eligible target population. [pmid: 16775229].
69 Fernandez-Rodriguez CM, Lledo JL, Lopez-Serrano P, et al. Effect of pentoxiphylline on survival, cardiac function, and portal and systemic hemodynamics in advanced alcoholic cirrhosis. Revista Espanola de Enfermedades Digestivas. 2008:481-9. Language. [pmid: 18942901].
70 Forsythe WI, Redmond A. Two controlled trials of tyramine in children with migraine. Developmedchild Neurol. 1974:794-9. Not eligible exposure.
71 Fox AW. Clinical trial ethics. Headache. Sep. 2005;45(8):1090-1. author reply 1. Letter. [pmid: 16109130].
72 Freitag FG, Forde G, Neto W, et al. Analysis of pooled data from two pivotal controlled trials on the efficacy of topiramate in the prevention of migraine. J Am Osteopath Assoc. Jul. 2007;107(7):251-8. Not eligible target population. [pmid: 17682112].
73 Fujita M, Fujiwara J, Maki T, et al. The efficacy of sodium valproate and a MRA finding in confusional migraine. Brain & Development. Apr. 2007;29(3):178-81. Not eligible outcomes. [pmid: 16973324].
74 Gaby AR. Intravenous nutrient therapy: the “Myers' cocktail”. Alternative Medicine Review. Oct. 2002;7(5):389-403. Not eligible target population. [pmid: 12410623].
75 Garaizar C, Prats JM, Zuazo E. Results of prophylactic treatment for common childhood headaches. Revista de Neurología. 1998. Language.
76 Garaizar C, Prats JM, Zuazo E. Response to prophylactic treatment of benign headache in children. Revista de neurologia. 1998:380-5. Language. [pmid: 9585947].
77 Gillies D, Sills M, Forsythe I. Pizotifen (Sanomigran) in childhood migraine. A double-blind controlled trial. European neurology. 1986:32-5. Not eligible exposure. [pmid: 3510125].
78 Gobel H, Heinze A, Dworschak M, et al. Analgesic efficacy and tolerability of locally applied oleum menthae piperitae preparation LI 170 in patients with migraine or tension-type headache. Zeitschrift fur Allgemeinmedizin. 2001:287-95. Not eligible target population.
79 Gobel H, Heinze A, Dworschak M, et al. Oleum menthae piperitae in the acute therapy of migraine and tension-type headache. Zeitschrift fur Phytotherapie. 2004:129-39. Language.
80 Good PA, Taylor RH, Mortimer MJ. The use of tinted glasses in childhood migraine. Headache. Sep. 1991;31(8):533-6. Not eligible exposure. [pmid: 1960058].
81 Gottschling S, Meyer S, Gribova I, et al. Laser acupuncture in children with headache: a double-blind, randomized, bicenter, placebo-controlled trial. Pain. 2008:405-12. Not eligible exposure. [pmid: 18022318].
82 Gottschling S, Meyer S, Gribova I, et al. Laser acupuncture in children with headache: a double-blind, randomized, bicenter, placebo-controlled trial. Deutsche Zeitschrift fur Akupunktur. 2009:52. Not eligible exposure.
83 Greenlee CR, Puri V. Pediatric migraines: a case report. Journal of the Kentucky Medical Association. Nov. 2003;101(11):498-504. Not eligible outcomes. [pmid: 14635578].
84 Gruppo LQ Jr. Intravenous Zofran for headache. Journal of Emergency Medicine. Aug. 2006;31(2):228-9. Not eligible target population. [pmid: 17044590].
85 Guariso G, Bertoli S, Cernetti R, et al. Migraine and food intolerance: a controlled study in pediatric patients. La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1993:57-61. Language. [pmid: 8488128].
86 Gupta VK. Magnesium therapy for migraine: do we need more trials or more reflection?. Headache. May. 2004;44(5):445-6. Comment. [pmid: 15147256].
87 Gysin T. Clinical hypnotherapy/self-hypnosis for unspecified, chronic and episodic headache without migraine and other defined headaches in children and adolescents. Forschende Komplementärmedizin. 1999:44-6. Language. [pmid: 10077718].
88 Gysin T, Z C. Clinical hypnosis therapy/self hypnosis for aspecific and episodic headache or migraine and other defined types of headaches in children and adolescents. Schweizerische Medizinische Wochenschrift Supplementum. 1994:64-6. Not eligible exposure. [pmid: 8073241].
89 Haddock CK, Rowan AB, Andrasik F, et al. Home-based behavioral treatments for chronic benign headache: a meta-analysis of controlled trials. Cephalalgia. Apr. 1997;17(2):113-8. Not eligible exposure. [pmid: 9137849].
90 Hall GC, Brown MM, Mo J, et al. Triptans in migraine: the risks of stroke, cardiovascular disease, and death in practice. Neurology. Feb. 24. 2004;62(4):563-8. Not eligible exposure. [pmid: 14981171].
91 Hamalainen M, Jones M, Loftus J, et al. Sumatriptan nasal spray for migraine: a review of studies in patients aged 17 years and younger. International Journal of Clinical Practice. Nov. 2002;56(9):704-9. Not eligible exposure. [pmid: 12469987].
92 Hamalainen ML, Hoppu K, Santavuori P. Sumatriptan for migraine attacks in children: a randomized placebo-controlled study. Do children with migraine respond to oral sumatriptan differently from adults?. Neurology. Apr. 1997;48(4):1100-3. Not eligible target population. [pmid: 9109909].
93 Hamalainen ML, Hoppu K, Santavuori PR. Oral dihydroergotamine for therapy-resistant migraine attacks in children. Pediatr Neurol. Feb. 1997;16(2):114-7. Not eligible target population. [pmid: 9090684].
94 Hershey AD. Adolescents with migraine: nature vs nurture. Neurology. Jul. 3. 2007;69(1):12-3. Comment. [pmid: 17606876].
95 Hershey AD, Powers SW, Bentti AL, et al. Effectiveness of amitriptyline in the prophylactic management of childhood headaches. Headache. Jul-Aug. 2000;40(7):539-49. Not eligible outcomes. [pmid: 10940092].
96 Hershey AD, Powers SW, LeCates S, et al. Effectiveness of nasal sumatriptan in 5- to 12-year-old children. Headache. Jul-Aug. 2001;41(7):693-7. Not eligible target population. [pmid: 11554957].
97 Hershey AD, Powers SW, Vockell A-LB, et al. Coenzyme Q10 deficiency and response to supplementation in pediatric and adolescent migraine. Headache. Jan. 2007;47(1):73-80. Not eligible exposure. [pmid: 17355497].
98 Hirfanoglu T, Serdaroglu A, Gulbahar O, et al. Prophylactic drugs and cytokine and leptin levels in children with migraine. Pediatric Neurology. Oct. 2009;41(4):281-7. Not eligible outcomes. [pmid: 19748048].
99 Hoffman L, Mayzell G, Pedan A, et al. Evaluation of a monthly coverage maximum (drug-specific quantity limit) on the 5-HT1 agonists (triptans) and dihydroergotamine nasal spray. Journal of Managed Care Pharmacy. Jul-Aug. 2003;9(4):335-45. Not eligible exposure. [pmid: 14613452].
100 Holtmann M, Opp J, Tokarzewski M, et al. Human epilepsy, episodic ataxia type 2, and migraine. Lancet. Jan. 12. 2002;359(9301):170-1. Comment. [pmid: 11809294].
101 Iannetti P, Spalice A, Iannetti L, et al. Residual and persistent Adie's pupil after pediatric ophthalmoplegic migraine. Pediatric Neurology. Sep. 2009;41(3):204-6. Not eligible outcomes. [pmid: 19664538].
102 Itil TM, Herrmann WM, Akpinar S. Prediction of psychotropic properties of lisuride hydrogen maleate by quantitative pharmaco-electroencephalogram. Int J Clin Pharmacol Biopharm. Jul. 1975;12(1-2):221-33. Not eligible target population. [pmid: 1100539].
103 Jeavons PM, Clark JE, Maheshwari MC. Treatment of generalized epilepsies of childhood and adolescence with sodium valproate (“epilim”). Dev Med Child Neurol. Feb. 1977;19(1):9-25. Not eligible target population. [pmid: 403104].
104 Kabbouche MA, Powers SW, Segers A, et al. Inpatient treatment of status migraine with dihydroergotamine in children and adolescents. Headache. Jan. 2009;49(1):106-9. Not eligible target population. [pmid: 19125879].
105 Kabbouche MA, Powers SW, Vockell A-LB, et al. Carnitine palmityltransferase II (CPT2) deficiency and migraine headache: two case reports. Headache. May. 2003;43(5):490-5. Not eligible target population. [pmid: 12752755].
106 Kabbouche MA, Vockell AL, LeCates SL, et al. Tolerability and effectiveness of prochlorperazine for intractable migraine in children. Pediatrics. Apr. 2001;107(4):E62. Not eligible target population. [pmid: 11335783].
107 Kakisaka Y, Wakusawa K, Haginoya K, et al. Abdominal migraine associated with ecchymosis of the legs and buttocks: does the symptom imply an unknown mechanism of migraine?. Tohoku Journal of Experimental Medicine. 2010;221(1):49-51. Not eligible exposure. [pmid: 20453457].
108 Kitley JL, Lachmann HJ, Pinto A, et al. Neurologic manifestations of the cryopyrin-associated periodic syndrome. Neurology. 2010:1267-70. Not eligible target population. [pmid: 20404307].
109 Kmie T, Kami, et al. Usefulness of cerebral SPECT in the children with migraine. Neurologia i neurochirurgia polska. 2005:S36-41. Language. [pmid: 16419568].
110 Kornblau DH. Treatment of childhood migraine attacks with oral zolmitriptan and ibuprofen. Neurology. Apr. 24. 2007;68(17):1441. Comment. [pmid: 17452599].
111 Korostenskaja M, Pardos M, Kujala T, et al. Impaired auditory information processing during acute migraine: a magnetoencephalography study. Int J Neurosci. Jul. 2011;121(7):355-65. Not eligible target population. [pmid: 21425948].
112 Kothare SV. Efficacy of flunarizine in the prophylaxis of cyclical vomiting syndrome and abdominal migraine. European Journal of Paediatric Neurology. 2005;9(1):23-6. Not eligible exposure. [pmid: 15701563].
113 Kroener-Herwig B, Denecke H. Cognitive-behavioral therapy of pediatric headache: are there differences in efficacy between a therapist-administered group training and a self-help format?. J Psychosom Res. Dec. 2002;53(6):1107-14. Not eligible exposure. [pmid: 12479993].
114 Kung TA, Totonchi A, Eshraghi Y, et al. Review of pediatric migraine headaches refractory to medical management. Journal of Craniofacial Surgery. Jan. 2009;20(1):125-8. Not eligible outcomes. [pmid: 19165008].
115 Labbe E, W DA. Temperature biofeedback in the treatment of children with migraine headaches. J Pediatr Psychol. 1983:317-26. Not eligible exposure. [pmid: 6668525].
116 Labbe EE. Treatment of childhood migraine with autogenic training and skin temperature biofeedback: a component analysis. Headache. Jan. 1995;35(1):10-3. Not eligible exposure. [pmid: 7868327].
117 Labbe EL, Williamson DA. Treatment of childhood migraine using autogenic feedback training. J Consult Clin Psychol. Dec. 1984;52(6):968-76. Not eligible exposure. [pmid: 6520289].
118 Lanzi G, D'Arrigo S, Termine C, et al. The effectiveness of hospitalization in the treatment of paediatric idiopathic headache patients. Psychopathology. 2007:1-7. Not eligible target population. [pmid: 17057418].
119 Larsson B, Carlsson J, Fichtel A, et al. Relaxation treatment of adolescent headache sufferers: results from a school-based replication series. Headache. Jun. 2005;45(6):692-704. Not eligible exposure. [pmid: 15953302].
120 Lastra L, Herranz J, Arteaga R. Flunarizine or dihydroergotamine in the treatment of migraine in childhood. A randomised study of 50 patients. Anales Espa±oles de Pediatrfa. 1990:213-18. Language.
121 Lastra Martinez L, Herranz Fernandez J, Arteaga Manjon Cabez R. Flunarizine and dihydroergotamine in the treatment of migraine in children (published erratum appears in An Esp Pediatr 1990 Jun;32(6):566). An-Esp-Pediatr. 1990:213-8. Language. [pmid: 2189328].
122 Lastra Martínez L, Herranz Fernández J, Arteaga Manjón-Cabez R. Flunarizine and dihydroergotamine in the treatment of migraine in children. Anales españoles de pediatría. 1990:213-8. Language. [pmid: 2189328].
123 Lawler SP, Cameron LD. A randomized, controlled trial of massage therapy as a treatment for migraine. Ann Behav Med. Aug. 2006;32(1):50-9. Not eligible exposure. [pmid: 16827629].
124 Lehrer JF. Cyproheptadine's antiserotonin effects are responsible for its antimigraine activity. Headache. Oct. 2004;44(9):935. Comment. [pmid: 15447711].
125 Lewis D, Ashwal S, Hershey A, et al. Practice parameter: pharmacological treatment of migraine headache in children and adolescents: report of the American Academy of Neurology Quality Standards Subcommittee and the Practice Committee of the Child Neurology Society. Neurology. Dec. 28. 2004;63(12):2215-24. Guideline. [pmid: 15623677].
126 Lewis DW. Please don't let her suffer like I did!. Expert Review of Neurotherapeutics. May. 2005;5(3):291-4. Editorial. [pmid: 15938660].
127 Lewis DW. Headaches in children and adolescents. Pediatric Annals. Jul. 2010;39(7):388-90. Comment. [pmid: 20666342].
128 Lewis DW, Winner P, Hershey AD, et al. Efficacy of zolmitriptan nasal spray in adolescent migraine. Pediatrics. Aug. 2007;120(2):390-6. Not eligible target population. [pmid: 17671066].
129 Limmroth V, Biondi D, Pfeil J, et al. Topiramate in patients with episodic migraine: reducing the risk for chronic forms of headache. Headache. Jan. 2007;47(1):13-21. Not eligible target population. [pmid: 17355489].
130 Linder SL, Dowson AJ. Zolmitriptan provides effective migraine relief in adolescents. International Journal of Clinical Practice. Sep. 2000;54(7):466-9. Not eligible target population. [pmid: 11070573].
131 Linder SL, Mathew NT, Cady RK, et al. Efficacy and tolerability of almotriptan in adolescents: a randomized, double-blind, placebo-controlled trial. Headache. Oct. 2008;48(9):1326-36. Not eligible target population. [pmid: 18484981].
132 Lindkvist J, Airaksinen M, Kaukonen AM, et al. Evolution of paediatric off-label use after new significant medicines become available for adults: a study on triptans in Finnish children 1994-2007. Br J Clin Pharmacol. Jun. 2011;71(6):929-35. Not eligible target population. [pmid: 21564161].
133 Loder E. Safety of sumatriptan in pregnancy: a review of the data so far. CNS Drugs. 2003;17(1):1-7. Not eligible exposure. [pmid: 12467489].
134 Loder E, Goldstein R, Biondi D. Placebo effects in oral triptan trials: the scientific and ethical rationale for continued use of placebo controls. Cephalalgia. Feb. 2005;25(2):124-31. Not eligible target population. [pmid: 15658949].
135 Longo G, Rudoi I, Iannuccelli M, et al. Treatment of essential headache in developmental age with L-5-HTP (cross over double-blind study versus placebo). La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1984:241-5. Language. [pmid: 6397729].
136 Louis P, Schoenen J, Hedman C. Metoprolol v. clonidine in the prophylactic treatment of migraine. Cephalalgia. Sep. 1985;5(3):159-65. Not eligible target population. [pmid: 3899370].
137 Ludvigsson J. Letter: Propranolol in treatment of migraine in children. Lancet. Oct. 6. 1973;2(7832):799. Letter. [pmid: 4126507].
138 Lutschg J, Vassella F. Flunarizine and propranolol in the treatment of migraine in children. Schweizerische Medizinische Wochenschrift. 1990:1731-6. Language. [pmid: 2251492].
139 Lütschg J, Vassella F. The treatment of juvenile migraine using flunarizine or propranolol. Schweizerische medizinische Wochenschrift. 1990:1731-6. Language. [pmid: 2251492].
140 MacLennan SC, Wade FM, Forrest KM, et al. High-dose riboflavin for migraine prophylaxis in children: a double-blind, randomized, placebo-controlled trial. J Child Neurol. Nov. 2008;23(11):1300-4. Not eligible exposure. [pmid: 18984840].
141 Maneyapanda SB, Venkatasubramanian A. Relationship between significant perinatal events and migraine severity. Pediatrics. Oct. 2005;116(4):e555-8. Not eligible exposure. [pmid: 16199683].
142 Martinez LL, Fernandez JH, Manjon-Cabeza RA. Flunarizine or dihydroergotamine in the treatment of migraine in childhood. A randomised study of 50 patients. <ORIGINAL>. FLUNARIZINA O DIHIDROERGOTAMINA EN EL TRATAMIENTO DE LA MIGRANA EN LA INFANCIA. ESTUDIO RANDOMIZADO DE 50 PACIENTES. An Esp Pediat. 1990:213-8. Language.
143 Martinez-Lage JM. Flunarizine (Sibelium) in the prophylaxis of migraine. An open, long-term, multicenter trial. Cephalalgia. Suppl 8. 1988;8:15-20. Not eligible target population. [pmid: 3052850].
144 Mauskop A, Farkkila M, Hering-Hanit R, et al. Zolmitriptan is effective for the treatment of persistent and recurrent migraine headache. Curr Med Res Opin. 1999;15(4):282-9. Not eligible target population. [pmid: 10640260].
145 Mavromichalis I, Zaramboukas T, Giala MM. Migraine of gastrointestinal origin. European journal of pediatrics. 1995:406-10. Not eligible exposure. [pmid: 7641777].
146 Mazzone L, Vitiello B, Incorpora G, et al. Behavioural and temperamental characteristics of children and adolescents suffering from primary headache. Cephalalgia : an international journal of headache. 2006:194-201. Not eligible exposure. [pmid: 16426275].
147 McCarty J, Ruoff GE, Jacobson KD. Loracarbef (LY163892) versus cefaclor in the treatment of bacterial skin and skin-structure infections in an adult population. The American journal of medicine. 1992:80s-5s. Not eligible target population. [pmid: 1621751].
148 McGrath PJ, Humphreys P, Goodman JT, et al. Relaxation prophylaxis for childhood migraine: a randomized placebo-controlled trial. Dev Med Child Neurol. Oct. 1988;30(5):626-31. Not eligible exposure. [pmid: 3229560].
149 McGrath PJ, Humphreys P, Keene D, et al. The efficacy and efficiency of a self-administered treatment for adolescent migraine. Pain. Jun. 1992;49(3):321-4. Not eligible target population. [pmid: 1408297].
150 Mendizabal JE. Extended-release divalproex sodium improves the quality of life of adolescent migraineurs. Headache. Apr. 2002;42(4):327-8. Letter. [pmid: 12010402].
151 Miano S, Parisi P, Pelliccia A, et al. Melatonin to prevent migraine or tension-type headache in children. Neurol Sci. Sep. 2008;29(4):285-7. Not eligible exposure. [pmid: 18810607].
152 Mierzwi ski J, Pawlak O, et al. The vestibular system and migraine in children. Otolaryngologia polska. The Polish otolaryngology. 2000:537-40. Language. [pmid: 11202339].
153 Moorjani BI, Rothner AD. Indomethacin-responsive headaches in children and adolescents. Seminars in Pediatric Neurology. Mar. 2001;8(1):40-5. Not eligible target population. [pmid: 11332865].
154 Moreno MJ, Abounader R x00E, et al. Efficacy of the non-peptide CGRP receptor antagonist BIBN4096BS in blocking CGRP-induced dilations in human and bovine cerebral arteries: potential implications in acute migraine treatment. Neuropharmacology. Mar. 2002;42(4):568-76. Animal studies. [pmid: 11955527].
155 Morrato EH, Nicol GE, Maahs D, et al. Metabolic screening in children receiving antipsychotic drug treatment. Arch Pediatr Adolesc Med. Apr. 2010;164(4):344-51. Not eligible target population. [pmid: 20368487].
156 Natarajan S, Jabbour JT, Webster CJ, et al. Long-term tolerability of sumatriptan nasal spray in adolescent patients with migraine. Headache. Nov-Dec. 2004;44(10):969-77. Not eligible exposure. [pmid: 15546259].
157 Nezvalov x00E Henriksen K, et al. Triptan exposure during pregnancy and the risk of major congenital malformations and adverse pregnancy outcomes: results from the Norwegian Mother and Child Cohort Study. Headache. Apr. 2010;50(4):563-75. Not eligible target population. [pmid: 20132339].
158 Nickel AK, Hillecke T, Argstatter H, et al. Outcome research in music therapy: a step on the long road to an evidence-based treatment. Ann N Y Acad Sci. Dec. 2005;1060:283-93. Not eligible exposure. [pmid: 16597777].
159 Nicolodi M, Sicuteri F. L-5-hydroxytryptophan can prevent nociceptive disorders in man. Adv Exp Med Biol. 1999;467:177-82. Not eligible target population. [pmid: 10721054].
160 Noronha MJ. Double-blind randomised cross-over trial of timolol in migraine prophylaxis in children. Cephalalgia. 1985:174-5. Not eligible exposure.
161 Novembre E, Dini L, Bernardini R, et al. Unusual reactions to food additives. La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1992:39-42. Language. [pmid: 1579515].
162 Oedegaard KJ, Riise T, Dilsaver SC, et al. A pharmaco-epidemiological study of migraine and antidepressant medications: complete one year data from the Norwegian population. J Affect Disord. Mar. 2011;129(1-3):198-204. Not eligible exposure. [pmid: 20889212].
163 Oelkers-Ax R, Leins A, Parzer P, et al. Butterbur root extract and music therapy in the prevention of childhood migraine: an explorative study. Eur J Pain. Apr. 2008;12(3):301-13. Not eligible exposure. [pmid: 17659990].
164 Ogose T, Manabe T, Abe T. Childhood steroid-responsive painful ophthalmoplegia: clues to ophthalmoplegic migraine. Journal of Pediatrics. Aug. 2007;151(2):e8-9. author reply e. Comment. [pmid: 17643751].
165 Olness K, Hall H, Rozniecki JJ, et al. Mast cell activation in children with migraine before and after training in self-regulation. Headache. Feb. 1999;39(2):101-7. Not eligible exposure. [pmid: 15613202].
166 Olness K, Hall H, Schmidt W, et al. Mast cell activation in child migraine patients before and after training in self regulation. Alternative therapies in health and medicine. 1997:100-1. Not eligible exposure. [pmid: 8997810].
167 Olness K, MacDonald J. Self-hypnosis and biofeedback in the management of juvenile migraine. J Dev Behav Pediatr. Dec. 1981;2(4):168-70. Not eligible exposure. [pmid: 7033294].
168 Olson AD, Li BUK. The diagnostic evaluation of children with cyclic vomiting: a cost-effectiveness assessment. Journal of Pediatrics. Nov. 2002;141(5):724-8. Not eligible target population. [pmid: 12410206].
169 Omata T, Takanashi J, Wada T, et al. Genetic diagnosis and acetazolamide treatment of familial hemiplegic migraine. Brain & Development. Apr. 2011;33(4):332-4. Not eligible target population. [pmid: 20542393].
170 O'Quinn S, Ephross SA, Williams V, et al. Pregnancy and perinatal outcomes in migraineurs using sumatriptan: a prospective study. Arch Gynecol Obstet. Nov. 1999;263(1-2):7-12. Not eligible exposure. [pmid: 10728620].
171 Osterhaus SO, Passchier J, van der Helm-Hylkema H, et al. Effects of behavioral psychophysiological treatment on schoolchildren with migraine in a nonclinical setting: predictors and process variables. J Pediatr Psychol. Dec. 1993;18(6):697-715. Not eligible exposure. [pmid: 8138865].
172 Ottman R, Lipton RB. Is the comorbidity of epilepsy and migraine due to a shared genetic susceptibility?. Neurology. Oct. 1996;47(4):918-24. Not eligible exposure. [pmid: 8857719].
173 Overbeek WA, de Vroede MA, Lahuis BE, et al. Antipsychotics and metabolic abnormalities in children and adolescents: a review of the literature and some recommendations. Tijdschr Psychiatr. 2010;52(5):311-20. Language. [pmid: 20458678].
174 Paisley RD, Arora HS, Nazeri A, et al. Migraine and vasodepressor syncope in a large family. Texas Heart Institute Journal. 2009;36(5):468-9. Not eligible outcomes. [pmid: 19876431].
175 Pakalnis A, Kring D. Zonisamide prophylaxis in refractory pediatric headache. Headache. May. 2006;46(5):804-7. Not eligible outcomes. [pmid: 16643584].
176 Pakalnis A, Kring D, Paolicchi J. Parental satisfaction with sumatriptan nasal spray in childhood migraine. Journal of Child Neurology. Nov. 2003;18(11):772-5. Not eligible target population. [pmid: 14696905].
177 Panconesi A, Pavone E, Vacca F, et al. Triptans in the Italian population: a drug utilization study and a literature review. Journal of Headache & Pain. Apr. 2008;9(2):71-6. Not eligible exposure. [pmid: 18317865].
178 Parisi P, Kasteleijn-Nolst T x00E, et al. A case with atypical childhood occipital epilepsy “Gastaut type”: an ictal migraine manifestation with a good response to intravenous diazepam. Epilepsia. Nov. 2007;48(11):2181-6. Not eligible target population. [pmid: 17711460].
179 Parisi P, Pagani J, Galiffa S, et al. Migrainous vertigo unresponsive to antimigraine therapy in a child with “asymptomatic” cerebellar lesion: casual or causal association?. Cephalalgia. Oct. 2005;25(10):831-5. Not eligible target population. [pmid: 16162262].
180 Parker GB, Pryor DS, Tupling H. Why does migraine improve during a clinical trial? Further results from a trial of cervical manipulation for migraine. Aust N Z J Med. Apr. 1980;10(2):192-8. Not eligible exposure. [pmid: 6992760].
181 Parker GB, Tupling H, Pryor DS. A controlled trial of cervical manipulation of migraine. Aust N Z J Med. Dec. 1978;8(6):589-93. Not eligible target population. [pmid: 373735].
182 Patrick DL, Hurst BC, Hughes J. Further development and testing of the migraine-specific quality of life (MSQOL) measure. Headache. Jul-Aug. 2000;40(7):550-60. Not eligible target population. [pmid: 10940093].
183 Pedersen E, Moller CE. Methysergide in migraine prophylaxis. Clinical pharmacology and therapeutics. 1966:520-6. Not eligible target population. [pmid: 5328472].
184 Pellock JM, Willmore LJ. A rational guide to routine blood monitoring in patients receiving antiepileptic drugs. Neurology. Jul. 1991;41(7):961-4. Editorial. [pmid: 2067658].
185 Philipp M. Therapy of migraine. Clinical experience with Migraeflux, a new migraine drug. Fortschritte der Medizin. 1977:107-10. Language. [pmid: 832830].
186 Pintov S, Lahat E, Alstein M, et al. Acupuncture and the opioid system: implications in management of migraine. Pediatr Neurol. Sep. 1997;17(2):129-33. Not eligible exposure. [pmid: 9367292].
187 Piovesan EJ, Young Blood MR, Kowacs PA, et al. Prevalence of migraine in Noonan syndrome. Cephalalgia. Apr. 2007;27(4):330-5. Not eligible exposure. [pmid: 17376109].
188 Poston S, Dickson M, Johnsrud M, et al. Topiramate prescribing patterns among medicaid patients: diagnosis, comorbidities, and dosing. Clinical Therapeutics. Mar. 2007;29(3):504-18. Not eligible target population. [pmid: 17577471].
189 Pothmann R. Calcium-antagonist flunarizine vs. low-dose acetylsalicylic acid in childhood migraine: a double-blind study. Cephalalgia. 1985:385-56. Not eligible exposure.
190 Pothmann R. Migraine prophylaxis in children with low dose aspirin and flunarzin. Journal of Neurology. 1985:219. Record not found. [pmid: 2864402].
191 Pothmann R. Childhood migraine prophylaxis with calcium antagonist flunarizine and acetylsalicylic acid. A double blind study. Monatsschrift fur Kinderheilkunde. 1987:646-9. Language.
192 Pothmann R. Prevention of migraine with flunarizine and acetylsalicylic acid. A double-blind study. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft für Kinderheilkunde. 1987:646-9. Language. [pmid: 3313023].
193 Pothmann R, Danesch U. Migraine prevention in children and adolescents: results of an open study with a special butterbur root extract. Headache. Mar. 2005;45(3):196-203. Not eligible exposure. [pmid: 15836592].
194 Pothmann R, Lobisch M. Acute treatment of episodic childhood tension-type headache with flupirtine and paracetamol - A double-blind crossover-study. Schmerz. 2000:1-4. Not eligible target population. [pmid: 12799904].
195 Pothmann R, Winter K. Migraine prophylaxis with dihydroergotamine - A double-blind placebo-controlled study. Cephalalgia. 1989;9:428-9. Not eligible outcomes.
196 Pradalier A, Serratrice G, Collard M, et al. Beta-blockers and migraine. Efficacy of time-release propranolol versus placebo. Thérapie. 1990:441-5. Language. [pmid: 2260046].
197 Pradalier A, Serratrice G, Collard M, et al. Long-acting propranolol in migraine prophylaxis: results of a double-blind, placebo-controlled study. Cephalalgia. Dec. 1989;9(4):247-53. Not eligible target population. [pmid: 2692838].
198 Pradalier A, Vincent D. Migraine and non-steroidal anti-inflammatory agents. Pathologie-biologie. 1992:397-405. Language. [pmid: 1495823].
199 Rapoport A, Mauskop A, Diener HC, et al. Long-term migraine prevention with topiramate: open-label extension of pivotal trials. Headache. Jul-Aug. 2006;46(7):1151-60. Not eligible target population. [pmid: 16866719].
200 Riadh H, Mohamed G, Salah Y, et al. Pediatric case of ophthalmoplegic migraine with recurrent oculomotor nerve palsy. Canadian Journal of Ophthalmology. Dec. 2010;45(6):643. Not eligible exposure. [pmid: 21135898].
201 Richardson MS, Bowers BW, Petrie JL. The comparative clinical and economic benefits of drugs should be established and discussed as part of any formulary decision process. American Journal of Managed Care. Aug. 2002;8(8):693-4. author reply 4-5. Comment. [pmid: 12212757].
202 Richer LP, Laycock K, Millar K, et al. Treatment of children with migraine in emergency departments: national practice variation study. Pediatrics. Jul. 2010;126(1):e150-5. Not eligible target population. [pmid: 20530076].
203 Richter IL, McGrath PJ, Humphreys PJ, et al. Cognitive and relaxation treatment of paediatric migraine. Pain. 1986:195-203. Not eligible exposure. [pmid: 3523394].
204 Roach ES. Questioning botulinum toxin for headache: reality or illusion. Archives of Neurology. Jan. 2008;65(1):151-2. Comment. [pmid: 18195157].
205 Rompel H, Bauermeister PW. Aetiology of migraine and prevention with carbamazepine (Tegretol): results of a double-blind, cross-over study. S Afr Med J. Jan. 24. 1970;44(4):75-80. Not eligible target population. [pmid: 4905910].
206 Rosen JA. Observations on the efficacy of propranolol for the prophylaxis of migraine. Ann Neurol. Jan. 1983;13(1):92-3. Not eligible target population. [pmid: 6338806].
207 Rosenberg MD, Strassels SA. Serotonin-active drugs. Journal of the Massachusetts Dental Society. 2000;48(4):48-50. Not eligible exposure. [pmid: 11819931].
208 Rothner AD, Wasiewski W, Winner P, et al. Zolmitriptan oral tablet in migraine treatment: high placebo responses in adolescents. Headache. Jan. 2006;46(1):101-9. Not eligible target population. [pmid: 16412157].
209 Rothner AD, Winner P, Nett R, et al. One-year tolerability and efficacy of sumatriptan nasal spray in adolescents with migraine: results of a multicenter, open-label study. Clinical Therapeutics. Dec. 2000;22(12):1533-46. Not eligible target population. [pmid: 11192144].
210 Ruiz C, Gener B, Garaizar C, et al. Episodic spontaneous hypothermia: a periodic childhood syndrome. Pediatric Neurology. Apr. 2003;28(4):304-6. Not eligible target population. [pmid: 12849886].
211 Salfield SA, Wardley BL, Houlsby WT, et al. Controlled study of exclusion of dietary vasoactive amines in migraine. Arch Dis Child. May. 1987;62(5):458-60. Not eligible exposure. [pmid: 3038036].
212 Salmon M. Pizotifen (BC.105. Sanomigran) in the prophylaxis of childhood migraine. Cephalalgia. 1985;5(Suppl 3):178. PMID. Not eligible exposure.
213 Sánchez-Pérez R, Asensio M, Melchor A, et al. Clinical features of migraine according to the questionnaire 'Alcoi-92' in the Comtat area. Revista de neurologia. 1999:459-63. Language. [pmid: 10229957].
214 Santucci M, Cortelli P, Rossi PG, et al. L-5-hydroxytryptophan versus placebo in childhood migraine prophylaxis: a double-blind crossover study. Cephalalgia : an international journal of headache. 1986:155-7. Not eligible exposure. [pmid: 3533271].
215 Saper JR, Lake AE, Tepper SJ. Nefazodone for chronic daily headache prophylaxis: an open-label study. Headache. May. 2001;41(5):465-74. Not eligible exposure. [pmid: 11380644].
216 Sartory G, Muller B, Metsch J, et al. Psychological and medicinal treatment of migraine in children and adolescents. Verhaltenstherapie. 1995:A25. Language.
217 Schabert E, Crow WT. Impact of osteopathic manipulative treatment on cost of care for patients with migraine headache: a retrospective review of patient records. Journal of the American Osteopathic Association. Aug. 2009;109(8):403-7. Not eligible exposure. [pmid: 19706829].
218 Scharff L, Marcus DA, Masek BJ. A controlled study of minimal-contact thermal biofeedback treatment in children with migraine. J Pediatr Psychol. Mar. 2002;27(2):109-19. Not eligible exposure. [pmid: 11821495].
219 Schradi A, B J. Results in the therapy of bronchial asthma using histaglobine Zeitschrift fur Erkrankungen der Atmungsorgane. MitFolia Bronchologica. 1972:337-45. Not eligible target population.
220 Seidel WT, Mitchell WG. Cognitive and behavioral effects of carbamazepine in children: data from benign rolandic epilepsy. Journal of child neurology. 1999:716-23. Not eligible target population. [pmid: 10593548].
221 Serdaroglu G, Erhan E, Tekgul H, et al. Sodium valproate prophylaxis in childhood migraine. Headache. Sep. 2002;42(8):819-22. Not eligible outcomes. [pmid: 12390647].
222 Sewell RA, Gottschalk CH. Problem child is no headache. Headache. Feb. 2011;51(2):306. author reply -7. Comment. [pmid: 21083559].
223 Shin JI, Lee JS. Can chronic fatigue symptoms associated with nutcracker phenomenon be treated with aspirin?. Medical Hypotheses. 2007;69(3):704-5. Comment. [pmid: 17329037].
224 Shuhaiber S, Pastuszak A, Schick B, et al. Pregnancy outcome following first trimester exposure to sumatriptan. Neurology. Aug. 1998;51(2):581-3. Not eligible exposure. [pmid: 9710039].
225 Shulman ST. Headaches!. Pediatric Annals. Jul. 2010;39(7):386-7. Comment. [pmid: 20666341].
226 Sicuteri F, Del Bene E. The influence of tryptophan and parachlorophenylalanine on the sexual activity in man. Acta vitaminologica et enzymologica. 1975:100-2. Not eligible target population. [pmid: 146411].
227 Silberstein SD, Loder E, Forde G, et al. The impact of migraine on daily activities: effect of topiramate compared with placebo. Curr Med Res Opin. Jun. 2006;22(6):1021-9. Not eligible target population. [pmid: 16846536].
228 Silberstein SD, Neto W, Schmitt J, et al. Topiramate in migraine prevention: results of a large controlled trial. Arch Neurol. Apr. 2004;61(4):490-5. Not eligible target population. [pmid: 15096395].
229 Silcocks P, Whitham D, Whitehouse WP. P3MC: a double blind parallel group randomised placebo controlled trial of Propranolol and Pizotifen in preventing migraine in children. Trials. 2010;11:71. Not eligible exposure. [pmid: 20553601].
230 Sillanpää M, Koponen M. Papaverine in the prophylaxis of migraine and other vascular headache in children. Acta paediatrica Scandinavica. 1978:209-12. Not eligible exposure. [pmid: 343489].
231 Siniatchkin M, Hierundar A, Kropp P, et al. Self-regulation of slow cortical potentials in children with migraine: an exploratory study. Applied Psychophysiology and Biofeedback. 2000:13-32. Not eligible target population. [pmid: 10832507].
232 Sorge F, De Simone R, Marano E, et al. Efficacy of flunarizine in the prophylaxis if migraine in children: a double-blind, cross-over, controlled study. Cephalalgia. 1985:174. Not eligible exposure.
233 Soriani S, Battistella PA, Naccarella C, et al. Nimesulide and acetaminophen for the treatment of juvenile migraine: A study for comparison of efficacy, safety, and tolerability. Headache Quarterly. 2001:233-6. Not eligible target population.
234 Spigt MG, Kuijper EC, Schayck CP, et al. Increasing the daily water intake for the prophylactic treatment of headache: a pilot trial. European journal of neurology : the official journal of the European Federation of Neurological Societies. 2005:715-8. Not eligible exposure. [pmid: 16128874].
235 Sri-udomkajorn S, Ruangsuwan S. Short-term outcomes of tension type and migraine headache in children. Journal of the Medical Association of Thailand. Oct. Suppl 3. 2008;91:S104-8. Not eligible outcomes. [pmid: 19253504].
236 Storey JR, Calder CS, Hart DE, et al. Topiramate in migraine prevention: a double-blind, placebo-controlled study. Headache. Nov-Dec. 2001;41(10):968-75. Not eligible target population. [pmid: 11903524].
237 Swanson JW. Topiramate for migraine prevention. Curr Neurol Neurosci Rep. Mar. 2005;5(2):77-8. Not eligible target population. [pmid: 15743542].
238 Symon DN, Russell G. Double blind placebo controlled trial of pizotifen syrup in the treatment of abdominal migraine. Arch Dis Child. Jan. 1995;72(1):48-50. Not eligible exposure. [pmid: 7717738].
239 Teixeira AL, Meira FC, Maia DP, et al. Migraine headache in patients with Sydenham's chorea. Cephalalgia : an international journal of headache. 2005:542-4. Not eligible target population. [pmid: 15955042].
240 Tepper SJ, Donnan GA, Dowson AJ, et al. A long-term study to maximise migraine relief with zolmitriptan. Curr Med Res Opin. 1999;15(4):254-71. Not eligible target population. [pmid: 10640258].
241 Terwindt GM, Ophoff RA, Haan J, et al. Familial hemiplegic migraine: a clinical comparison of families linked and unlinked to chromosome 19. DMG RG. Cephalalgia : an international journal of headache. 1996:153-5. Not eligible target population. [pmid: 8734765].
242 Titus F, Davalos A, Alom J, et al. 5-Hydroxytryptophan versus methysergide in the prophylaxis of migraine. Randomized clinical trial. Eur Neurol. 1986;25(5):327-9. Not eligible exposure. [pmid: 3536521].
243 Torelli P, Cologno D, Manzoni GC. Weekend headache: a retrospective study in migraine without aura and episodic tension-type headache. Headache. Jan. 1999;39(1):11-20. Not eligible exposure. [pmid: 15613189].
244 Trottier ED, Bailey B, Dauphin-Pierre S, et al. Practice variation after implementation of a protocol for migraines in children. European Journal of Emergency Medicine. Oct. 2010;17(5):290-2. Not eligible target population. [pmid: 19864956].
245 Trottier ED, Bailey B, Dauphin-Pierre S, et al. Clinical outcomes of children treated with intravenous prochlorperazine for migraine in a pediatric emergency department. J Emerg Med. Aug. 2010;39(2):166-73. Not eligible target population. [pmid: 19150192].
246 Tuchin PJ, Pollard H, Bonello R. A randomized controlled trial of chiropractic spinal manipulative therapy for migraine. J Manipulative Physiol Ther. Feb. 2000;23(2):91-5. Not eligible target population. [pmid: 10714533].
247 Tuchman M, Edvinsson L, Geraud G, et al. Zolmitriptan provides consistent migraine relief when used in the long-term. Curr Med Res Opin. 1999;15(4):272-81. Not eligible target population. [pmid: 10640259].
248 Ueberall M. Sumatriptan in paediatric and adolescent migraine. Cephalalgia. Suppl 1. 2001;21:21-4. Not eligible exposure. [pmid: 11678817].
249 Uldall P, Bulteau C, Pedersen S, et al. Single-blind study of safety, tolerability, and preliminary efficacy of tiagabine as adjunctive treatment of children with epilepsy. Epilepsia. 1995;36(Suppl 3):S147-S8. PMID. Not eligible target population.
250 Vardi Y, Rabey IM, Streifler M, et al. Migraine attacks. Alleviation by an inhibitor of prostaglandin synthesis and action. Neurology. 1976:447-50. Not eligible target population. [pmid: 944395].
251 Vasconcellos E, Pina-Garza JE, Millan EJ, et al. Analgesic rebound headache in children and adolescents. J Child Neurol. Sep. 1998;13(9):443-7. Not eligible target population. [pmid: 9733291].
252 Verspeelt J, De Locht P, Amery WK. Post-marketing cohort study comparing the safety and efficacy of flunarizine and propranolol in the prophylaxis of migraine. Cephalalgia. Aug. 1996;16(5):328-36. discussion 288. Not eligible exposure. [pmid: 8869768].
253 Victor S, Ryan SW. Drugs for preventing migraine headaches in children. Cochrane Database of Systematic Reviews. 2003;(4):CD002761. Not eligible outcomes. [pmid: 14583952].
254 Vieira J, Pedro x00E, et al. Ophthalmoplegic migraine and infundibular dilatation of a cerebral artery. Headache. Oct. 2008;48(9):1372-4. Not eligible exposure. [pmid: 18631189].
255 Virtanen R, Aromaa M, Rautava P, et al. Changing headache from preschool age to puberty. A controlled study. Cephalalgia : an international journal of headache. 2007:294-303. Not eligible outcomes. [pmid: 17376106].
256 Visudtibhan A, Lusawat A, Chiemchanya S, et al. Flunarizine for prophylactic treatment of childhood migraine. Journal of the Medical Association of Thailand. Dec. 2004;87(12):1466-70. Not eligible exposure. [pmid: 15822542].
257 Visudtibhan A, Thampratankul L, Khongkhatithum C, et al. Migraine in junior high-school students: A prospective 3-academic-year cohort study. Brain & Development. Nov. 2010;32(10):855-62. Not eligible outcomes. [pmid: 20060252].
258 Vollono C, Ferraro D, Miliucci R, et al. The abnormal recovery cycle of somatosensory evoked potential components in children with migraine can be reversed by topiramate. Cephalalgia. Jan. 2010;30(1):17-26. Not eligible target population. [pmid: 19489886].
259 Vonderheid-Guth B, Todorova A, Wedekind W, et al. Evidence for neuronal dysfunction in migraine: concurrence between specific qEEG findings and clinical drug response--a retrospective analysis. European Journal of Medical Research. Nov. 30. 2000;5(11):473-83. Not eligible exposure. [pmid: 11121368].
260 Wainscott G, Sullivan FM, Volans GN, et al. The outcome of pregnancy in women suffering from migraine. Postgrad Med J. Feb. 1978;54(628):98-102. Not eligible exposure. [pmid: 634879].
261 Wang S-J, Fuh J-L, Lu S-R, et al. Outcomes and predictors of chronic daily headache in adolescents: a 2-year longitudinal study. Neurology. Feb. 20. 2007;68(8):591-6. Not eligible outcomes. [pmid: 17182975].
262 Weaver MB, Mackowiak JI, Solari PG. Triptan therapy impacts health and productivity. Journal of Occupational & Environmental Medicine. Aug. 2004;46(8):812-7. Not eligible target population. [pmid: 15300133].
263 Wilkins AJ, Patel R, Adjamian P, et al. Tinted spectacles and visually sensitive migraine. Cephalalgia. Nov. 2002;22(9):711-9. Not eligible exposure. [pmid: 12421156].
264 Winner P, Dalessio D, Mathew N, et al. Concomitant administration of antiemetics is not necessary with intramuscular dihydroergotamine. The American journal of emergency medicine. 1994:138-41. Not eligible target population. [pmid: 8161382].
265 Wober C, Wober-Bingol C. Intranasal sumatriptan for the acute treatment of migraine in children. Neurology. Mar. 14. 2000;54(5):1209-10. Not eligible target population. [pmid: 10720311].
266 Young WB, Hopkins MM, Shechter AL, et al. Topiramate: a case series study in migraine prophylaxis. Cephalalgia. Oct. 2002;22(8):659-63. Not eligible target population. [pmid: 12383061].
267 Zafeiriou DI, Vargiami E. Childhood steroid-responsive painful opthalmoplegia: clues to opthalmoplegic migraine. Journal of Pediatrics. Dec. 2006;149(6):881. Not eligible target population. [pmid: 17137913].
268 Zangaladze A, Asadi-Pooya AA, Ashkenazi A, et al. Sporadic hemiplegic migraine and epilepsy associated with CACNA1A gene mutation. Epilepsy & Behavior. Feb. 2010;17(2):293-5. Not eligible target population. [pmid: 20071244].
269 Zgorzalewicz M. Visual evoked potentials in children and school adolescents with migraine and tension-type headache. Clinical and neurophysiological correlations. Neurologia i neurochirurgia polska. 2005:S26-35. Language. [pmid: 16419567].
270 Zwozdziak W. Treatment of migraine with migristin. Wiadomo&#347;ci lekarskie (Warsaw, Poland 1960). 1973:1617-20. Language.