# Analytical Framework

## PICOTS Framework

### Population(s)

Children with episodic migraine, chronic daily headache, or chronic migraine as defined by the Headache Classification Subcommittee of the International Headache Society1 (see below for definitions).

- Patient characteristics that can modify the effects of pharmacological treatments for preventing migraine attacks in children and adults:
  – Age
  – Sex
  – The onset of menarche
  – Race and ethnicity
  – Socioeconomic status
  – Education
  – Family history
  – Access to care, type of care, and residence in rural or urban areas
  – Definition of migraine
  – Presence of aura
  – Headache frequency
  – Prior treatments; overuse of drugs for acute migraine
  – Obesity
  – Nutritional and dietary factors, specifically caffeine
  – Aerobic fitness
  – Previous head injury
  – Psychological factors and social/family support system
  – Comorbidities (depression, bipolar disorder, anxiety, diabetes, hypertension, cardiovascular diseases, others)
  – Concomitant medications for comorbid conditions

### Interventions

Off-label medications previously examined in clinical trials for preventing migraine.2

Monotherapy.

Multidrug interventions.

Combined pharmacological with nonpharmacological modalities: behavioral interventions with education, exercise, biofeedback, relaxation techniques, yoga, massage, acupuncture, and dietary supplements.

### Comparators

Placebo.

Drug treatments (comparative effectiveness).

Nonpharmacological treatments: behavioral interventions with education, exercise, biofeedback, relaxation techniques, yoga, massage, acupuncture, and dietary supplements.

### Outcomes

Patient-centered outcomes:

- Reduction of migraine attacks by >50 percent from baseline; primary outcome for the review.
- Quality of life.
- Patient satisfaction.
- Composite patient centered outcomes defined as an aggregate improvement of the aforementioned outcomes.
- Emergency visits, loss of school days; treatment failure.

Intermediate outcomes:

- Number of headache days.
- Number of moderate to severe headache days.
- Improvement in associated symptoms.
- Use of drugs for acute migraine (prescribed or over-counter).
- Physician/healthcare professional (HCP) visits.

Harms:

- All reported adverse reactions and effects (such as anxiety, nausea, vomiting, sleep time reduction, drowsiness, or weakness).
- Treatment discontinuation due to adverse effects.
- Additional medical resource utilization to manage adverse effects (e.g., prescription medication, urgent care/emergency services, physician/HCP visits).

### Timing

6 months or more; optimally 12 months

Any time of occurrence for harms

### Setting

Outpatient settings

## Definition of Terms

Migraine (as defined by the Headache Classification Subcommittee of the International Headache Society):1

Repeated attacks of headache lasting 4 to 72 hours in patients with a normal physical examination, no other reasonable cause for the headache, and

- At least two of the following features:
  – Unilateral pain
  – Throbbing pain
  – Aggravation by movement
  – Moderate or severe intensity
- Plus at least one of the following features:
  – Nausea/vomiting
  – Photophobia and phonophobia

Episodic migraine as an indication for preventive treatment:

- Five or more attacks a month3
- Three or more attacks a month3

Definitions of chronic migraine (can be chronic from onset or transformed from episodic migraine):

- FDA:
  – Chronic migraine is defined as having a history of migraine and experiencing a headache on most days of the month.4
- Revised International Headache Society criteria for chronic migraine:1
  1.5.1 Chronic migraine
    A. Headache (tension-type and/or migraine) on ≥15 days per month for at least 3 months
      * Characterization of a frequently recurring headache generally requires a headache diary to record information on pain and associated symptoms day by day for at least 1 month.
    B. Occurring in a patient who has had at least five attacks.
    C. On ≥8 days per month for at least 3 months headache has fulfilled C.1 and/or C.2 below; that is, has fulfilled criteria for pain and associated symptoms of migraine without aura.
      1. Has at least two of a–d
        a. Unilateral location
        b. Pulsating quality
        c. Moderate or severe pain intensity
        d. Aggravation by or causing avoidance of routine physical activity (e.g., walking or climbing stairs) and at least one of (1) or (2):
          (1) Nausea and/or vomiting
          (2) Photophobia and phonophobia
      2. Treated and relieved by triptan(s) or ergot before the expected development of C.1 above
    D. No medication overuse^†^ and not attributed to another causative disorder
      † Headache Classification Committee criteria for a medication overuse headache (A8.2)1

- Diagnostic criteria for pediatric migraine without aura5
  A. At least five attacks fulfilling criteria B through D
  B. Headache attacks lasting 1 to 72 hours
  C. Headache has at least two of the following characteristics:
    1. Unilateral location, which may be bilateral or frontotemporal (not occipital)
    2. Pulsing quality
    3. Moderate or severe pain intensity
    4. Aggravation by or causing avoidance of routine physical activity (e.g., walking, climbing stairs)
  D. During the headache, at least one of the following:
    1. Nausea or vomiting
    2. Photophobia and phonophobia, which may be inferred from a child's behavior
  E. Not attributed to another disorder
- Diagnostic criteria for pediatric migraine with aura5—episodes of intense disabling headache separated by symptom-free intervals.
  A. At least five distinct attacks lasting 1 to 72 hours and permit attacks to be briefer than in adults (range: 4–72 hours).
  B. The location of the pain may be unilateral or, in children younger than 15 years of age, bilateral (bifrontal or bitemporal). The quality of pain is typically pulsing or throbbing, a symptom that may require specific questioning in young children.
  C. The pain is moderate to intense and aggravated by routine physical activity, such as walking or climbing stairs.
  D. The accompanying associated autonomic features (nausea, vomiting, photophobia, and phonophobia) may be as disabling as the pain. The latter two features may be inferred by the patient's behavior if the child withdraws to a quiet dark place during the attack.
  E. The headache must be “not attributed to another disorder,” implying that the prudent physician should carefully consider other possible causes for the recurrent headaches.

The disorders within the migraine with aura spectrum reflect the concept that the focal symptoms, such as visual disruptions, hemiparesis, and aphasia, are manifestations of the regional neuronal depolarization and oligemia caused by cortical spreading depression (CSD). Clinical entities of childhood with focal neurologic symptoms, previously termed migraine variants, such as hemiplegic and basilar type, now are included within this category of migraine with aura.

### References

1 Olesen J, Bousser MG, Diener HC, et al. New appendix criteria open for a broader concept of chronic migraine. Cephalalgia. Jun. 2006;26(6):742-6. [pmid: 16686915].
2 Rapoport A. Antimigraine drugs: new frontiers. Neurol Sci. May. Suppl 1. 2009;30:S49-54. [pmid: 19415426].
3 Goadsby PJ, Raskin NH. Chapter 15. Headache. Fauci AS, Braunwald E, Kasper DL, Hauser SL, Longo DL, Jameson JL, et al., editors. Harrison's principles of internal medicine. 17th ed. New York. The McGraw-Hill Companies. 2008.
4 U.S. Food and Drug Administration. FDA News Release: FDA Approves Botox to Treat Chronic Migraine. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm229782.htm. February 1 2011.
5 Lewis DW. Pediatric migraine. Neurol Clin. May. 2009;27(2):481-501. [pmid: 19289227].

## Appendix Table C1 Pharmacological classes for migraine prevention

Drug, ATC Code* | Class of Drug
ANTIEPILEPTICS
Topiramate, N03AX11 | N03 ANTIEPILEPTICS N03AX Other antiepileptics
Lamotrigine, N03AX09 | N03A ANTIEPILEPTICS
Levetiracetam, N03AX14 | N03A ANTIEPILEPTICS
Pregabalin, N03AX16 | N03A ANTIEPILEPTICS alpha2-delta agonist
Carbamazepine , N03AF01 | N03A ANTIEPILEPTICS N03AF Carboxamide derivatives
Valproic acid, N03AG01 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, Gamma-aminobutyric acid (GABA) enhancer and analog
Vigabatrin, N03AG04 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, GABA transaminase inhibitor
Tiagabine, N03AG06 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, gamma aminobutyric acid (GABA) enhancer
Zonisamide, N03AX15 | N03A ANTIEPILEPTICS N03AX Other antiepileptics
Valproate | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives
Divalproex | Gamma-aminobutyric acid (GABA) enhancer and analog
Gabapentin, N03AX12 | N03A ANTIEPILEPTICS
Acetazolamide, S01EC01 | S01EC, carbonic anhydrase inhibitor
ANTIDEPRESSANTS
Nortriptyline , N06AA10 | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Clomipramine, N06AA04 | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Citalopram, N06AB04 | N06A ANTIDEPRESSANTS N06AB Selective serotonin reuptake inhibitors
Venlafaxine, N06AX16 | N06A ANTIDEPRESSANTS N06AX Other antidepressants
Amitriptyline | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Mirtazapine, N06AX11 | N06A ANTIDEPRESSANTS tricyclic antidepressants
BETA BLOCKERS
Timolol, C07AA06 | C07AA , Beta blocking agents, nonselective
Nadolol , C07AA12 | C07AA Beta blocking agents, nonselective
Propranolol,C07AA05 | C07AA Beta blocking agents, nonselective
Metoprolol,C07AB02 | C07AB Beta blocking agents, selective
Atenolol, C07AB03 | C07AB Beta blocking agents, selective
Bisoprolol,C07AB07 | C07AB Beta blocking agents, selective
Acebutolol,C07AB04 | C07AB Beta blocking agents, selective
Alprenolol, C07AA01 Oxprenolol, C07AA02 (discontinued in the FDA) | C07A BETA BLOCKING AGENTS C07AA Beta blocking agents, nonselective
Pindolol, C07AA03 | C07AA Beta blocking agents, nonselective
ACE INHIBITORS
Trandolapril, C09AA10 | C09AA ACE inhibitors
Enalapril,C09AA02 | C09AA ACE inhibitors
Captopril,C09AA01 | C09AA ACE inhibitors
Lisinopril, C09AA03 | C09AA ACE inhibitors
ANGIOTENSIN II ANTAGONISTS
Telmisartan,C09CA07 | C09CA Angiotensin II antagonists
Candesartan, C09CA06 | C09CA Angiotensin II antagonists
CALCIUM CHANNEL ANTAGONIST
Dotarizine | SELECTIVE CALCIUM CHANNEL ANTAGONIST; 5-HT receptors ANTAGONIST
Flunarizine, N07CA03; Sibelium | SELECTIVE CALCIUM CHANNEL ANTAGONISTN07C ANTIVERTIGO PREPARATIONS
SELECTIVE CALCIUM CHANNEL BLOCKERS
Nimodipine,C08CA06 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
Verapamil,C08DA01 | C08D SELECTIVE CALCIUM CHANNEL BLOCKERS WITH DIRECT CARDIAC EFFECTS C08DA Phenylalkylamine derivatives
Nicardipine,C08CA04 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
Nifedipine,C08CA05 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
ANTIADRENERGICS
Clonidine,C02AC01 | C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02AC Imidazoline receptor agonists
Labetalol, C07AG01 | C07AG , Alpha and beta blocking agents
Dixarit (clonidine, C02AC01) Guanfacine, C02AC02 | C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02AC Imidazoline receptor agonists
ANTI-DEMENTIA
Donepezil, N06DA02 Memantine, N06DX01 | N06 PSYCHOANALEPTICS N06D ANTI-DEMENTIA DRUGS N-methyl-D-aspartate (NMDA) receptor inhibitor
ANTIPSYCHOTICS
Aripiprazole,N05AX12 | N05A ANTIPSYCHOTICS
Olanzapine,N05AH03 | N05A ANTIPSYCHOTICS N05AH Diazepines, oxazepines, thiazepines and oxepines
Quetiapine,N05AH04 | N05A ANTIPSYCHOTICS N05AH Diazepines, oxazepines, thiazepines and oxepines
Deanxit (Flupentixol, N05AF01) | N05A ANTIPSYCHOTICS N05AF Thioxanthene derivatives
Sulpiride, N05AL01 (antipsychotic) | N05A ANTIPSYCHOTICS N05AL Benzamides
Prochlorperazine, N05AB04 | N05A ANTIPSYCHOTICS
DOPAMINERGIC AGENTS
Amantadine, N04BB01 | N04B DOPAMINERGIC AGENTS N04BB Adamantane derivatives N-methyl-D-aspartate (NMDA) receptor inhibitor
Dihydroergocryptine, N04BC03 | N04B DOPAMINERGIC AGENTS N04BC Dopamine agonists
ERGOT ALKALOIDS
Dihydroergotamine, N02CA01 | N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
Lisuride, N02CA07 Ergotamine, N02CA02 | N02C ANTIMIGRAINE PREPARATIONS N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
Methysergide, N02CA04 | N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
MUSCLE RELAXANTS
Botulinum Toxin Type A, M03AX01 | M03A MUSCLE RELAXANTS, PERIPHERALLY ACTING AGENTS M03AX Other muscle relaxants, peripherally acting agents
Tizanidine, M03BX02 | M03B MUSCLE RELAXANTS, CENTRALLY ACTING AGENTS
SYSTEMIC DRUGS
Montelukast, R03DC03 | R03D OTHER SYSTEMIC DRUGS FOR OBSTRUCTIVE AIRWAY DISEASES R03DC Leukotriene receptor antagonists

ATC code - The Anatomical Therapeutic Chemical classification