# Ongoing Studies of Migraine Prevention in Children

Appendix Table B1 Characteristics of ongoing studies of migraine prevention in children

Registration Number Recruitment | Interventions | Phases | Enrollment | Study Designs | Outcome Measures | Publication
NCT00195741 Completed | Drug: divalproex sodium | Phase 3 | 300 | Allocation: Randomized∣Endpoint Classification: Safety Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Treatment | Reduction from baseline in 4-week migraine headache rate∣Migraine headache rate in last 4 weeks of study∣Percent reduction from baseline∣Percent of subjects with >75% reduction in migraine headache rate | Not available
NCT00195754 Completed | Drug: divalproex sodium | Phase 3 | 114 | Allocation: Nonrandomized∣Endpoint Classification: Safety Study∣Intervention Model: Single Group Assignment∣Masking: Open Label∣Primary Purpose: Treatment | Safety outcome measure∣Migraine headache rate | Not available
NCT00195806 Completed | Drug: divalproex sodium | Phase 3 | 315 | Allocation: Nonrandomized∣Endpoint Classification: Safety Study∣Intervention Model: Single Group Assignment∣Masking: Open Label∣Primary Purpose: Treatment | Number of migraine headache days∣Adverse events∣Laboratory data∣Vital signs∣Study drug exposure∣Behavioral/cognitive assessments | Not available
NCT00237302 Completed | Drug: topiramate | Phase 3 | 162 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Prevention | Number of migraine days per month (28 days) during the double-blind treatment period relative to the prospective baseline period∣Monthly rates of migraine episodes, nonmigraine headache episodes, and total headache days; percentage of treatment responders; severity and duration of migraines; frequency and severity of associated migraine symptoms, and use of rescue medicines. | Not available, but Clinical Study Report CR002662 is available with the outcomes and methods
NCT00210535 Completed | Drug: Topiramate; Placebo | Phase 3 | 110 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Treatment | Percent reduction in the frequency of monthly migraine attacks (using 48-hour rule) over the last 12 weeks of the double-blind treatment phase compared with the 4-week prospective baseline period∣Percent reduction in (a) average monthly migraine days, (b) average monthly headache days, and (c) monthly migraine rate, over the last 12 weeks of the double-blind treatment phase compared with the prospective baseline period. | Not available, but synopsis available (Clinical study report CR002245)
NCT00231595 Completed | Drug: topiramate | Phase 3 | 768 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Treatment | Change in monthly (28 day) migraine period rate from the prospective baseline period to the double-blind phase.∣Proportion of patients responding to the treatment. Changes from baseline to the double-blind phase in number of monthly migraine attacks, monthly migraine days, number of days/month requiring rescue medication and Health-Related Quality of Life measures | Brandes, 2004^1^
NCT00236509 Completed | Drug: topiramate | Phase 3 | 763 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Treatment | Changes in length of time between the onset and cessation of painful migraine symptoms (migraine period) from baseline. Safety evaluations conducted throughout the study. Proportion of patients responding to the treatment. Changes from baseline to double-blind phase in number of monthly migraine attacks, monthly migraine days, number of days/month requiring rescue medication, and Health-Related Quality of Life measures. | Silverstein, 2004^2^
NCT00236561 Completed | Drug: topiramate, propranolol | Phase 3 | 786 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Treatment | Change in the monthly (28 days) migraine period rate from the Prospective Baseline Period to the Core Double-Blind Phase. Proportion of patients responding to treatment. Change from Baseline Phase to Core Double-Blind Phase in number of monthly migraine attacks, monthly migraine days, number of days/month requiring rescue medication, and Health Related Quality of Life measures | Diener, 2004^3^
NCT00131443 Completed | Drug: Topiramate | Phase II∣Phase III | 40 | Allocation: Randomized∣Control: Dose Comparison∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double-Blind∣Primary Purpose: Educational/Counseling/Training | The primary efficacy outcome will be the reduction in average monthly migraine-days over the entire double-blind phase relative to the prospective baseline period∣Reduction in frequency, severity and duration of basilar or hemiplegic aura symptoms∣Reduction in migraine pain severity and duration∣Reduction in migraine episode and headache episode frequency∣Reduction in total headache days∣Proportion of responders (i.e., the proportion of subjects who experience a â‰¥ 50% reduction in migraine-days and migraine episodes)∣Cumulative reduction in frequency of migraine days and migraine episodes∣Reduction in the use of acute/abortive medications∣Reduction in migraine-associated symptoms | Not available
NCT00158002 Completed | Drug: Topiramate | Phase II | 40 | Allocation: Nonrandomized∣Control: Uncontrolled∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Single Group Assignment∣Masking: Open Label∣Primary Purpose: Educational/Counseling/Training | Reduction of average monthly migraine days Reduction in frequency, severity and duration of basilar or hemiplegic aura symptoms∣Reduction in migraine pain severity and duration∣Migraine episode and headache episode frequency∣Total headache days∣Proportion of responders (i.e., the proportion of subjects who experience a 50% reduction in migraine-days and migraine episodes)∣Cumulative frequency of migraine days and migraine episodes∣Use of acute/abortive medications∣Migraine episode and headache episode frequency∣Total headache days∣Migraine-associated symptoms | Not available
NCT00203255 Completed | Drug: Soy Isoflavones | | 25 | Allocation: Nonrandomized∣Control: Uncontrolled∣Endpoint Classification: Efficacy Study∣Intervention Model: Single Group Assignment∣Masking: Open Label | To compare headache outcome measures between baseline and soy treatment periods. Headache outcome measures include frequency and duration of menstrually-associated migraine (MAM), as well as presence or absence of associated symptoms∣Duration of MAM headaches∣Maximum headache intensity∣Incidence of MAM headache associated symptoms∣Duration of MAM headache associated symptoms∣Maximum functional impairment score during MAM headache∣Incidence of use of rescue medication for the treatment of a MAM attack∣Patient satisfaction score at the end of each treatment period∣Describe headaches associated with menstruation∣Describe the association of headache to premenstrual symptoms.∣Explore premonitory symptoms in the menstrual migraine population∣Compare questionnaire data collected at screening visit to questionnaire data collected at termination visit.∣Assess electronic diary effectiveness in capturing diary information in this population | Not available
NCT00475514 Completed | Drug: Frovatriptan 2.5mg QD∣Drug: Frovatriptan 2.5 mg BID∣Drug: placebo | Phase III | | Allocation: Randomized∣Control: Placebo Control∣Intervention Model: Parallel Assignment∣Masking: Double-Blind | Primary endpoint Number of MRM headache free PMPs out of a potential of three treated PMPs∣Incidence of MRM headache∣Maximum headache intensity∣Incidence of moderate or severe MRM headaches∣Number of MRM headache free days during treated PMPs∣Incidence of MRM headache associated symptoms (e.g. photophobia, phonophobia, nausea and vomiting)∣Functional impairment during treatment phase∣Time to onset (days) of MRM headache (during the treated PMP and until five days post treatment)∣Time to onset of first post-treatment migraine Incidence of intercurrent migraine outside of the peri-menstrual period Use of rescue medication | Not available
NCT00551980 Completed | Behavioral: Cognitive, Relaxation, Exercise Therapy | Phase III | 2895 | Allocation: Randomized∣Control: Active Control∣Endpoint Classification: Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Open Label∣Primary Purpose: Treatment | Reduction in number of days per month with headache and shoulders pain after 6 months. Proportion of subjects with more than 4 days with headache and shoulder pain at the baseline that will have reduction in pain frequency of more than 50%, after 6 months∣Headache index (Intensity × Frequency) after 6 and 12 months. Frequency of analgesic drug consumption after 6 and 12 months Frequency of headache and shoulder pain after 12 months | Not available
NCT01035983 Completed | Drug: Frovatriptan 2.5 mg | Phase III | 550 | Endpoint Classification: Safety Study∣Intervention Model: Single Group Assignment∣Masking: Open Label∣Primary Purpose: Treatment | Incidence of all treatment-emergent adverse events (AEs).∣Incidence of menstrual migraine headache∣Maximum headache severity∣Number of headache-free days during a treated perimenstrual period (PMP)∣Occurrence and severity of menstrual migraine headache-associated symptoms∣Maximum functional impairment during menstrual migraine headache∣Incidence and severity of intercurrent migraine∣Total migraine burden∣Standard hematology and biochemistry∣12-lead electrocardiogram (ECG) and vital signs, physical examination∣Short-form 12 (SF-12) Health Related Quality of Life Questionnaire | MacGregor, 2009^4^
NCT01581281 Not yet recruiting | Drug: Amitriptyline∣Drug: Topiramate∣Drug: Placebo | Phase 3 | 675 | Allocation: Randomized∣Endpoint Classification: Safety/Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Double Blind (Subject, Caregiver, Investigator, Outcomes Assessor)∣Primary Purpose: Prevention | Reduction in Migraine Frequency (amitriptyline and topiramate)∣Reduction in absolute migraine disability score on PedMIDAS∣Safety and tolerability of amitriptyline and topiramate∣Occurrence of treatment-emergent serious adverse events∣Reduction in absolute migraine frequency days | Not available
NCT00269581 Active, not recruiting | Other: Educational CD-rom∣Other: Headstrong CD-rom | Phase III | 92 | Allocation: Randomized∣Control: Active Control∣Endpoint Classification: Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Open Label∣Primary Purpose: Treatment | Pain, mood, and stress self-rating scales∣Quality of life∣Headache-related disability | Not available
NCT00665236 Active, not recruiting | Other: Craniosacral therapy∣Procedure: Low strength static magnets | | 66 | Allocation: Randomized∣Control: Placebo Control∣Endpoint Classification: Efficacy Study∣Intervention Model: Parallel Assignment∣Masking: Single Blind (Outcomes Assessor)∣Primary Purpose: Treatment | HIT-6∣Headache frequency | Not available

## References

1 Brandes JL, Saper JR, Diamond M, et al. Topiramate for migraine prevention: a randomized controlled trial. JAMA. Feb. 25. 2004;291(8):965-73. [pmid: 14982912].
2 Silberstein SD, Neto W, Schmitt J, et al. Topiramate in migraine prevention: results of a large controlled trial. Arch Neurol. Apr. 2004;61(4):490-5. [pmid: 15096395].
3 Diener HC, Tfelt-Hansen P, Dahlof C, et al. Topiramate in migraine prophylaxis--results from a placebo-controlled trial with propranolol as an active control. J Neurol. Aug. 2004;251(8):943-50. [pmid: 15316798].
4 MacGregor EA, Brandes JL, Silberstein S, et al. Safety and tolerability of short-term preventive frovatriptan: a combined analysis. Headache. Oct. 2009;49(9):1298-314. [pmid: 19788471].