# Literature Search

January 2011 PubMed

# | Strings | N
#8 | Search “Migraine Disorders”[Mesh] AND “Migraine Disorders”[Mesh] Limits: Humans, Meta-Analysis, English | 97
#7 | Search “Migraine Disorders”[Mesh] AND “Migraine Disorders”[Mesh] Limits: Humans, Randomized Controlled Trial, English | 907

# | Strings | N
#71 | Search migraine NOT acute Limits: Humans, Randomized Controlled Trial, English | 655
#70 | Search migraine Limits: Humans, Randomized Controlled Trial, English | 1040
#66 | Search melatonin AND migraine | 55
#67 | Search melatonin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 7
#64 | Search “Brain-Derived Neurotrophic Factor”[Mesh] AND migraine | 6
#63 | Search “Brain-Derived Neurotrophic Factor”[Mesh] AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 1
#62 | Search “Brain-Derived Neurotrophic Factor”[Mesh] Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 94
#58 | Search Risperidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#57 | Search Paliperidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#56 | Search Methiothepin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#55 | Search Metergoline AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#53 | Search Lisuride AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 5
#51 | Search Bromocriptine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 4
#50 | Search Zotepine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#49 | Search Ziprasidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#48 | Search Trifluoperazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#47 | Search Tenilapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#46 | Search Sulpiride AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 1
#45 | Search Spiperone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#44 | Search Sertindole AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#43 | Search Olanzapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#42 | Search Loxapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#41 | Search Ketanserin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#40 | Search Imipramine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#39 | Search Fluperlapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#38 | Search Fluphenazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#36 | Search Cyproheptadine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 9
#35 | Search Clozapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#33 | Search Clomipramine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 2
#32 | Search Aripiprazole AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#31 | Search Amoxapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#29 | Search Amitriptyline AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 34
#28 | Search Amitriptyline AND migraine Limits: Humans, English | 150
#27 | Search 5-HT7 AND migraine Limits: Humans, English | 12
#24 | Search 5-HT7 Limits: Humans, English | 150
#13 | Search Quetiapine AND migraine Limits: Humans, English | 5
#21 | Search “Antipsychotic Agents ”[Pharmacological Action] AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 41
#20 | Search “Antipsychotic Agents ”[Pharmacological Action] AND migraine Limits: Humans, English | 206
#19 | Search “Antipsychotic Agents ”[Pharmacological Action] Limits: Humans, English | 51308
#11 | Search 5-HT2A AND migraine Limits: Humans, English | 14
#10 | Search 5-HT2A antagonists AND migraine Limits: Humans, English | 3
#7 | Search 5-HT2A antagonists Limits: Humans, English | 394
#5 | Search Alpha-2 agonists AND migraine Limits: Humans, English | 6
#4 | Search Alpha-2 agonists AND migraine | 17

#84 | Search telcagepant AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 4
#83 | Search olcegepant AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#82 | Search Arachidonic cascade modulators Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#80 | Search tonabersat) AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 6
#79 | Search dextromethorphan AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#78 | Search dextromethorphan AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#77 | Search loxapine AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
#76 | Search prochlorperazine AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 8
#75 | Search prochlorperazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 20

August, 2011

# | Strings | N
#15 | Search Phenelzine AND migraine Limits: Humans, Journal Article, English | 11
#14 | Search Bupropion AND migraine Limits: Humans, Journal Article, English | 1
#13 | Search Imipramine AND migraine Limits: Humans, Journal Article, English | 15
#12 | Search Imipramine AND headache Limits: Humans, Journal Article, English | 60
#11 | Search Doxepin AND headache Limits: Humans, Journal Article, English | 15
#9 | Search Desipramine AND headache Limits: Humans, Journal Article, English | 13
#10 | Search Desipramine AND migraine Limits: Humans, Journal Article, English | 1
#7 | Search Protriptyline AND headache Limits: Humans, Journal Article, English | 4
#6 | Search Protriptyline AND migraine Limits: Humans, Journal Article, English | 0

Updated search in Ovid; 1948 to November Week 3 2011

# | Searches | Results
1 | exp migraine disorders/dt | 5944
2 | exp migraine disorders/pc | 1669
3 | ad.fs. | 998247
4 | 2 and 3 | 286
5 | 1 or 4 | 6112
6 | 1 or 2 | 7065
7 | exp “off-label use”/ | 519
8 | off label.mp. | 2412
9 | 7 or 8 | 2412
10 | 6 and 9 | 14
11 | exp calcium channel blockers/ | 68976
12 | exp antihypertensive agents/ | 216956
13 | exp antidepressive agents/ | 113058
14 | exp anticonvulsants/ | 111349
15 | exp botulinum toxin type a/ | 4832
16 | exp alzheimer disease/dt | 8107
17 | 11 or 12 or 13 or 14 or 15 or 16 | 476372
18 | 6 and 17 | 1675
19 | 5 or 10 or 18 | 6489
20 | limit 19 to (humans and yr=“2000 -Current”) | 3195
21 | limit 20 to updaterange=“mesz(20111121020154-20111121091315]” | 0

Search for systematic reviews

Searches | Results
Search systematic[sb] AND (quetiapine) AND child | 16
Search systematic[sb] AND (Telmisartan) AND child | 1
Search systematic[sb] AND (Captopril) AND child | 5
Search systematic[sb] AND (Enalapril) AND child | 2
Search systematic[sb] AND (Femoxetine) AND child | 0
Search systematic[sb] AND (Metoprolol) AND child | 4
Search systematic[sb] AND (acebutolol) AND child | 0
Search systematic[sb] AND (bisoprolol) AND child | 0
Search systematic[sb] AND (Atenolol) AND child | 2
Search systematic[sb] AND (opipramol) AND child | 0
Search systematic[sb] AND (Nadolol) AND child | 0
Search systematic[sb] AND (Oxprenolol) AND child | 0
Search systematic[sb] AND (Alprenolol) AND child | 0
Search systematic[sb] AND (Labetalol) AND child | 1
Search systematic[sb] AND (Timolol) AND child | 2
Search systematic[sb] AND (Propranolol) AND child | 17
Search systematic[sb] AND (Pindolol) AND child | 0
Search systematic[sb] AND (Pindolol) | 18
Search systematic[sb] AND (Rizatriptan) AND child | 6
Search systematic[sb] AND (Zolmitriptan) AND child | 5
Search systematic[sb] AND (Frovatriptan) AND child | 0
Search systematic[sb] AND (Almotriptan) AND child | 1
Search systematic[sb] AND (Sumatriptan) AND child | 13
Search systematic[sb] AND (Venlafaxine) AND child | 8
Search systematic[sb] AND (Paroxetine) AND child | 13
Search systematic[sb] AND (citalopram) AND child | 12
Search systematic[sb] AND (fluvoxamine) AND child | 12
Search systematic[sb] AND (Nicardipine) AND child | 1
Search systematic[sb] AND (Verapamil) AND child | 4
Search systematic[sb] AND (Nimodipine) AND child | 5
Search systematic[sb] AND (Nifedipine) AND child | 4
Search systematic[sb] AND (Telcagepant) AND child | 0
Search systematic[sb] AND (Olanzapine) AND child | 18
Search systematic[sb] AND (aripiprazole) AND child | 16
Search systematic[sb] AND (Pizotifen) AND child | 9
Search systematic[sb] AND (Lasmiditan ) AND child | 0
Search systematic[sb] AND (Lasmiditan hydrochloride) AND child | 0
Search systematic[sb] AND (Quinazoline) AND child | 4
Search systematic[sb] AND (Piperazine) AND child | 1
Search systematic[sb] AND (Clonidine) AND child | 28
Search systematic[sb] AND (nortriptyline ) AND child | 4
Search systematic[sb] AND (mirtazapine) AND child | 2
Search systematic[sb] AND (Memantine) AND child | 3
Search systematic[sb] AND (Amantadine) AND child | 27
Search systematic[sb] AND (Botulinum Toxin Type A) AND child | 35
Search systematic[sb] AND (Montelukast) AND child | 19
Search systematic[sb] AND (Simvastatin) AND child | 5
Search systematic[sb] AND (cimetidine) AND child | 2
Search systematic[sb] AND (Indomethacin) AND child | 10
Search systematic[sb] AND (Flurbiprofen) AND child | 0
Search systematic[sb] AND (Valproic acid) AND child | 36
Search systematic[sb] AND (Divalproex) AND child | 40
Search systematic[sb] AND (Topiramate) AND child | 24
Search systematic[sb] AND (Eletriptan) AND child | 1
Search systematic[sb] AND (Naratriptan) AND child | 0
Search systematic[sb] AND (Pregabalin) AND child AND adverse | 1
Search systematic[sb] AND (Levetiracetam) AND child AND adverse | 4
Search systematic[sb] AND (amitriptyline) AND child AND adverse | 6
Search systematic[sb] AND (carbamazepine ) AND child AND adverse | 28
Search systematic[sb] AND (Prochlorperazine) AND child AND adverse | 2
Search systematic[sb] AND (melatonin) AND child AND adverse | 7
Search systematic[sb] AND (melatonin) AND child | 16
Search systematic[sb] AND (Naproxen) AND child | 6
Search systematic[sb] AND (flunarizine) AND child | 5
Search systematic[sb] AND (Dihydroergocryptine) AND child | 0
Search systematic[sb] AND (dihydroergotamine) AND child | 5
Search systematic[sb] AND (Ergotamine) AND child | 1

March 29, 2012

# | Searches | Results
1 | exp migraine disorders/dt | 5944
2 | exp migraine disorders/pc | 1674
3 | ad.fs. | 991506
4 | 2 and 3 | 288
5 | 1 or 4 | 6107
6 | 1 or 2 | 7059
7 | exp “off-label use”/ | 571
8 | off label.mp. | 2478
9 | 7 or 8 | 2478
10 | 6 and 9 | 14
11 | exp calcium channel blockers/ | 68415
12 | exp antihypertensive agents/ | 215895
13 | exp antidepressive agents/ | 112330
14 | exp anticonvulsants/ | 111378
15 | exp botulinum toxin type a/ | 4780
16 | exp alzheimer disease/dt | 8048
17 | 11 or 12 or 13 or 14 or 15 or 16 | 474031
18 | 6 and 17 | 1675
19 | 5 or 10 or 18 | 6481
20 | limit 19 to (humans and yr=“2000 -Current”) | 3194
21 | limit 20 to updaterange=“mesz(20111121020154-20111121091315]” | 0

Ovid Technologies, Inc. Email Service
- Search for: limit 20 to (english language and “all child (0 to 18 years)”)
- Results: 100

Database: Ovid MEDLINE(R) <1946 to May Week 2 2012> Search Strategy:
1. exp migraine disorders/dt (5965)
2. exp migraine disorders/pc (1692)
3. ad.fs. (1002489)
4. 2 and 3 (291)
5. 1 or 4 (6136)
6. 1 or 2 (7101)
7. exp “off-label use”/ (628)
8. off label.mp. (2572)
9. 7 or 8 (2572)
10. 6 and 9 (14)
11. exp calcium channel blockers/ (68722)
12. exp antihypertensive agents/ (217035)
13. exp antidepressive agents/ (113333)
14. exp anticonvulsants/ (112028)
15. exp botulinum toxin type a/ (4853)
16. exp alzheimer disease/dt (8211)
17. 11 or 12 or 13 or 14 or 15 or 16 (477138)
18. 6 and 17 (1689)
19. 5 or 10 or 18 (6514)
20. limit 19 to (humans and yr=“2000 -Current”) (3226)
21. limit 20 to (english language and “all child (0 to 18 years)”) (578)

Scientific Information Package requests and responses

Company Name | Date Responded
Abbott Laboratories | No response
Alexza Pharmaceuticals, Inc. | No response
Allergan, Inc. | No response
Almirall, S.A. | No response
AstraZeneca Pharmaceuticals, LP | No response
Beth Israel Deaconess Medical Center | No response
Boston Scientific | No response
BTG International, Ltd. | No response
Capnia, Inc. | No response
Centre Hospitalier Universitaire de Saint Etienne | No response
Cephalon, Inc | No response
Chengdu University of Traditional Chinese Medicine | No response
Clinvest | No response
CoLucid Pharmaceuticals, Inc. | No response
D-Pharm Ltd. | No response
Eisai Inc. | No response
Eli Lilly & Co | No response
Endo Pharmaceuticals | No response
eNeura | No response
Eurohead | No response
GlaxoSmithKline | Submitted
HaEmek Medical Center | No response
Ipsen Biopharm, Ltd | No response
Janssen Cilag Pharmaceutica S.A.C.I. | No response
Janssen EMEA | No response
Janssen Pharmaceutica NV | Submitted
Janssen-Ortho, Inc. | No response
Johnson & Johnson Pharmaceutical Research & Development, L.L.C. | No response
Kowa Pharmaceuticals America | No response
Lotus Pharmaceuticals, Inc. | No response
Luitpold Pharmaceuticals, Inc. | No response
Manhattan Pharmaceuticals, Inc. | No response
MAP Pharmaceuticals, Inc. | No response
Medtronic, Inc. | No response
Merck & Co., Inc. | Submitted
Nektar | Nothing to submit 11/16/2011
NeurAxon | No response
Nordlandssykehuset HF | No response
Novartis Pharmaceuticals Corporation | No response
NPS Pharmaceuticals | No response
Ortho-McNeil Janssen Scientific Affairs, LLC | No response
Ortho-McNeil Neurologics | No response
Ortho-McNeil-Janssen Pharmaceuticals, Inc | No response
Pfizer Inc | No response
Pozen | No response
PriCara® (Division of Ortho-McNeil-Janssen Pharmaceuticals, Inc.) | No response
Raptor Pharmaceutical Corp. | No response
Roxane Laboratories | No response
SK Chemicals | No response
Sorlandet Hospital HF | No response
Takeda Global Research & Development Center, Inc. | No response
Takeda Pharmaceuticals North America, Inc. | No response
The EMMES Corporation | No response
UCB, Inc. | No response
Valeant Pharmaceuticals International | No response
Zogenix | No response