# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ARD: Absolute risk difference
CBT: Cognitive behavioral training
CI: Confidence interval
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
ICHD-II: International Classification of Headache Disorders (second edition)
KQ: Key questions
MeSH: Medical Subject Heading
PICOTS: Population, Intervention, Comparator, Outcome, Timing, and Setting
PRISMA: Preferred Reporting Items for Systematic Review and Meta-Analysis
RCT: Randomized controlled trial
TEP: Technical Expert Panel