# Results

This section presents the results of the literature searches, followed by results for each Key Question (KQ). KQ 1 presents evidence on interventions targeting children exposed to trauma. KQ 2 presents similar evidence for interventions targeting children exposed to trauma who already have symptoms. KQ 3 provides a summary of the evidence by child characteristics, treatment characteristics, and the setting of the intervention. KQ 4 summarizes evidence on harms.

## Results of Literature Searches

Figure 2 presents our literature search results. Literature searches through August 3, 2012, for the current report identified 6,647 unduplicated citations. Appendix A provides a list of all search terms used and the results of each literature search.

Figure 2 Literature search results

No. = number

^a^ Additional articles were identified through grey literature searches (SIP searches, peer, and public review comments) and by means of manual entry or Medline, ProQuest, and Worldcat OCLC search engines.

^b^ We identified one systematic review45 for inclusion in this report. The review found no eligible studies.

Figure 2 is titled “Disposition of articles (PRISMA figure).” The figure is a flow chart that summarizes the search and selection of articles: There were 6,417 citations identified by searching PubMed, Web of Science (ISI), PsycINFO®, CINAHL®, and IPA, Embase, the Cochrane Library, and the PILOTS Database. There were 230 handsearch citations identified through other sources. After removal of duplicate citations, titles and abstracts of 6,647 references were screened for potential inclusion. Of these, 506 were deemed appropriate for full-text review in order to determine eligibility. After full-text review, 481 were not included in analysis: 84 were the wrong type of publication, 65 were the wrong study design, 256 were the wrong population, 8 contained the wrong or no intervention, 17 had either the wrong or no comparator, 16 had the wrong or no outcome, and 35 had a high risk of bias. Twenty-five articles are included in this report's qualitative synthesis.

After applying our eligibility and exclusion criteria to titles and abstracts of all identified citations, we excluded 6,141 articles. Thus, we obtained full-text copies of 506 published articles. We reapplied our inclusion criteria and excluded 446 of these articles from further review before the risk-of-bias assessment. Appendix C provides a list of excluded studies and reasons for exclusion at the full-text stage.

Of the 60 articles included after full-text review, we dropped 35 articles from further analysis because of their high risk of bias (described in detail below). Thus, we included a total of 25 articles for qualitative synthesis. Evidence tables for these 25 articles are provided in Appendix D; risk-of-bias assessments for all 60 articles included after full-text review can be found in Appendix E.

The 25 articles included in this review represent 23 studies. Of the 25 included articles, 16 were randomized controlled trials (RCTs), 6 were cluster RCTs, 2 were prospective cohort studies, and 1 was a systematic review. We assessed 19 included articles as medium risk of bias and 5 as low risk of bias. We did not assess the risk of bias for the single systematic review45 that met our criteria because tools such as AMSTAR cannot be applied easily to systematic reviews with no included studies. No other systematic reviews could be used in our review in their entirety because their inclusion/exclusion criteria did not match ours, although we evaluated the citation lists for several systematic reviews for additional studies.

We reviewed 58 unduplicated articles, obtained through scientific information packets, of which we excluded 43 during the abstract review stage and 13 during the full-text review stage. From the remaining 2 articles, we eliminated 1 study46 because of high risk of bias and included the other study47 in this report. Of the 58 articles we examined, 5 were unpublished; 4 of these studies were excluded during the abstract review stage, and 1 was excluded during the full-text review stage.

Our search of the grey literature yielded six articles, of which we excluded two during the abstract review stage and one during the full-text review stage. After assessing risk of bias for the remaining three studies, we eliminated one study48 for high risk of bias and included the other two studies49,50 in this report. Of the six studies we examined, only one of these studies was unpublished, and it was eliminated at the risk-of-bias review stage.

We also dropped 35 studies for high risk of bias. We most commonly eliminated studies with high risk of bias owing to selection bias (n=30), including poor randomization and lack of allocation concealment for trials and failure to control for confounding factors for observational studies (see Appendix E for further details). Other common reasons for the removal of studies with high risk of bias included attrition bias or differential attrition bias (n=12; e.g., loss to followup of ≥ 20% or differential loss to followup of ≥15% without appropriate handling of missing data), detection bias (n=11; e.g., bias in outcome assessment), and performance bias (n=9; e.g., not controlling for concurrently occurring or unintended interventions). Of these, we dropped 34 of 35 for multiple reasons; we dropped only one study with a single reason for the high risk-of-bias rating that invalidated all findings: a 77% drop-out rate (see Appendix E for more details). Having a study design less rigorous than a controlled trial did not drive our decision to drop the study for high risk of bias; we excluded only four of these 35 studies that had observational (prospective cohort) study designs. Most of these studies dropped for high risk of bias tested interventions similar to those included in our review (e.g., psychotherapeutic interventions such as cognitive behavioral therapy [CBT], eye movement desensitization and reprocessing (EMDR), exposure therapies, school-based interventions including Cognitive Behavioral Intervention for Trauma in Schools [CBITS] and pharmacotherapeutic interventions such as sertraline and other selective serotonin reuptake inhibitors [SSRIs]). Although high risk of bias studies may have added to some of the sparse evidence in this literature, their inclusion would not have materially altered strength of evidence (SOE) because they would not have increased our confidence in the estimate of effect.

### Descriptions of Included Studies

Overall, the evidence from 21 trials and 1 observational study (25 articles) evaluated 6 types of KQ 1 interventions targeting children with trauma exposure (7 studies, 8 articles) and 13 types of KQ 2 interventions targeting children with trauma exposure and already experiencing traumatic stress symptoms (15 studies, 16 articles). We also found 2 studies that addressed KQ 3 and 5 studies that addressed KQ 4. Although we identified numerous potential interventions in our protocol, very few studies examining these interventions met our inclusion criteria, likely because the interventions have not been implemented among children with trauma from sources other than maltreatment or family violence. For example, we did not find any evidence on child-parent psychotherapy, an intervention primarily used for maltreated children. The interventions included in our review had substantial heterogeneity in components, dose, frequency, involvement of family members, and mode and method of delivery. The wide variety of approaches presented challenges to attempts to combine or categorize interventions as we had anticipated. In four instances did we combine treatments for presentation and discussion: two mixed school-based interventions addressing KQ 1, two mixed school-based interventions addressing KQ 2, two CBITS trials addressing KQ 2, and two chloral hydrate pharmacotherapeutic trials addressing KQ 2. The remainder of this section describes the characteristics of studies, notes key points, and gives a detailed synthesis for each intervention in the order listed in Table 5 through Table 8. We support the analysis for each intervention with a summary table under key points showing overall findings. The detailed synthesis subsection for each intervention includes one table describing the characteristics of the study, a second table on results, and a third on SOE for each intervention type. Entries in summary tables are presented by intervention type first and then by the last name of the first author of the trial.

Table 5 Number of included studies by intervention, comparator, and outcome for Key Question 1: interventions targeting children exposed to trauma

Intervention | Comparator | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes | Number of Studies
TF-CBT (school group and individual) | No treatment | X | X | | | 1^51,52^
CFTSI | Supportive therapy | X | X | | | 1^53^
Mixed (psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments), ERASE Stress (school groups) | Wait-list control that received religious classes | X | X | X | X | 2^54,55^
Mixed (psychoeducational material and skills training with meditative practices, bio-energy exercises, art therapy, and narrative techniques for reprocessing traumatic experiences), Overshadowing the Threat of Terrorism (school groups) | Wait-list control | X | X | X | X | 1^56^
Early psychological intervention | Usual care | X | X | | | 1^50^
Propranolol | Placebo | X | | X | | 1^57^

CFTSI = Child and Family Traumatic Stress Intervention; ERASE Stress = Enhancing Resiliency Among Students Experiencing Stress; TF-CBT = trauma-focused cognitive behavioral therapy; X = evidence available on outcomes

Table 6 Number of included studies by intervention, comparator, and outcome for Key Question 2: interventions targeting children exposed to trauma already experiencing symptoms

Intervention | Comparator | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes | Numberof Studies
Trauma-focused cognitive behavioral therapy | Wait-list control | X | X | | | 1^58^
Cognitive processing therapy | Wait-list control | X | X | | | 1^59^
Narrative Exposure Therapy | Meditation-relaxation therapy | X | | X | X | 1^60^
Grief-and trauma-focused intervention-group | Grief- and trauma-focused intervention-individual | X | X | | | 1^61^
Grief-and trauma-focused intervention with coping skills and trauma loss narrative | Grief- and trauma-focused intervention with coping skills only | X | X | | X | 1^62^
Emotion Regulation Therapy | Relational supportive therapy | X | X | | | 1^49^
Eye movement desensitization and reprocessing | Wait-list control | X | X | X | X | 1^63^
Cognitive Behavioral Intervention for Trauma in Schools | Wait-list control | X | X | | X | 2^47,64^
Trauma and grief component therapy (school groups) | Usual care | X | X | | | 1^65^
Mixed (CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements) (school groups) | Wait list | X | X | | X | 2^66,67^
Imipramine | Chloral hydrate Placebo | X | | | | 2^68,69^
Fluoxetine | Placebo | X | | | | 1^69^
Sertraline | Placebo | X | X | | X | 1^70^

X = evidence available on outcomes

Table 7 Number of included studies by intervention, comparator, and subgroup comparisons for Key Question 3: subgroup differences in efficacy of interventions targeting children exposed to trauma, some of whom already have symptoms

Intervention | Comparator | Treatment Based on Exposure | Treatment Based on Symptoms | Subgroups Examined | Outcomes Compared | Number of Studies
TF-CBT (school group and individual) | No treatment | | X | Sex | Trauma symptom, mental health (depression) | 1^51^
Mixed (CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements) (school groups) | Wait list | | X | Age group, exposure to violence, sex | Trauma symptom, other (functional impairment) | 1^71^

CBT = cognitive behavioral therapy; TF-CBT = trauma-focused cognitive behavioral therapy; X = evidence available on outcomes

Table 8 Number of included studies by intervention, comparator, and harms comparisons for Key Question 4: harms in interventions targeting children exposed and/or already experiencing traumatic stress symptoms

Intervention | Comparator | Mental Health Harms | Physical Health Harms | Other Harms | Number of Studies
TF-CBT | Wait-list control | X | X | X | 1^58^
TGCT | Wait-list control | X | | | 1^65^
Sertraline | Placebo | X | X | X | 1^70^
Imipramine | Fluoxetine, placebo | X | X | X | 1^69^
Imipramine | Chloral hydrate | X | X | X | 1^68^

TF-CBT = trauma-focused cognitive behavioral therapy; TGCT = trauma and grief component therapy (school groups); X = evidence available on outcomes

We kept our main framework of organization by psychotherapy and pharmacotherapy approaches. For the psychotherapy approaches, we followed the organization of interventions in the introduction by describing cognitive-based therapies first, followed by other types of psychotherapies. For the cluster of school-based therapies, we first reported on specific individualized approaches and school-based approaches we had identified in our protocol (e.g., CBITS) that have both individual and group components. Following these interventions, we described school-based psychotherapies with mixed components.

For each subsection on characteristics of the trial, we present an overview, followed by details on population, intervention, comparator, outcome, and setting (i.e., PICOTS) and applicability. The key points distinguish “insufficient” grades for bodies of evidence in which some research exists on the outcomes but is insufficient to make a call on the SOE.

## Key Question 1 Interventions Targeting Children Exposed to Trauma

### Key Question 1 Trauma-Focused Cognitive Behavioral Therapy

#### Description of Included Studies

We found one prospective cohort study comprising two articles,51,52 rated medium risk of bias, addressing trauma-focused cognitive behavioral therapy (TF-CBT).

This study identified four schools in a single city severely affected by an earthquake. Children in the sixth and seventh grades were selected for therapy 1.5 years after the earthquake. The method of selecting children was not reported. The mean age was 13.2 years. All children were exposed to serious direct threats to life, including witnessing mutilating injuries, agonizing screams of distress, and cries for help. Children were selected based on exposure to therapy, not on diagnosis or symptom score. No children were on psychotropic medicine or other mental health treatment. For the 1.5-year ollow-up study, two schools closest to the study staff's clinics were chosen for treatment, and two other schools served as the control condition. Children participated in four group sessions (30 minutes) and two individual sessions (60 minutes) of TF-CBT over 3 weeks. Outcome measures included traumatic stress symptoms (University of California-Los Angeles [UCLA] Post-Traumatic Stress Disorder Index [PTSD-RI scores] and depressive symptoms [Children's Depression Scale]). See Table 9 for study characteristics.

Table 9 Trauma-focused cognitive behavioral therapy versus usual care: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Number | Risk of Bias
Goenjian, et al., 1997^51^ and Goenjian, et al., 2005^52^ | Male and female students in grades 6 and 7 from four schools in Gumri, Armenia | Natural disasters | Prospective cohort 12 weekly sessions of 1.5 hours (18 hours total) | G1: Trauma-focused cognitive behavioral therapy G2: Comparison schools | Pretreatment G1: 38 G2: 29 Analyzed G1: 35 G2: 29 1.5-year followup: G1: 35 G2:25 for PTSD; 20 for depression 3.5-year followup: G1: 36 G2: 27 | Medium

G = group; PTSD = post-traumatic stress disorder

This study does not report funding source. This study is applicable to children in resource-poor settings suffering from severe natural disasters who may not have significant post-traumatic stress symptoms but are at high risk for developing these symptoms.

#### Key Points

- PTSD symptoms: Participants in TF-CBT had greater decreases in PTSD symptoms than those in usual care in a single prospective cohort study51,52 (low SOE).
- Depression symptoms: Participants in TF-CBT had greater decreases in depression symptoms than those in usual care in a single prospective cohort study51,52 (low SOE).

#### Detailed Synthesis

One prospective cohort study51,52 found a significant difference in changes in PTSD symptoms scores and depressive symptom scores pretreatment to post-treatment among children receiving the intervention compared with those in the control schools (Table 10). We graded the SOE as low because of the presence of only one small prospective cohort study (Table 11).

Table 10 Trauma-focused cognitive behavioral therapy versus usual care: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Goenjian et al. 1997^51^ and Goenjian et al., 2005^52^ | G1: School-based TF-CBT G2: Comparison schools | Greater reduction of PTSD symptoms (child PTSD Reaction Index, score range 0–80) Pretreatment G1: 45.3 (SD=11.0) G2: 41.1 (SD=9.0) Within-group change at 1.5 years: G1: -13.1 (calculated) G2: 6.1 (calculated) Between-group change at 1.5 years: -19.2 (calculated) Adjusted between group MANOVA treatment*time: F=31.16, df=1,56, p<0.05 Within-group change at 3.5 years: G1: -16.3 (SD=13.0) G2: -5.4 (SD=11.0) Between-group change at 3.5 years: -10.9 (calculated) Reported t-test between group difference: t=3.5, df=61, p<0.001 | Greater reduction of depression symptoms (Depression Rating Scale; scale range 0–63) Pretreatment G1: 16.8 (SD=5.9) G2: 15.3 (SD=5.5) Within-group change at 1.5 years: G1: -0.8 (calculated) G2: 4.9 (calculated) Between-group change at 1.5 years G1 vs. G2: -5.7 (calculated) Between-group difference p value not reported Within-group change at 3.5 years: G1: -1.7 (SD=5.4) G2: 2.7 (SD=6.7) Between-group change at 3.5 years: -4.4 (calculated) Reported t-test between group difference: t=2.9, df=61, p<0.01 | NR | NR

df = degrees of freedom; G = group; MANOVA = multivariate analysis of variance; NR = not reported; PTSD = post-traumatic stress disorder; SD = standard deviation; TF-CBT = trauma-focused cognitive behavioral therapy

Table 11 Trauma-focused cognitive behavioral therapy: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TF-CBT | 1; 65 (65) | PTSD symptoms | Prospective cohort Medium | Unknown | Direct | Precise | Difference of 19.2 points on child PTSD reaction index at 1.5 years favoring TF-CBT Low
TF-CBT | 1; 65 (55) | Depression symptoms | Prospective cohort Medium | Unknown | Direct | Precise | Difference of 5.7 points on Depression Rating Scale at 1.5 years favoring TF-CBT Low

PTSD = post-traumatic stress disorder; TF-CBT = trauma-focused cognitive behavioral therapy

### Key Question 1 Child and Family Traumatic Stress Interventions

#### Description of Included Studies

We found one RCT, rated medium risk of bias, testing the efficacy of the Child and Family Traumatic Stress Intervention (CFTSI) with a population of children exposed to a potentially traumatic event for KQ 1.^53^

CFTSI is a four-session caregiver-child early intervention and secondary prevention model developed for children ages 7 to 17 years. CFTSI focuses on two key risk factors of poor social or familial support and poor coping skills in its effort to prevent chronic PTSD. CFTSI attempts to (1) increase communication between children and their caregivers about feelings, symptoms, and behaviors with the goal of increasing the caregivers' support of the child and (2) providing specific behavioral skills that are taught both to the caregiver and child to assist the child in coping with symptoms. CFTSI's focus is informed by findings that indicate the role of family support as a primary protective factor for children exposed to a potentially traumatic event. Fidelity to protocol was maintained through weekly group supervision, and progress notes were developed for each condition to help supervisors ensure fidelity.

Children ages 7 to 17 years who were exposed to a potentially traumatic event, including motor vehicle accidents, sexual abuse, witnessing of violence, physical assaults, injuries, animal bites, and threats of violence, were randomly assigned to a four-session CFTSI intervention (N=53) or a four-session supportive intervention (N=53).53 The intervention, designed to prevent the development of chronic PTSD, was provided within 30 days of exposure to the potentially traumatic event; treatment was provided in a mental health clinic. The study outcomes were trauma symptoms as measured by the University of California-Los Angeles (UCLA) Post-Traumatic Stress Disorder Index (PTSD-RI) and the Trauma Symptom Checklist for Children (TSCC). The study was funded by a clinical and treatment and service development grant to design early intervention models for youth exposed to a potentially traumatic event. See Table 12 for study characteristics.

Table 12 Child and Family Traumatic Stress Intervention versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Berkowitz, et al., 2011^53^ | Males and females ages 7–17 exposed to potentially traumatic event | Mixed trauma (MVA, sexual abuse, witnessing violence, physical assaults, injuries, threats of violence) | Parallel RCT Four weekly sessions (1–1.5 hours) psychotherapy sessions of CFTSI | Four sessions supportive intervention | Randomized: G1: 53 G2: 53 Analyzed: G1: 53 G2: 53 3-month followup: n=83 | Medium

CFTSI=Child and Family Traumatic Stress Intervention; G = group; MVA=motor vehicle accident; RCT = randomized controlled trial

The applicability of this intervention is limited to the specific populations recruited for this study: English-speaking male and female youth ages 7 to 17 years without developmental delay, having psychosis or bipolar disorder who were exposed to a potentially traumatic event including motor vehicle accidents, witnessing of violence, physical assaults, injuries, animal bites, threats of violence, and sexual abuse.

#### Key Points

We identified one RCT comparing the efficacy of CFTSI to a supportive comparison condition.53

- PTSD symptoms: Participants in the CFTSI group had significantly greater reductions in PTSD symptomatology than participants receiving a supportive intervention at 3 months following intervention (low SOE).
- PTSD diagnosis: Participants in the CFTSI group had a greater decrease in the proportion of those with full and partial PTSD diagnosis at the 3-month followup (low SOE).

#### Detailed Synthesis

In one RCT53 CFTSI participants demonstrated a greater decrease in full and partial PTSD diagnoses than the comparison group (Table 13). The children in the CFTSI group also demonstrated a greater reduction in PTSD and anxiety symptom scores than the comparison group. We found insufficient evidence of CFTSI having an effect on dissociation given that only one study met study criteria and the significance of the effect size was not reported; thus, we graded the SOE as insufficient (Table 14). For all other outcomes (PTSD diagnoses and symptoms and anxiety symptoms), we graded the SOE of CFTSI as low given that significant effects were found in only a single study.

Table 13 Child and Family Traumatic Stress Intervention versus supportive comparison: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Berkowitz, et al., 2011^53^ | G1: CFTSI G2: Supportive intervention | Greater reduction of full and partial PTSD diagnoses and PTSD symptoms after trauma exposure PTSD symptoms TSCC Post-Traumatic Stress Index (range NR) Pretreatment G1: 53.30 (SD=1.34) G2: 51.74 (SD=1.29) Within-group change at post-treatment assessment: G1: -10.33 (calculated) G2: -5.62 (calculated) Within-group change at 3 months: G1: -13.56 (calculated) G2: -9.52 (calculated) Between-group change at post-treatment assessment: -4.71 (calculated) Between-group change at 3-month assessment: -4.04 (calculated) Repeated measures with mixed effect models: F=3.25, df=163, p=0.04 UCLA PTSD-RI Index for DSM-IV diagnosis at 3-month followup (range NR) Logistic regression model for full or partial diagnosis: Treatment variable OR (95% CI): 0.268 (0.10, 0.71), p<0.01 | Greater reduction in anxiety symptoms but no difference in between-group change in dissociation symptoms TSCC-Dissociation Index (range NR) Pretreatment G1: 47.64 (SD=1.12) G2: 48.23(SD=1.07) Within-group change at post-treatment assessment: G1: -5.38 (calculated) G2: -3.11 (calculated) Within-group change at 3 months: G1: -6.62 (calculated) G2: -4.69 (calculated) Between-group change at post-treatment assessment: -2.27(calculated) Between-group change at 3-month assessment: -1.95 (calculated) Repeated measures with mixed effect models: F=1.28, df=163, p=0.28 TSCC Anxiety Index (range not reported): Pretreatment G1: 51.34 (SD=1.33) G2: 50.45 (SD=1.29) Within-group change at post-treatment assessment: G1: -10.48 (calculated) G2: -4.96 (calculated) Within-group change at 3 months: G1: -11.70 (calculated) G2: -8.63 (calculated) Between-group change at post-treatment assessment: -5.52 (calculated) Between-group change at 3-month assessment: -3.07 (calculated) Repeated measures with mixed effect models: F=4.89, df=163, p=0.009 | NR | NR

CFTSI = Child and Family Traumatic Stress Intervention; CI = confidence interval; df = degrees of freedom; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; G = group; NR = not reported; OR = odds ratio; PTSD = post-traumatic stress disorder; SD = standard deviation; TSCC = Trauma Symptom Checklist for Children;UCLA PTSD-RI = University of California, Los Angeles Post-Traumatic Stress Disorder Reaction Index

Table 14 Strength of evidence for Key Question 1: Child and Family Traumatic Stress Intervention

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
CFTSI vs. supportive comparison53 | 1; 106 (106) | Full or partial PTSD diagnoses (PTSD-RI) | RCT Medium | Unknown | Direct | Precise | Treatment variable odds ratio (95% CI) of 0.268 (0.10, 0.71) for full or partial PTSD diagnosis (using PTSD-RI) at 3 months post-treatment Low
CFTSI vs. supportive comparison53 | 1; 106 (106) | Post-Traumatic stress symptoms (TSCC PTSD Index) | RCT Medium | Unknown | Direct | Precise | Difference of 4.71 points on the TSCC PTSD Index at post-treatment favoring CFTSI Low
CFTSI vs. supportive comparison53 | 1; 106 (106) | Dissociative symptoms (TSCC Dissociation Index) | RCT Medium | Unknown | Direct | Imprecise | No between-group difference in change in dissociative symptoms Insufficient
CFTSI vs. supportive comparison53 | 1; 106 (106) | Anxiety symptoms (TSCC Anxiety Index) | RCT Medium | Unknown | Direct | Precise | Difference of 5.52 points on the TSCC Anxiety Index at post-treatment favoring CFTSI Low

CFTSI = Child and Family Traumatic Stress Intervention; CI = confidence interval; PTSD = post-traumatic stress disorder; PTSD-RI = University of California, Los Angeles Posttraumatic Stress Disorder Reaction Index, Revised; RCT = randomized controlled trial; TSCC = Trauma Symptom Checklist for Children

### Key Question 1 School-Based Interventions

#### Description of Included Studies

We found three RCTs, each rated medium risk of bias, addressing two distinct school-based interventions for KQ 1. Two studies tested the efficacy of the ERASE (Enhancing Resiliency among Students Experiencing) Stress intervention,54,55 and the other tested the efficacy of the Overshadowing the Threat of Terrorism (OTT) intervention.56 Tables 15 and 16 present study characteristics, Tables 17 and 18 present results, and Table 19 presents SOE grades.

Table 15 ERASE Stress versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Berger, et al., 2009^54^ | Male and females students ages 9–15 years at a selected school in Sri Lanka whose parents/caregivers gave consent | Natural disasters (tsunami exposure in Sri Lanka) | Cluster RCT w/wait-list control 12 weekly sessions of 1.5 hours (18 hours total) | G1: Structured ERASE Stress Sri Lanka classroom-based program that incorporates psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments completed with a caregiver G2: Wait-list control that received religious classes | Randomized: G1: 84 G2: 82 Analyzed: G1: 84 G2: 82 | Medium
Gelkopf, et al., 2009^55^ | Male seventh- and eighth-grade students (mean age=13.09 years) at an all-male school in conflicted region of Israel whose parents signed a consent form | War/terror attacks in Israel | Cluster RCT w/wait-list control 12 weekly sessions of 1.5 hours | G1: Structured ERASE Stress classroom-based program that incorporates psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments completed with a caregiver G2: Wait-list control that received religious classes | Randomized: G1: 58 G2: 49 Analyzed: G1: 58 G2: 49 | Medium

ERASE Stress = Enhancing Resiliency Among Students Experiencing Stress; G = group; RCT = randomized controlled trial

Table 16 Overshadowing the Threat of Terrorism program versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Berger, et al., 2007^56^ | Male and female Israeli students in grades 2–6 in an area with high levels of terrorism-related trauma exposure whose parents signed consent forms | War/terror attacks in Israel | Cluster RCT with wait-list control 8 sessions lasting 90 minutes each | G1: Overshadowing the Threat of Terrorism classroom-based program that combines psychoeducational material and skills training with meditative practices, bio-energy exercises, art therapy, and narrative techniques for reprocessing traumatic experiences. G2: Wait-list control | Randomized: G1: 70 G2: 72 Analyzed: G1: 70 G2: 72 | Medium

G = group; RCT = randomized controlled trial

Table 17 ERASE Stress versus wait-list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Berger, et al., 2009^54^ | G1: Structured ERASE Stress Sri Lanka classroom-based program that incorporated psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments completed with a caregiver G2: Wait-list control that received religious classes | Greater reduction in PTSD probable DSM-IV diagnosis and PTSD severity (UCLA PTSD Index for DSM-IV PTSD, range=0–68) Diagnosis: Pretreatment G1: 28% (SD=33.3%) G2: 26% (SD=31.7%) Within-group change at post-treatment: G1: -27.3% (calculated) G2: -2.6% (calculated) Between-group change at post-treatment: -24.7% (calculated) Between-group chi-square: X2=14.02, df=2, p=0.001 Severity: Pretreatment G1: 44.94 (SD=8.7) G2: 47.23 (SD=7.2) Within-group change at post-treatment: G1: -8.73 (calculated) G2: -1.52 (calculated) Between-group change at post-treatment: -7.21 (calculated) Between-group ANOVA: F=53.52, df=1,164, p<0.001 | Greater reduction in depressive symptoms (Brief Beck Depression Inventory, range=0–21) Pretreatment G1: 4.44 (SD=3.2) G2: 4.04 (SD=3.3) Within-group change at post-treatment: G1: -1.89 (calculated) G2: -0.34 (calculated) Between-group change at post-treatment: -1.55 (calculated) Between-group ANOVA: F=22.55, df=1,164, p<0.001 | Greater reduction of somatic complaints (DPS), range=0–5) Pretreatment G1: 1.46 (SD=1.0) G2: 1.26 (SD=1.0) Within-group change at post-treatment: G1: -0.82 (calculated) G2: 0.19 (calculated) Between-group change at post-treatment: -1.01 (calculated) Between-group ANOVA: F=44.80, df=1,164, p<0.001 | Greater reduction in functional impairment (Seven items measuring school performance, social relationships, family relationships, and after-school activities from DPS), range=7–35) Pretreatment G1: 11.29 (SD=3.9) G2: 12.05 (SD=4.7) Within-group change at post-treatment: G1: -2.71 (calculated) G2: -0.26 (calculated) Between-group change at post-treatment: -2.45 (calculated) Between-group ANOVA: F=40.73, df=1,164, p<0.001
Gelkopf, et al., 2009^55^ | G1: Structured ERASE Stress classroom-based program that incorporated psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments completed with a caregiver G2: Wait-list control that received religious classes | Greater reduction of PTSD severity (UCLA PTSD Index for DSM-IV (Child version), range=0–68) Diagnosis: Pretreatment G1: 5.2% (calculated) G2: 0% (calculated) Within-group change at post-treatment: G1: -5.2% (calculated) G2: 6.1% (calculated) Between-group change at post-treatment: -11.3% (calculated) p not reported Severity: Pretreatment G1: 23.6 (SD=9.3) G2: 20.4 (SD=10.3) Within-group change at post-treatment: G1: -10.9 (calculated) G2: -1.9 (calculated) Between-group change at post-treatment: -9.0 (calculated) Between group ANOVA: F=49.42, df=1,106, p<0.001 | Greater reduction of depression symptoms (Brief Beck Depression Inventory, range=0–21) Pretreatment G1: 3.1 (SD=2.9) G2: 2.3 (SD=2.9) Within-group change at post-treatment: G1: -1.6 (calculated) G2: 0.2 (calculated) Between-group change at post-treatment: -1.8 (calculated) Between-group ANOVA: F=18.66, df=1,106, p<0.001 | Greater reduction of somatic complaints (Five items from DPS), range=0–5) Pretreatment G1: 2.1 (SD=1.3) G2: 1.9 (SD=1.2) Within-group change at post-treatment: G1: -1.0 (calculated) G2: Unknown based on data reporting error Between-group change at post-treatment: unknown based on data reporting error Between-group ANOVA: F=24.07, df=1,106, p<0.001 | Greater reduction in functional impairment (Seven items measuring school performance, social relationships, family relationships, and after-school activities from DPS), range=7–35) Pretreatment G1: 12.6 (SD=3.7) G2: 12.7 (SD=4.2) Within-group change at post-treatment: G1: -2.3 (calculated) G2: -0.3 (calculated) Between-group change at post-treatment: -2.0 (calculated) Between-group ANOVA: F=15.50, df=1,106, p<0.001

ANOVA = analysis of variance; df = degrees of freedom; DPS = DISC Predictive Scales; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; ERASE Stress – Enhancing Resilience among Students Experiencing Stress; G = group; PTSD = post-traumatic stress disorder; SD = standard deviation; UCLA PTSD-Symptom Severity = University of California, Los Angeles Posttraumatic Stress Disorder-Symptom Severity

Table 18 Overshadowing the Threat of Terrorism program versus wait-list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Berger, et al., 2007^56^ | G1: Overshadowing the Threat of Terrorism classroom-based program that combined psychoeducational material and skills training with meditative practices, bio-energy exercises, art therapy, and narrative techniques for reprocessing traumatic experiences. G2: Wait-list control | Greater reduction in PTSD symptoms and severity and unknown difference in between-group difference in change in proportion with PTSD diagnosis. (UCLA PTSD Index for DSM-IV PTSD Symptoms (range=0–17) and Severity (range=0–68)) Unknown between group difference in change in PTSD diagnosis (significance not reported) Diagnosis: Pretreatment G1: 8.6% (calculated) G2: 6.9% (calculated) Within-group change in proportion with PTSD at post-treatment G1: -8.6% (calculated) G2: 0% Between-group change in PTSD diagnosis proportion at post-treatment: -8.6% Significance not reported Severity: Pretreatment G1: 25.6 (SD=12.3) G2: 23.5 (SD=11.2) Within-group change at post-treatment: G1: -11.7 (calculated) G2: 0.4 (calculated) Between-group change at post-treatment: -12.1 (calculated) Between-group ANOVA: F=129.33, df=1,140, p<0.001 Symptoms: Pretreatment G1: 7.6 (SD=3.9) G2: 6.7 (SD=3.8) Within-group change at post-treatment: G1: -3.7 (calculated) G2: 0.9 (calculated) Between-group change at post-treatment: -4.6 (calculated) Between-group ANOVA: F=132.62, df=1,140, p<0.001 | Greater reduction in generalized and separation anxiety (SCARED Generalized Anxiety range=8–24, Separation Anxiety range=7–-21) Generalized anxiety: Pretreatment G1: 12.5 (SD=2.9) G2: 12.4 (SD=3.1) Within-group change at post-treatment: G1: -2.3 (calculated) G2: 0.5 (calculated) Between-group change at post-treatment: -2.8 (calculated) Between-group ANOVA: F=59.25, df=1,140, p<0.001 Separation anxiety: Pretreatment G1: 14.8 (SD=4.3) G2: 14.3 (SD=3.7) Within-group change at post-treatment: G1: -2.6 (calculated) G2: -0.2 (calculated) Between-group change at post-treatment: -2.4 (calculated) Between-group ANOVA: F=29.24, df=1,140, p<0.001 | Greater reduction of somatic complaints (DPS), range=0–6) Pretreatment G1: 2.1 (SD=1.7) G2: 1.9 (SD=1.6) Within-group change at post-treatment: G1: -1.0 (calculated) G2: 0.1 (calculated) Between-group change at post-treatment: -1.1 (calculated) Between-group ANOVA: F=40.44, df=1,140, p<0.001 | Greater reduction in functional impairment (Four items measuring school performance, social relationships, family relationships, and after-school activities from Childhood Diagnostic Interview Schedule, range=0–16) Pretreatment G1: 8.5 (SD=2.3) G2: 8.2 (SD=2.2) Within-group change at post-treatment: G1: -1.7 (calculated) G2: 0.1 (calculated) Between-group change at post-treatment: -1.8 (calculated) Between-group ANOVA: F=132.62, df=1,140, p<0.001

ANOVA = analysis of variance; df = degrees of freedom; DPS = DISC Predictive Scales; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; G = group; PTSD = post-traumatic stress disorder; SCARED = Screen for Child Anxiety Related Emotional Disorders; SD = standard deviation; UCLA PTSD-Symptom Severity = University of California, Los Angeles Posttraumatic Stress Disorder-Symptom Severity

Table 19 Strength of evidence for Key Question 1: school-based interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
ERASE Stress vs. wait-list control | 2; 273 (273) | PTSD diagnosis | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in proportion with PTSD diagnosis in ERASE Stress group in one study (24.7% greater decrease); second study significance not reported (11.3% greater decrease in proportion in ERASE Stress group) Low
ERASE Stress vs. wait-list control | 2; 273 (273) | PTSD severity | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in PTSD symptom severity in both studies (mean differences of 7.21, 9.0) Low
ERASE Stress vs. wait-list control | 2; 273 (273) | Depression symptoms | RCT Medium | Consistent | Direct | Precise | Significantly greater decrease in depression symptoms in both studies (mean differences of 1.55,1.8) Low
ERASE Stress vs. wait-list control | 2; 273 (273) | Somatic complaints | RCT Medium | Consistent | Direct | Precise | Significantly greater decrease in somatic complaints in both studies (mean differences of 1.01, unknown magnitude in second study) Low
ERASE Stress vs. wait-list control | 2; 273 (273) | Functional impairment | RCT Medium | Consistent | Direct | Precise | Significantly greater decrease in functional impairment in both studies (mean differences of 2.45, 2.0) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | PTSD symptoms | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in PTSD symptoms (mean difference of 4.6) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | PTSD severity | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in PTSD severity (mean difference of 12.1) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | PTSD diagnosis | RCT Medium | Unknown | Direct | Imprecise | Unknown difference in PTSD diagnosis reduction between baseline and followup between groups (difference in proportions of 8.6% favoring treatment group) Insufficient
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | Generalized anxiety symptoms | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in generalized anxiety symptoms (mean difference of 2.8) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | Separation anxiety symptoms | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in separation anxiety symptoms (mean difference of 2.4) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | Somatic complaints | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in somatic complaints (mean difference of 1.1) Low
Overshadowing the Threat of Terrorism vs. wait-list control | 1; 142 (142) | Functional impairment | RCT Medium | Unknown | Direct | Precise | Significantly greater decrease in functional impairment (mean difference of 1.8) Low

ERASE Stress = Enhancing Resiliency among Students Experiencing Stress; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

The first two trials focused on comparing participants in the ERASE Stress program and wait-list controls (Table 14).54,55 ERASE Stress is a classroom-based program that incorporates psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments completed with a caregiver (Table 15). Participants in the first study54 included 166 male and female students ages 9 to 15 years from 12 homeroom classes at a single school in Sri Lanka who had been exposed to a tsunami. All 12 teachers received three 8-hour training sessions on administering the ERASE Stress program. Six teachers delivered the intervention immediately, while the other six teachers delivered religious classes to the wait-list control group participants first, followed by the intervention. Teachers received weekly supervision by two local mental health professionals previously trained by the researchers to ensure program fidelity. Participants in the second study55 included 107 male seventh- and eighth-grade students (mean age=13.09 years) at an all-male school in a conflicted region of Israel who had been exposed to war and terror attacks. In this study, three teachers who delivered the intervention had three 90-minute supervision sessions with the author of the treatment manual to ensure consistency in applying the intervention. In addition, trainers who were familiar with the ERASE Stress program observed the teachers during the application phase and rated adherence to the manual in five areas using a 6-point Likert scale. Both ERASE Stress trials consisted of 12 sessions lasting 90 minutes each. The comparison group in both studies consisted of wait-list controls who received the intervention after the study concluded. Assessed outcomes included PTSD symptom severity via the UCLA PTSD Index for DSM-IV, depression symptoms via the Brief Beck Depression Inventory, somatic complaints via five items from the DISC Predictive Scales (DPS), and functional impairment via seven items from the DPS in both studies.54,55 The first trial54 also assessed changes in PTSD diagnosis from baseline to followup using the UCLA PTSD Index for DSM-IV. A categorical measure of probable PTSD was constructed by assessing whether the reported symptoms met the criteria required for a DSM-IV diagnosis. A score of at least 3 was necessary for an item to be considered both as a symptom criterion for probable PTSD and a distinct symptom of traumatic stress.

The third trial tested the efficacy of the OTT program (Table 16).56 OTT is a classroom-based program that combines psychoeducational material and skills training with meditative practices, bio-energy exercises, art therapy, and narrative techniques for reprocessing traumatic experiences. Participants included 142 male and female students in 10 classrooms of grades two through six in an area with high levels of terrorism in Israel. All 10 teachers participated in five 4-hour training sessions of the OTT course. Five teachers delivered the intervention, while the other five teachers had wait-list controls as students and thus did not apply the intervention during the study period. The five teachers immediately delivering the OTT program participated in three 3-hour supervisory sessions delivered by trainers to ensure fidelity of the protocol and monitor adherence. The trial consisted of eight sessions lasting 90 minutes each. The comparison group consisted of wait-list controls who received the intervention after the study concluded. The baseline and follow-up assessments occurred 1 week prior to the start of the intervention and 2 months after the end of the intervention, respectively. Assessments included PTSD symptoms, severity, and diagnosis after the study concluded. Assessed outcomes included PTSD symptom severity via the UCLA PTSD Index for DSM-IV, generalized anxiety and separation anxiety symptoms via the SCARED (Screen for Child Anxiety Related Emotional Disorders), somatic complaints via six items from the DPS, and functional impairment via four items from the Childhood Diagnostic Interview Schedule.

No study reported funding source.

The applicability of these interventions is limited to the specific populations recruited for each study. Although both ERASE Stress trials were conducted on approximately same-aged children, the first study findings54 apply only to students exposed to a tsunami in Sri Lanka, and the second study findings55 apply only to male students exposed to war/terror in Israel. The OTT trial56 findings apply only to male and female students in grades two through six exposed to war/terror in Israel.

#### Key Points

We found three studies that tested two school-based interventions that addressed KQ 1.

##### ERASE Stress Versus Wait-List Control

- PTSD severity: Participants in the ERASE Stress group had significantly greater decreases in PTSD symptom severity than wait-list group participants between baseline and follow-up assessments in both studies (low SOE54,55).
- PTSD diagnosis: Participants in the ERASE Stress group had significantly greater decreases in PTSD diagnosis in one study54 than wait-list group participants. The statistical significance of the comparison between ERASE Stress group participants and wait-list control participants was unknown in the second study55 (low SOE).
- Depression symptoms: Participants in the ERASE Stress group had significantly greater decreases in depression symptoms than wait-list controls between baseline and follow-up assessments in both studies54,55 (low SOE).
- Somatic complaints: Participants in the ERASE Stress group had significantly greater decreases in somatic complaints than wait-list controls in one study.54 The differences in the second study are reported as significant, but the magnitude of the difference is unknown because of a data reporting error in the publication55 (low SOE).
- Functional impairment: Participants in the ERASE Stress group had significantly greater decreases in functional impairment than wait-list controls between baseline and follow-up assessments in both studies (low SOE).

##### Overshadowing the Threat of Terrorism Versus Wait-List Control, Study Characteristics

- PTSD symptoms: Participants in the OTT group had significantly greater reduction in PTSD symptoms between baseline and followup than wait-list control participants (low SOE).
- PTSD severity: Participants in the OTT group had significantly greater reduction in PTSD severity between baseline and followup than wait-list control participants (low SOE).
- PTSD diagnosis: The statistical significance of the comparison of reduction in PTSD diagnosis between OTT and wait-list group participants is not reported (insufficient SOE).
- Generalized anxiety symptoms: Participants in the OTT group had significantly greater reduction in generalized anxiety symptoms between baseline and followup than wait-list control participants (low SOE).
- Separation anxiety symptoms: Participants in the OTT group had significantly greater reduction in separation anxiety between baseline and followup than wait-list control participants (low SOE).
- Somatic complaints: Participants in the OTT group had significantly greater reduction in somatic complaints between baseline and followup than wait-list control participants (low SOE).
- Functional impairment: Participants in the OTT group had significantly greater reduction in functional impairment between baseline and followup than wait-list control participants (low SOE).

#### Detailed Synthesis

##### ERASE Stress Versus Wait-List Control

Both ERASE trials found that the ERASE Stress arm had significantly greater decreases in PTSD symptom severity (Table 17), significantly greater decreases in depressive symptoms, significantly greater decreases in somatic complaints, and significantly greater decreases in functional impairment. The proportion of participants who lost their PTSD diagnosis between baseline and follow-up assessments was significantly greater in the ERASE Stress group than the wait-list control group in the first study,54 while the significance was not reported in the second study.55 We graded the SOE as low for PTSD severity, depressive symptoms, somatic complaints, and functional impairment given that only two studies met inclusion criteria and both reported imprecise estimates (Table 17).

##### Overshadowing the Threat of Terrorism Versus Wait-List Control, Study Characteristics

The OTT arm had significantly greater decreases in PTSD symptoms, significantly greater decreases in PTSD severity, significantly greater decreases in generalized anxiety symptoms, significantly greater decreases in separation anxiety symptoms, significantly greater decreases in somatic complaints, and significantly greater decreases in functional impairment than wait-list controls (Table 18). The significance in the decrease in the proportion of participants with PTSD diagnosis at baseline versus followup is not reported. We found insufficient evidence of OTT having an effect on PTSD diagnosis given that only one study met study criteria and the significance of the effect size was not reported; thus, we graded the SOE as insufficient (Table 19). For all other outcomes (PTSD symptoms and severity, separation anxiety and generalized anxiety symptoms, somatic complaints, and functional impairment), we graded the SOE of OTT as low, given that significant effects were found in only a single study.

### Key Question 1 Early Psychological Intervention

#### Description of Included Studies

We found one RCT50 rated medium risk of bias, testing an early psychological intervention.

This study recruited children ages 7 to 16 years from a university hospital in Switzerland who received medical treatment after a road traffic accident (collision). Children and at least one of their parents were contacted within a week after the accident to participate. Inclusion criteria additionally necessitated German fluency, no severe head injury, and no previous evidence of intellectual impairment according to medical records. No children were on psychotropic medicine or other mental health treatment. The program was delivered around 10 days following the collision. The manualized intervention included reconstruction of the accident using drawings and accident-related toys, and psychoeducation. The brief intervention itself consisted of four steps, lasting a total of about 30 minutes, and was delivered to the child and at least one parent.

Follow-up data were collected at 2 months and 6 months after the accident. Assessments were done using a standardized, 30- to 45-minute interview conducted by trained psychologists at the hospital or in the child's home. Mothers completed questionnaire assessments at the same time. Medical variables were obtained from medical records and responsible physicians.

Standardized instruments were used to assess acute stress disorder (ASD), PTSD (the German version of the CAPS-CA), depressive symptoms (using the German version of the Child Depression Inventory [CDI]) and behavioral problems.

See Table 20 for study characteristics.

Table 20 Early psychological intervention versus usual care: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Number | Risk of Bias
Zehnder, 2010^50^ | Children ages 6–17 from Switzerland | Injury (road traffic accidents) | RCT One 30-minute session | G1: Early psychological intervention G2: Usual care | Randomized: G1: 51 G2: 50 Analyzed: 2 months: G1: 50 G2: 50 6 months: G1: 49 G2: 50 | Medium

G = group; RCT = randomized controlled trial

This study was funded by grants from the Foundation Mercator (Switzerland).

This study is applicable to school-aged children who received treatment in a hospital for a road traffic accident (collision).

#### Key Points

- PTSD symptoms: Participants in early psychological intervention group had no difference in changes in PTSD symptoms pre- to post-treatment than those in usual care in a single RCT50 (insufficient SOE).
- Depression symptoms: Participants in early psychological intervention group had no difference in changes in depressive symptoms pre- to post-treatment than those in usual care in a single RCT50 (insufficient SOE).
- Behavioral problems: Participants in early psychological intervention group had no difference in changes in behavioral problems pre- to post-treatment than those in usual care in a single RCT50 (insufficient SOE).

#### Detailed Synthesis

One RCT50 found no significant differences in changes in PTSD symptoms, depressive symptoms, or behavioral problems between pretreatment and post-treatment among children receiving the intervention compared with those receiving usual care (Table 21). We graded the SOE as insufficient because of imprecise evidence from a single study (Table 22).

Table 21 Early psychological intervention versus usual care: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Zehnder, 2010^50^ | G1: Early psychological intervention G2: Usual care | No between-group difference in changes in PTSD symptoms (IBS-K: range not reported) Pretreatment: G1: 29.3 (SD=23.7) G2: 26.3 (SD=23.0) Within-group change at Time 1: G1: -7.7 (calculated) G2: -7.8 (calculated) Between-group change at Time 1: 0.1 (calculated) Within-group change at Time 2: G1: -5.7 (calculated) G2: -4.4; (calculated) Between-group change at Time 2: -1.3 (calculated) Repeated measures ANOVA treatment by time interaction: F=0.10, p=NS | No between-group difference in anxiety, depression, or anger symptoms (DIKJ: range not reported) Pretreatment: G1: 10.1 (SD=6.0) G2: 9.6 (SD=6.5) Within-group change at Time 1: G1: -1.9 (calculated) G2: -1.0 (calculated) Between-group change at Time 1: -0.9 (calculated) Within-group change at Time 2: G1: -1.0 (calculated) G2: -0.9 (calculated) Between-group change at Time 2: -0.1 (calculated) Repeated measures ANOVA treatment*time interaction: F=0.01, p=NS | NR | No between-group difference in behavioral problems (CBCL: range not reported) CBCL-German version, Mean Pretreatment: G1: 53.4 (SD=9.3) G2: 50.6 (SD=9.1) Within-group change at Time 1: G1: -3.4 (calculated) G2: -0.6 (calculated) Between-group change at Time 1: -2.8 (calculated) Within-group change at Time 2: G1: -2.6 (calculated) G2: -1.8 (calculated) Between-group change at Time 2: -0.8 (calculated) Repeated measures ANOVA treatment*time interaction: F=0.01, p=NS

ANOVA = analysis of variance; CBCL = Child Behavior Checklist; DIKJ = German Version of Child Depression Inventory; G = group; IBS-K = German Version of Clinician-Administered Post-Traumatic Stress Disorder Scale for children and adolescents; NR = not reported; NS = not sufficient; PTSD = post-traumatic stress disorder; SD = standard deviation

Table 22 Early psychological intervention versus usual care: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Early psychological intervention | 1; 101 (99) | PTSD symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference in change in PTSD symptoms Insufficient
Early psychological intervention | 1; 101 (99) | Depression symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant change in depression symptoms Insufficient
Early psychological intervention | 1; 101 (99) | Behavioral problems | RCT Medium | Unknown | Direct | Imprecise | No statistically significant change in behavioral problems Insufficient

PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 1 Beta-Blocker Medication

#### Description of Included Studies

Authors found one study conducted to evaluate beta-blocker medication's effect targeting children exposed to trauma. We rated this study as having a low risk of bias.

The study recruited children ages 10 to 18 years who had been involved in multiple types of accidents, presented to an emergency room with injury in the United States, and were screened to have a high risk of developing PTSD. The population was recruited based on exposure to trauma but were all found to be “at risk” of developing PTSD at screening. Study participants were screened and enrolled in an emergency department in the midwestern United States. Medication was administered during admissions and as outpatients for 10 days. Children were excluded if they had a Glasgow Coma Scale less than 14 or if medical conditions contraindicated propranolol. The study evaluated the intervention of 10 days of propranolol medication after an accident with followups 2 and 6 weeks after the accident to assess for PTSD symptoms and physiologic variables. Propranolol is a central-acting beta-blocker that has been shown to decrease memory consolidation in emotionally distressing situation and physiologic reactivity after trauma. Ten days of propranolol was chosen because previous studies72 had shown efficacy with 10 days of propranolol in adults immediately following trauma. The study used 10 days of liquid placebo as a comparator so that participants and providers could both be blinded to study condition. Other aspects of medical treatment and evaluation were no different between groups. The study did comment on recruitment and adherence to the study protocol and followup. Investigators assessed participants and administered the intervention within 12 hours postadmission for 10 days following the accident. Subjects, providers, and evaluators were blinded to experimental or control status. Study characteristics are presented in Table 23.

Table 23 Beta-blocker medication intervention versus placebo: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Nugent, et al, 2010^57^ | Male and female children ages 10–18 at high risk of developing PTSD presenting to an emergency room in the United States with injury | Accidents (multiple types) | Parallel RCT 10 days of medication with 2- and 6-week followup | G1: Propranolol G2: Placebo | Randomized G1: 14 G2: 15 Analyzed G1: 12 G2: 14 | Low

G = group; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

The applicability of the study was limited to the participants recruited to the study. Only 2 out of 29 subjects were nonwhite. Accidents included in the study were motor vehicle accidents, bicycle accidents, falls, and miscellaneous. Four participants had had a family member die, 9 had a chronic psychiatric diagnosis, and 8 had had previous trauma. Apart from the racial makeup of patients, the study could be applied to children who had been seen for accidents in the emergency room.

#### Key Points

We found one study that tested beta-blocker medication that addressed KQ 1.

- PTSD diagnosis and symptoms: No differences between groups were found for changes in PTSD diagnosis or symptoms.57 We rated the SOE as insufficient for the efficacy of beta-blocker medication to decrease PTSD diagnosis and symptoms based on the conclusion of one study with imprecise estimates.
- Physiologic reactivity: No differences between groups were found for changes in heart rate reactivity.57 We rated the SOE as insufficient for the efficacy of propranolol to reduce the physiologic reactivity to trauma triggers based on the results of a single study.

#### Detailed Synthesis

One RCT57 found no statistically significant difference in physiologic reactivity by study arms (Table 24). We graded the SOE as insufficient for both PTSD diagnosis, symptoms, and physiologic reactivity outcomes given that only one study met inclusion criteria and owing to lack of precision in the estimates of effect (Table 25).

Table 24 Beta-blocker medication intervention versus placebo: results

Author, Year | Comparison Groups | Traumatic Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Nugent, et al., 2010^57^ | G1: Propanolol liquid medication (20 mg/5 mL) at 2.5 mg/kg dosing split twice daily with a 5-day taper and maximum daily dosage of 40 mg twice daily for a total of 10 days. G2: Liquid placebo twice daily for 10 days. | No between-group difference in changes in difference in proportion of those with PTSD diagnosis or changes in PTSD symptoms (CAPS-CA; range not reported) Diagnosis: No data reported for PTSD diagnosis other than x2<1; p=NS for G1 vs. G2 at post-treatment Symptoms: No means reported. Between-group differences at followup not reported. Intent-to-treat linear regression predicting PTSD symptoms at post-treatment, adjusted for sex, age, and prior trauma PTSD severity, showed treatment group OR (95% CI)=1.32 (0.84, 2.08) (calculated^*^) | NR | No between-group difference in heart rate during or after trauma narrative p=NS. No other data given | NR

CAPS-CA = Clinician-Administered Posttraumatic Stress Disorder Scale for Children and Adolescents; CI = confidence interval; G= group; kg = kilogram; mg = milligram; mL = milliliter; NR = not reported; NS = not sufficient; OR = odds ratio; PTSD = post-traumatic stress disorder

* Calculation is an estimation based on reported unstandardized coefficient and standard error and calculated standard deviation of the treatment group variable, assuming no correlation with other variables in the multivariate model.

Table 25 Strength of evidence for Key Question 1: beta-blocker medication

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Propranolol vs. placebo medication | 1; 29 (20) | PTSD diagnosis | RCT Low | Unknown | Direct | Imprecise | No greater difference in proportion with change in PTSD diagnosis at post-treatment. Insufficient
Propranolol vs. placebo medication | 1; 29 (20) | PTSD symptoms | RCT Low | Unknown | Direct | Imprecise | No greater difference in PTSD symptoms at post-treatment. Insufficient
Propranolol vs. placebo medication | 1; 29 (20) | Physiologic reactivity | RCT Low | Unknown | Direct | Imprecise | No greater difference in heart rate reactivity to traumatic triggers. Insufficient

PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

## Key Question 2 Interventions Targeting Children Exposed to Trauma and Already Having Symptoms

### Key Question 2 Trauma-Focused Cognitive Behavioral Therapy

#### Description of Included Studies

We found one RCT58 comparing trauma-focused cognitive behavioral therapy (TF-CBT) to wait-list control for the treatment of PTSD in children. This study was rated as having a low risk of bias. In an RCT conducted by Smith,58 24 children ages 8 to 18 years and meeting DSM-IV criteria for PTSD after a single-incident traumatic event (motor vehicle accident, interpersonal violence, witnessing of violence) were randomly assigned, after a 4-week symptom-monitoring baseline period, to 10 weeks of TF-CBT (N=12) or placement on a wait list (N=12) for 10 weeks. Participants were recruited from an outpatient mental health trauma clinic in London. The study outcomes were PTSD symptomatology as measured by the self-report Child Post Traumatic Stress Scale (CPSS), the self-report Children's Revised Impact of Event Scale (C-RIES), and the Clinician Administered PTSD Scale (CAPS); anxiety symptoms as measured by the Revised Children's Manifest Anxiety Scale (RCMAS); and depressive symptoms as measured by the Depression Self-Rating Scale (DSRS). The applicability of this intervention is limited to the specific populations recruited. The TF-CBT intervention is applicable to male and female outpatients ages 8 to 18 years presenting for treatment in an outpatient mental health clinic.58 Study characteristics are presented in Table 26.

Table 26 Trauma-focused cognitive behavioral therapy versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Smith, 2007^58^ | Male and female children ages 8–18, PTSD relating to a single traumatic event, fluent in English | Mixed: MVA, assault, witnessed violence | RCT with wait-list control 10 weekly sessions | G1: CBT G2: Wait-list control | Randomized: G1: 12 G2:12 Analyzed: G1:12 G2:12 | Low

CBT = cognitive behavioral therapy; G = group; MVA=motor vehicle accident; PTSD = post-traumatic stress disorder; RCT=randomized clinical trial

#### Key Points

- PTSD severity: Participants in the TF-CBT intervention58 demonstrated significantly less PTSD symptomatology compared with wait-list control (low SOE).
- PTSD diagnoses: At post-treatment, a significantly greater number of TF-CBT participants were free of diagnosis compared with the wait-list control (low SOE).
- Anxiety: Participants in the TF-CBT group scored lower than the wait-list control group on anxiety measures (low SOE).
- Depression: Participants in the TF-CBT group scored lower than the wait-list control group on depression measures (low SOE).

#### Detailed Synthesis

One RCT58 evaluated the efficacy of TF-CBT compared with the wait-list control group in 24 male and female children 8 to 18 years old, presenting to an outpatient community mental health clinic in London (Table 27). Following the TF-CBT intervention, participants rated themselves lower than the wait-list participants on PTSD symptomatology on the CPSS, C-RIES, and CAPS. Participants who participated in the TF-CBT intervention were found to have lower ratings on the CPSS, the C-RIES, and the clinician-administered CAPS score. Participants in the TF-CBT group also scored lower than the wait-list participants on measures of anxiety as assessed by the RCMAS and depression on the DSRS. Eleven of 12 of the children receiving TF-CBT were free of PTSD diagnosis post-treatment, whereas only 5 of 12 children improved in the wait-list group. The first group was reassessed 6 months later. All 12 of the TF-CBT group had lost their PTSD diagnosis at followup and were significantly improved on measures of PTSD (CPSS, RIES, CAPS-CA), and associated depression and anxiety symptoms remained improved. We graded the SOE as low for outcomes with significant differences in outcomes between groups (PTSD diagnosis and symptoms and depression and anxiety symptoms), given that only one study met inclusion criteria (Table 28).

Table 27 Trauma-focused cognitive behavioral therapy versus wait-list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Smith, 2007^58^ | G1: TF-CBT G2: Inactive control | Greater reduction in proportion with PTSD diagnosis and symptoms of PTSD PTSD diagnosis: ADIS-C/P (range of scale not reported) Pretreatment G1: 100% G2: 100% Within-group change in proportions at post-treatment: G1: -92% G2: -42% Between-group change in proportions at post-treatment: -50% (calculated) X^2^=6.8, df=1, 24, p<0.01 PTSD symptoms: CPSS (range of scale not reported) Pretreatment G1: 28.1 (SD=8.8) G2: 28.3 (SD=10.5) Within-group change at post-treatment: G1: -25.1 (calculated) G2: -3.05 (calculated) Between-group change at post-treatment: -22.05 (calculated) MANCOVA F=48.3, df=1,18, p<0.001 C-RIES (range of scale not reported) Pretreatment G1: 47.5 (SD=11.5) G2: 41.6 (SD=11.7) Within-group change at post-treatment: G1: -39.0 (calculated) G2: -6.3 (calculated) Between-group change at post-treatment: -32.7 (calculated) MANCOVA F=36.8, df=1,18, p<0.001 CAPS-CA (range of scale not reported) Pretreatment G1: 60.9 (SD=9.6) G2: 54.7 (SD=14.6) Within-group change at post-treatment: G1: -48.9 (calculated) G2: -14.4 (calculated) Between-group change at post-treatment: -34.5 (calculated) MANCOVA F=20.2, df=1,18, p<0.005 | Greater reduction of symptoms of depression DSRS (range of scale not reported) Pretreatment G1: 18.3 (SD=5.2) G2: 13.9 (SD=5.6) Within-group change at post-treatment: G1: -10.3 (calculated) G2: -0.6 (calculated) Between-group change at post-treatment: -9.7 (calculated) MANCOVA F=19.1, df=1,18, p<0.001 Greater reduction of symptoms of anxiety RCMAS (range of scale not reported) Pretreatment G1: 19.8 (SD=5.6) G2: 16.3 (SD=5.7) Within-group change at post-treatment: G1: -12.4 (calculated) G2: 0.2 (calculated) Between-group change at post-treatment: -12.6 (calculated) MANCOVA F=14.3, df=1,18, p<0.005 | NR | NR

ADIS-C/P = Anxiety Disorders Interview Schedule; CAPS-CA = Clinician-Administered PTSD Scale for Children and Adolescents; CPSS = Child Post-Traumatic Stress Disorder Symptom Scale; C-RIES = Children's Revised Impact of Event Scale; df = degrees of freedom; DSRS = Depression Self-Rating Scale; G = group; MANCOVA = multivariate analysis of covariance; NR = not reported; PTSD = post-traumatic stress disorder; RCMAS = Revised Children's Manifest Anxiety Scale; SD = standard deviation; TF-CBT = trauma-focused cognitive behavioral therapy

Table 28 Strength of evidence for Key Question 2: trauma-focused cognitive behavioral therapy

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TF-CBT vs. wait-list control58 | 1; 38 (38) | PTSD symptoms | RCT Low | Unknown | Direct | Precise | Cohen effect size 2.48 on CPSS scale favoring TF-CBT Low
TF-CBT vs. wait-list control58 | 1; 38 (38) | PTSD symptoms | RCT Low | Unknown | Direct | Precise | Cohen effect size 2.20 on the C-RIES scale favoring TF-CBT Low
TF-CBT vs. wait-list control58 | 1:38 (38) | PTSD symptoms | RCT Low | Unknown | Direct | Precise | Cohen effect size 1.59 on the clinician-administered CAPS-CA scale favoring TF-CBT Low
TF-CBT vs. wait-list control58 | 1; 38 (38) | PTSD diagnosis | RCT Low | Unknown | Direct | Precise | Difference in proportion with PTSD diagnosis of 50% favoring TF‐CBT Low
TF-CBT vs. wait-list control58 | 1; 38 (38) | Anxiety | RCT Low | Unknown | Direct | Precise | Difference of 12.6 points on the RCMAS favoring TF‐CBT Low
TF-CBT vs. wait-list control58 | 1; 38 (38) | Depression | RCT Low | Unknown | Direct | Precise | Difference of 9.7 points on the DSRS favoring TF-CBT Low

CAPS-CA = Clinician-Administered Post-Traumatic Stress Disorder Scale for Children and Adolescents; CPSS = Child Post-Traumatic Stress Disorder Symptom Scale; C-RIES = Children's Revised Impact of Event Scale; DSRS = Depression Self-Rating Scale; PTSD = post-traumatic stress disorder; RCMAS = Revised Children's Manifest Anxiety Scale; RCT = randomized controlled trial; TF-CBT = trauma-focused cognitive behavioral therapy

### Key Question 2 Cognitive Behavioral Intervention for Trauma in Schools

#### Description of Included Studies

We found two RCTs47,64 comparing Cognitive Behavioral Intervention for Trauma in Schools (CBITS) to wait-list controls for the treatment of children exposed to trauma and already experiencing symptoms, both rated as having a medium risk of bias. One RCT64 was conducted in the schools with sixth-grade students in Los Angeles exposed to violence and with clinical symptoms of PTSD.64 Sixty-one 11-year-old students were randomly assigned to a 10-session cognitive behavioral therapy (CBT) early intervention group, and 65 students were assigned to a wait-list delayed intervention comparison group. The study outcomes were child-reported symptoms of PTSD (CPSS) and depression (CDI), parent-reported psychosocial dysfunction (Pediatric Symptom Checklist [PSC]), and teacher-reported classroom problems using the Teacher-Child Rating Scale. This study was funded by the National Institute of Mental Health, Substance Abuse and Mental Health Services Administration, Centers for Disease Control and Prevention, Robert Wood Johnson Foundation Clinical Scholar Program, and Los Angeles Unified School District.

The second RCT47 was a small pilot study (n=78) conducted to evaluate the Support for Students Exposed to Trauma (SSET) intervention, which has the same core cognitive behavioral elements as CBITS. The sample included predominantly Latino (88%) and African-American (12%) middle school students (sixth through eighth grades) from Los Angeles (mean age=11.5 years) who experienced violence in the past year and had current PTSD symptoms Thirty-nine middle school students were randomly assigned to 10 45-minute weekly SSET sessions, based on CBITS, and 39 students were assigned to a wait-list delayed intervention comparison group. The study outcomes were child-reported symptoms of PTSD (CPSS) and depression (CDI), and both parent-reported and teacher-reported problem behaviors as indicated by the Strength and Difficulties Questionnaire (SDQ). This study was funded by the National Institute of Mental Health.

The applicability of these interventions is limited to the specific populations recruited. Both trials were limited to male and female sixth-grade inner city, minority children exposed to violence. Study characteristics are presented in Table 29.

Table 29 Cognitive Behavioral Intervention for Trauma in Schools versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Stein, 2003^64^ | Male and female sixth-grade students, average age 11 years | Community violence | RCT with wait-list control 10 weekly sessions | G1: CBITS G2: Wait-list control | Randomized: G1: 61 G2: 65 Analyzed: G1:54 G2:63 | Medium
Jaycox, 2009^47^ | Male and female sixth to eighth grade students, average age 11.5 years | Community violence | RCT with wait-list control 10 weekly sessions | G1: SSET (CBITS) G2: Wait-list control | Randomized: G1: 39 G2: 39 Analyzed: G1: 39 G2: 37 | Medium

CBITS = Cognitive Behavioral Intervention for Trauma in Schools; G = group; RCT = randomized clinical trial; SSET = Support for Students Exposed to Trauma

#### Key Points

- PTSD severity: Participants in the CBITS intervention reported significantly lower symptoms of PTSD following intervention than wait-list control participants in one study and nonsignificant differences in the other study (low SOE).
- Depression: Participants in the CBITS intervention reported significantly lower levels of depression following intervention compared with wait-list control participants (low SOE).
- Psychosocial dysfunction: Parents of participants in the CBITS intervention group reported significantly less psychosocial dysfunction following intervention compared with parents of students in the wait-list control group (low SOE).
- Acting out behaviors: No differences in teacher-reported classroom acting out behavior in participants following CBITS intervention compared with wait-list controls (insufficient SOE).
- Shyness/anxiousness: No differences in teacher-reported shyness/anxiety in participants following CBITS intervention compared with wait-list controls (insufficient SOE).
- Learning problems: No differences in teacher-reported learning problems in participants following CBITS intervention compared with wait-list controls (insufficient SOE).
- Problem behaviors (parent-rated): No differences in parent-reported problem behaviors in participants following CBITS intervention compared with wait-list controls (insufficient SOE).
- Problem behaviors (teacher-rated): No differences in teacher-reported problem behaviors in participants following CBITS intervention compared with wait-list controls (insufficient SOE).

#### Detailed Synthesis

Two RCTs47,64 evaluated a CBITS intervention versus wait-list control in groups of Los Angeles middle school students (Table 30). At the conclusion of the intervention, children had lower scores on symptoms of PTSD as measured by the CPSS in one study but nonsignificant differences in the other. We graded the SOE for CBITS on PTSD symptoms as insufficient given the discrepant findings. We did find that CBITS was associated with greater decreases in depression as measured by the CDI in both studies and psychosocial dysfunction on the PSC in one study. Thus, we graded the SOE as low for depression and psychosocial dysfunction because these studies concluded significant differences between groups. There were no differences found for teacher-reported classroom problems in acting out, shyness/anxiousness, and learning in one study and on parent- and teacher-reported problem behaviors in the other study. For these outcomes with nonsignificant differences between groups, we graded the SOE as insufficient because only one study met inclusion criteria for each of these outcomes (Table 31).

Table 30 Cognitive Behavioral Intervention for Trauma in Schools versus wait-list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Stein, 2003^64^ | G1: CBITS G2: WL control | Greater reduction in symptoms of PTSD CPSS (range 0–51) Pretreatment G1: 24.5 (6.8) G2: 23.5 (7.2) Within-group change: G1: -15.6 (calculated) G2: -8.0 (calculated) Adjusted between-group change (95% CI): -7.0 (-10.8 to -3.2) | Greater reduction in symptoms of depression CDI (range 0–52) Pretreatment G1: 17.6 (10.8) G2: 16.7 (7.3) Within-group change: G1: -8.2 (calculated) G2: -4.0 (calculated) Adjusted between-group change (95% CI): -3.4 (-6.5 to -0.4) | NR | Greater reduction in (parent-reported) psychosocial dysfunction PSC (range 0–70) Pretreatment G1: 19.1 (9.4) G2: 16.2 (8.1) Within-group change: G1: -6.6 (calculated) G2: 0.3 (calculated) Adjusted between-group change (95% CI): -6.4 (-10.4 to -2.3) No differences between groups in (teacher reported) changes in learning problems, acting out behaviors, or anxiety Learning Problems: TCRS (subscale range 6–30) Learning Problems: Pretreatment G1: 13.8 (7.3) G2: 12.7 (7.0) Within-group change: G1: -1.1 (calculated) G2: 0.6 (calculated) Adjusted between-group change (95% CI): -1.1 (-2.9 to 0.8) Shyness/anxiousness scale: TCRS (subscale range 6–30) Pretreatment G1: 10.2 (4.1) G2: 11.0 (5.1) Within-group change: G1: -0.4 (calculated) G2: -0.4 (calculated) Adjusted between-group change (95% CI): 0.1 (-1.5 to 1.7) Acting out problems scale: TCRS (subscale range 6–30) Pretreatment G1: 11.3 (7.0) G2: 10.6 (5.5) Within-group change: G1: -1.9 (calculated) G2: -0.4 (calculated) Adjusted between group change (95% CI): -1.0 (-2.5 to 0.5)
Jaycox, 2009 47 | G1: SSET (CBITS) G2: WL control | No significant between-group changes in PTSD symptoms CPSS (range=NR) Pretreatment: G1: 17.46 (SD=10.37) G2: 19.41 (SD=10.00) Within-group change at post-treatment: G1: -3.74 (calculated); d=-0.39 G2: -1.09 (calculated); d=-0.16 Between group change at post-treatment: -2.65 (calculated); d (difference)= -0.23; regression estimate for followup controlling for baseline=0.58, t= -1.89, p=0.058; fixed effects model adjusted for school and group leader found that estimates “remained stable” | Greater reduction in symptoms of depression CDI (range=NR) Pretreatment: G1: 13.87 (SD=8.52) G2: 14.32 (SD=9.20) Within-group change at post-treatment: G1: -2.10 (calculated); d=-0.25 G2: 0.60 (calculated); d= 0.07 Between group change at post-treatment: -2.70 (calculated); d (difference)= -0.32; regression estimate of followup controlling for baseline=0.65, t=-1.99, p=0.046; fixed effects model adjusted for school and group leader found that estimates “remained stable” | NR | No significant between-group changes in parent-rated problem behaviors SDQ (range=NR) Pretreatment: G1: 11.64 (SD=5.80) G2: 12.46 (SD=5.90) Within-group change at post-treatment: G1: -1.92 (calculated); d=-0.39 G2: -1.16 (calculated); d=-0.28 Between-group difference at post-treatment: -0.76 (calculated); d (difference)=-0.10; regression estimate for followup controlling for baseline NR, t=-0.19, p=NS No significant between-group changes in teacher-rated problem behaviors SDQ (range=NR) Pretreatment: G1: 11.33 (SD=7.87) G2: 8.59 (SD=7.37) Within-group change at post-treatment: G1: -1.05 (calculated); d=0.006 G2: 0.71 (calculated); d=0.28 Between-group difference at postttreatment assessment: -0.34 (calculated); d (difference)=-0.28; regression estimate for followup controlling for baseline NR, t=-1.22, p=NS

CBITS = Cognitive Behavioral Intervention for Trauma in Schools; CDI = Child Depression Inventory; CI = confidence interval; CPSS = Child Post-Traumatic Stress Disorder Symptom Scale; d = effect size; G = group; NR = not reported; NS = not sufficient; PSC = Pediatric Symptom Checklist; PTSD = post-traumatic stress disorder; SD = standard deviation; SDQ = Strengths and Difficulties Questionnaire; SSET = Support for Students Exposed to Trauma; TCRS = Teacher Child Rating Scale; WL = wait list

Table 31 Strength of evidence for Key Question 2 psychotherapy: Cognitive Behavioral Intervention for Trauma in Schools

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
CBITS vs. wait-list control64 | 2; 204 (202) | PTSD symptoms | RCT Medium | Inconsistent | Direct | Imprecise | Difference of 7 points on CPSS favoring CBITS in one study; no difference in changes in PTSD symptoms in the other study Insufficient
CBITS vs. wait-list control64 | 2; 204 (202) | Depression symptoms | RCT Medium | Consistent | Direct | Precise | Difference of 3.4 and 2.7 points on CDI favoring CBITS in both studies, respectively Low
CBITS vs. wait-list control64 | 1; 126 (126) | Psychosocial dysfunction (parent -reported) | RCT Medium | Unknown | Indirect | Precise | Difference of 6.4 points on parent-rated PSC favoring CBITS Low
CBITS vs. wait-list control64 | 1; 126 (126) | Acting out behaviors in classroom (teacher reported) | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference in change in acting out behaviors subscale on Teacher Child Rating Scale Insufficient
CBITS vs. wait-list control64 | 1; 126 (126) | Shyness / anxiety (teacher reported) | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference in change in shyness/anxiety subscale on Teacher Child Rating Scale Insufficient
CBITS vs. wait-list control64 | 1; 126 (126) | Learning problems (teacher reported) | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference in change in learning problems subscale on Teacher Child Rating Scale
CBITS vs. wait-list control64 | 1; 78 (76) | Problem behaviors (parent reported) | RCT Medium | Unknown | Indirect | Imprecise | No statistically significant difference in change in parent-reported problem behaviors
CBITS vs. wait-list control64 | 1; 78 (76) | Problem behaviors (teacher reported) | RCT Medium | Unknown | Indirect | Imprecise | No statistically significant difference in change in teacher-reported problem behaviors

CBITS = Cognitive Behavioral Intervention for Trauma in Schools; CDI = Child Depression Inventory; CPSS = Child Post-Traumatic Stress Disorder Symptom Scale; PSC = Pediatric Symptom Checklist; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 Cognitive Processing Therapy

#### Description of Included Studies

We found one RCT59 that compared cognitive processing therapy (CPT) to wait-list control. One RCT conducted by Ahrens59 evaluated the efficacy of CPT on self-reported symptoms of trauma in a population of incarcerated males. Participants were incarcerated males ages 15 to 18 years identified as meeting the DSM-IV criteria for PTSD. They were randomly assigned to 8 sessions of CPT (N=19) or wait-list (N=19) control. The CPT treatment included psychoeducation about PTSD and exposure and cognitive restructuring strategies, including creating a narrative describing the trauma. Eleven of the youth had experienced multiple traumas, and 12 of the youth reported having seen someone they knew die, often in gang violence. Twenty of the youth reported having experienced a head injury that had led to a loss of consciousness. Outcomes were measured using the PTSD Symptom Scale-Self-Report (PSS-SR), the Impact of Events Scale (IES), and the Beck Depression Inventory. The funding source was not reported. The applicability of this intervention is limited to the specific populations recruited. The CPT trial59 is limited to male incarcerated youth ages 15 to 18 years old. Study characteristics are presented in Table 32.

Table 32 Cognitive processing therapy versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Ahrens, 2001^59^ | Incarcerated males ages 15–18 | Mixed | RCT with wait-list control 8 weekly 1‐hour sessions | G1: CPT G2: Wait-list control | Randomized: N=38 G1: 19 G2: 19 Analyzed: G1: NR G2: NR | Medium

CPT = Cognitive Processing Therapy; G = group; N = number; NR = not reported; RCT = randomized clinical trial

#### Key Points

- PTSD severity: Incarcerated male youth reported significantly fewer symptoms of PTSD after CPT treatment compared with wait-list controls (low SOE).
- Depression: Incarcerated male youth reported significantly lower levels of depression after CPT treatment compared with wait-list controls (low SOE).

#### Detailed Synthesis

One RCT59 evaluated the efficacy of CPT on self-reported symptoms of trauma in a population of incarcerated males with PTSD ages 15 to 18 years (Table 33). Following treatment with CPT, the participants reported significantly fewer symptoms of PTSD as measured by the PSS-SR and the IES and lower levels of depression. We graded the SOE as low for outcomes with significant differences in outcomes between groups (PTSD and depression symptoms), given that only one study met the inclusion criteria (Table 34).

Table 33 Cognitive processing therapy versus wait-list control: Results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Ahrens, 2002^59^ | G1: CPT G2: WL control | Greater reduction in PTSD symptoms PSS-SR (17 items, range of scale not reported) Pretreatment G1: 16.89 (SD=10.49) G2: 19.36 (SD=10.12) Within-group change: G1: -9.07 (calculated) G2: 1.02 (calculated) Between-group change: -10.09 (calculated) ANOVA (1, 36)=19.44, p=0.0001 IES (15 items, range of scale not reported): Pretreatment G1: 35.52 (SD=11.80) G2: 33.42 (SD=8.70) Within-group change: G1: -12.11 (calculated) G2: 2.08 (calculated) Between-group change: -14.19 (calculated) ANOVA (1, 36)=20.49, p=0.0001 | Greater reduction in depression symptoms BDI (21 items, range of scale not reported Pretreatment G1: 15.26 (SD=12.10) G2: 18.52 (SD=9.97) Within-group change: G1: -8.38 (calculated) G2: -0.58 (calculated) Between-group change (95% CI): -7.80 (calculated) ANOVA (1, 36)=17.95, p=0.02 | NR | NR

ANOVA = analysis of variance; BDI = Beck Depression Inventory; CPT = cognitive processing therapy; G = group; IES = Impact of Events Scale; NR = not reported; PTSD = post-traumatic stress disorder; PSS-SR = Post-Traumatic stress disorder Symptom Scale Self-Report; SD = standard deviation; WL = wait list

Table 34 Strength of evidence for Key Question 2: cognitive processing therapy

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
CPT vs. wait-list control59 | 1; 38 (38) | PTSD symptoms | RCT Medium | Unknown | Direct | Precise | Difference of 10.09 points on PSS-SR scale favoring CPT Low Difference of 14.19 on IES favoring CPT Low
CPT vs. wait-list control59 | 1; 38 (38) | Depression | RCT Medium | Unknown | Direct | Precise | Difference of 7.8 points on BDI scale favoring CPT Low

BDI = Beck Depression Inventory; CPT = cognitive processing therapy; IES = Impact of Events Scale; PSS-SR = Post-Traumatic Stress Disorder Symptom Scale Self-Report; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 Interventions to Treat Child Post-Traumatic Stress Symptoms: Narrative Exposure Therapy

#### Description of Included Studies

We found one RCT, rated medium risk of bias,60 comparing exposure therapy and meditation-relaxation therapy in children exposed to civil war and natural disaster.

This study identified 31 children ages 8 to 14 years old living at a refugee camp in Sri Lanka with a preliminary diagnosis of PTSD. Children were identified with potential PTSD (n=71) from an epidemiologic survey and excluded if they failed to meet diagnostic criteria for PTSD. Other exclusion criteria included mental retardation, neurologic disorder, and psychosis. No children were excluded for these reasons. The study took place 3 weeks after a tsunami that severely affected the region. Interventions included narrative exposure therapy for children (KIDNET) and active comparison of meditation-relaxation therapy (MED-RELAX) with 16 and 15 children in each treatment protocol, respectively. Children in both arms participated in 6 sessions of 60 to 90 minutes each. Outcome interviews were conducted 6 months after treatment. Observed outcomes included the University of California-Los Angeles (UCLA) PTSD Index for DSM-IV (UPID) and 2 project-derived 5-item scales of areas of functional impairment (e.g., social relationships, family life, and general life satisfaction), and physical problems or somatic complains (e.g., headache, stomach ache, fever, vomiting, and diarrhea). All treatment and interviews were conducted in 2 provisional refugee camps. See Table 35 for study characteristics.

Table 35 Narrative exposure therapy versus meditation-relaxation therapy: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Catani, et al., 2009^60^ | Male and female refugees ages 8–14 from villages destroyed by tsunami 3 weeks earlier | Natural disasters | RCT with active control Six sessions over 2 weeks 60–90 minutes duration | Meditation-relaxation therapy | Randomized: G1: 16 G2: 15 Analyzed: G1: 16 G2: 14 | Low

G = group; RCT = randomized controlled trial

The research was supported by funding from Deutsche Forschungsgemeinschaft (German Research Foundation) and the “Ein Herz für Kinder” foundation.

This study includes two efficient treatment protocols that may be effective in treating PTSD in resource-poor settings affected by natural disaster and/or civil war-related violence.

#### Key Points

- PTSD diagnosis: Participants in the KIDNET (narrative exposure therapy) group did not have significantly different improvements in PTSD diagnoses at 1- or 6-month followups than participants in the MED-RELAX (active comparison) group (insufficient evidence).
- Post-traumatic stress symptoms: Participants in the KIDNET (narrative exposure therapy) group did not have significantly different improvements in PTSD symptoms at 1- or 6-month followups than participants in the MED-RELAX (active comparison) group (insufficient evidence).
- Physical symptoms: Participants in the KIDNET (narrative exposure therapy) group did not have significantly different improvements in physical symptoms at 1- or 6-month followups than participants in the MED-RELAX (active comparison) group (insufficient evidence).
- Functioning problems: Participants in the KIDNET (narrative exposure therapy) group did not have significantly different improvements in functioning problems 1- or 6-month followups than participants in the MED-RELAX (active comparison) group (insufficient evidence).

#### Detailed Synthesis

One RCT60 found no statistically significant difference in PTSD symptoms or diagnosis by study arm. Both narrative exposure therapy versus meditation-relaxation therapy treatments demonstrated large reductions in PTSD severity and diagnosis as well as smaller decreases in physical symptoms and functional impairments; however, the comparison between narrative exposure therapy and active control showed no significant differences (Table 36). We graded the SOE as insufficient because of the lack of statistical significance in a single study with few subjects (Table 37).

Table 36 Narrative exposure therapy versus meditation-relaxation therapy: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Catani et al., 2009^60^ | G1: Narrative exposure therapy G2: Meditation-relaxation therapy | No between group differences in change in PTSD symptoms UCLA PTSD-I for DSM-IV (score 0–80) Pretreatment G1: 37.94 (SD=14.8) G2: 36.58 (SD=14.9) Within-group change at post-treatment assessment: G1: -25.53 (calculated) G2: -23.99 (calculated) Within-group change at 6 months: G1: -26.63 (calculated) G2: -26.83 (calculated) Between-group change at post-treatment assessment: -1.54 (calculated) Between-group change at 6-month assessment: 0.20 (calculated) Repeated measures ANOVA for Time × Treatment interaction p=0.9 No between-group differences in change in proportion with PTSD diagnosis UCLA PTSD-I for DSM-IV Pretreatment G1: 100% G2: 100% Within-group change in proportion at post-treatment assessment: G1: -75% G2: -66.6% Within-group change in proportion at 6 months: G1: -81.3% G2: -71.4% Between-group change at post-treatment assessment: 8.4% (calculated) Chi-square difference p=NS Between-group change at 6 month assessment: -9.9% Chi-square difference p=NS | NR | No between group differences in change in number of physical symptoms Five questions about specific somatic complaints in last 4 weeks. Pretreatment G1: 1.75 (SD=1.34) G2: 1.80 (SD=1.26) Within-group change at post-treatment assessment: G1: -0.25 (calculated) G2: -1.13 (calculated) Within-group change at 6 months: G1: -0.25 (calculated) G2: -0.51 (calculated) Between-group change at post-treatment assessment: 0.88 (calculated) Repeated measures ANOVA for Time × Treatment interaction p=NS Between-group change at 6-month assessment: 0.26 (calculated) Repeated measures ANOVA for Time × Treatment interaction p=NS | No between group differences in change in number of functioning problems Five questions related to problems in functioning in different areas of children's life Pretreatment G1: 2.06 (SD=1.34) G2: 2.14 (SD=1.17) Within-group change at post-treatment assessment: G1: -1.56 (calculated) G2: -1.34 (calculated) Within-group change at 6 months: G1: -1.62 (calculated) G2: -1.43 (calculated) Between-group change at post-treatment assessment: -0.22 (calculated) Repeated measures ANOVA for Time × Treatment interaction p=NS Between-group change at 6-month assessment: -0.19 (calculated) Repeated measures ANOVA for Time × Treatment interaction p=NS

ANOVA = analysis of variance; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; G = group; NR = not reported; NS = not sufficient; PTSD = post-traumatic stress disorder; SD = standard deviation; UCLA = University of California, Los Angeles Post-Traumatic Stress Disorder Index

Table 37 Strength of evidence for narrative exposure therapy

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Narrative exposure therapy | 1; 31 (30) | PTSD diagnosis | RCT Low | Unknown | Direct | Imprecise | Insufficient
Narrative exposure therapy | 1; 31 (30) | PTSD symptoms | RCT Low | Unknown | Direct | Imprecise | Insufficient
Narrative exposure therapy | 1; 31 (30) | Physical symptoms | RCT Low | Unknown | Direct | Imprecise | Insufficient
Narrative exposure therapy | 1; 31 (30) | Functional symptoms | RCT Low | Unknown | Direct | Imprecise | Insufficient

PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 Grief- and Trauma-Focused Interventions

#### Description of Included Studies

We found one RCT, rated medium risk of bias,61 addressing grief- and trauma-focused interventions. This study compared group and individual interventions.61

This study identified 56 children ages 7 to 12 years 4 months after exposure to Hurricane Katrina enrolled at a single elementary school. The subjects had to be identified from a single school as having experienced loss of home or loved one and experiencing at least moderate levels of post-traumatic stress symptoms. Children were excluded if they were less than 1 month from loss, actively suicidal, or considered inappropriate for group therapy. The study compared individual with group trauma- and grief-focused therapy. The interventions used a manualized approach incorporating CBT and narrative exposure therapy. Each arm was designed with 10 1-hour weekly sessions and one parent meeting. Outcome measures included the PTSD symptom scores (UCLA PTSD Index), depressive symptoms (MFQ-C—Mood & Feelings Questionnaire), traumatic grief (Traumatic Grief Subscale of the UCLA Grief Inventory Revised), and global distress (single project-derived item). These outcomes did not vary by intervention group. The outcomes were assessed at the end of the intervention and at followup, which occurred an average of 20 days post-treatment. The treatment was delivered in the school. See Table 38 for study characteristics.

Table 38 Individual versus group grief- and trauma-focused intervention: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Salloum, et al., 2008^61^ | Male and female students ages 7–12 in a New Orleans school, at least 1 month post loss (loved one/home), moderate symptoms | Natural disasters | RCT with active control 10 weekly 1‐hour sessions (10 hours total) | G1: Individual grief- and trauma-focused intervention G2: Group grief- and trauma-focused intervention | G1: 23 G2: 22 Analyzed: G1: 18 G2: 16 | Medium

G = group; RCT = randomized controlled trial

This study was funded by the Institute of Mental Hygiene, New Orleans, Louisiana.

This study is applicable to children in school settings with loss of loved one or home by natural disaster who are experiencing moderate levels of post-traumatic stress symptoms.

#### Key Points

- Post-traumatic stress symptoms: Participants in the individual therapy group did not have significantly different improvements in PTSD symptoms at the 20-day followup than participants in the group intervention (insufficient evidence).
- Depressive symptoms: Participants in the individual therapy group did not have significantly different improvements in depressive symptoms at the 20-day followup than participants in the group intervention (insufficient evidence).

#### Detailed Synthesis

One RCT61 found no statistically significant difference in PTSD symptoms or depressive symptoms by study arm (Table 39). Both individual and group grief- and trauma-focused intervention treatments demonstrated large reductions in PTSD severity and depressive symptoms. We graded the SOE as insufficient because of the lack of statistical significance in a single study with few subjects (Table 40).

Table 39 Individual versus group grief- and trauma-focused intervention: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Salloum, 2008^61^ | G1: Group grief- and trauma-focused intervention G2: Individual grief- and trauma-focused intervention | No between-group differences in change in PTSD symptom (UCLA PTSD –I for DSM-IV Child version, range 0–80) Pretreatment G1: 44.03 (SD=13.03) G2: 42.32 (SD=9.58) Post-treatment G1: 28.28 (SD=13.61) G2: 31.32 (SD=12.43) Within-group change at post-treatment assessment: G1: -15.75 (calculated) G2: -11.00 (calculated) Within-group change in proportion at 20 day followup: G1: -21.60 (calculated) G2: -20.47 (calculated) Between-group change at post-treatment assessment: -4.75 (calculated) Intent-to-treat analyses effect size: 0.95 Between-group change at 6-month assessment: -1.13 (calculated) Intent-to-treat analyses effect size: 1.34 General linear modeling repeated measure procedure time × treatment interaction p=NS | No between-group differences in change in of depression symptoms (Mood and Feelings Questionnaire) Pretreatment G1: 25.48 (SD=9.17) G2: 23.41 (SD=9.58) Within-group change at post-treatment assessment: G1: -8.57 (calculated) G2: -2.95 (calculated) Within-group change in proportion at 20-day followup: G1: -12.48 (calculated) G2: -9.18 (calculated) Between-group change at post-treatment assessment: -5.62 (calculated) Intent-to-treat analyses effect size: 0.47 Between-group change at 6-month assessment: -3.30 (calculated) Intent-to-treat analyses effect size: 0.92 General linear modeling repeated measure procedure time × treatment interaction p=NS | NR | NR

DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; G = group; NR = not reported; NS = not significant; PTSD = post-traumatic stress disorder; SD = standard deviation; UCLA PTSD-I = University of California, Los Angeles Posttraumatic Stress Disorder Index

Table 40 Individual versus group grief- and trauma-focused intervention: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Individual grief- and trauma-focused intervention | 1; 55 (44) | Posttraumatic stress symptoms | RCT Medium | Unknown | Direct | Imprecise | Insufficient
Individual grief- and trauma-focused intervention | 1; 55 (44) | Depressive symptoms | RCT Medium | Unknown | Direct | Imprecise | Insufficient

RCT = randomized controlled trial

### Key Question 2 Grief and Trauma Intervention with Coping Skills and Trauma Narrative Processing

#### Description of Included Studies

We found one RCT,62 rated low risk of bias, testing a grief and trauma intervention with trauma narrative processing (GTI-CN) versus a grief and trauma intervention with coping skills only (GTI-C).

This study randomized 72 6- to 12-year-old (mean age=9.6 years) male and female African-American students from 4 schools with exposure to multiple traumas, including Hurricane Katrina 3 years prior and Hurricane Gustav during study recruitment. Inclusion criteria were parental consent and child assent; enrolled in the second through sixth grade; exposure to violence, hurricane-related exposure, or exposure to death; and at least moderate levels of PTSD symptoms as determined by a score of 25 or greater on the UCLA-PTSD-I. Exclusion criteria were suicidal ideation as determined by the MFQ-C and deemed clinically inappropriate for group participation by evaluator. The intervention consisted of 12 50- to 60-minute group sessions of GTI-CN or GTI-C for 10 weeks, one individual session, and one parent session (Table 41).

Table 41 Grief and trauma intervention with coping skills and trauma narrative processing versus grief and trauma intervention with coping skills: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Number | Risk of Bias
Salloum, 2012^62^ | Second–sixth grade male and female African-American students | Mixed, multiple | RCT 12 50-minute weekly sessions | G1: GTI-CN G2: GTI-C | Randomized: G1: 39 G2: 33 Analyzed: Post-treatment: G1: 34 G2: 32 3-month followup: G1: 34 G2: 30 12-month followup: G1: 34 G2: 30 | Low

G = group; GTI-C = Grief and Trauma Intervention with coping skills; GTI-CN = Grief and Trauma Intervention with coping skills and trauma narrative processing; RCT = randomized controlled trial

Follow-up data were collected from assessments of students and parent interviews (for behavioral problems) at post-treatment and at 3 and 12 months postintervention. Outcomes assessed included traumatic stress symptoms and clinically significant PTSD syndrome (at 12 months only) as determined by the UCLA PTSD-I (12 months), depression symptoms and clinically significant syndrome (at 12 months only) as assessed with the MFQ-C, traumatic grief assessed with the Extended Grief Inventory (EGI), distress on the Global Distress (GD) scale, and internalizing and externalizing behavior problems as reported by parents about their children via the CBCL.

This study was funded by the Institute of Mental Hygiene (New Orleans, LA), Fahs-Beck Fund for Research and Experimentation, and the University of South Florida Internal Awards Program.

This study is applicable to second- through sixth-grade African-American students with multiple trauma exposures (including natural disasters) with at least moderate levels of PTSD symptoms.

#### Key Points

- PTSD symptoms and clinically significant PTSD: Participants in the GTI-CN group had no difference in changes in clinically significant PTSD or in PTSD symptoms pre- to post-treatment than those in the GTI-C group in a single RCT62 (insufficient SOE).
- Depression symptoms and clinically significant depression: Participants in the GTI-CN group had no difference in changes in clinically significant depression or in depressive symptoms pre- to post-treatment than those in the GTI-C group in a single RCT62 (insufficient SOE).
- Traumatic grief: Participants in the GTI-CN group had no difference in changes in traumatic grief symptoms pre- to post-treatment than those in the GTI-C group in a single RCT62 (insufficient SOE).
- Global distress: Participants in the GTI-CN group had no difference in changes in global distress pre- to post-treatment than those in the GTI-C group in a single RCT62 (insufficient SOE).
- Internalizing symptoms and clinically significant internalizing behavioral problems: Participants in the GTI-CN group had no difference in changes in clinically significant parent-reported internalizing problem behaviors or in internalizing symptoms pre- to post-treatment than those in the GTI-C group in a single RCT62 (insufficient SOE).
- Externalizing behavioral problems: The difference in clinically significant parent-reported externalizing problem behavior was not reported, nor was the significance of the between-group comparison of change in pre- to post-treatment externalizing symptoms between those in the GTI-CN and the GTI-C group in a single RCT.62 Although the intent-to-treat (ITT) between-group comparison showed a greater decrease in symptoms in the GTI-CN group compared with the GTI-C group, the magnitude of the changes was not consistent across follow-up periods. The non-ITT analyses were not reported, yet the ITT analyses were only reported for externalizing symptoms (insufficient SOE).

#### Detailed Synthesis

One RCT62 found no significant differences between GTI-CN and GTI-C in changes in PTSD symptoms or clinically significant PTSD, depression symptoms or clinically significant depression, traumatic grief, global distress, parent-reported internalizing symptoms or clinically significant internalizing behavior problems, or parent-reported externalizing symptoms among African-American second through sixth graders from New Orleans who had multiple types of trauma exposures, most of whom had been through Hurricane Katrina (Table 42). We graded the SOE as insufficient because of imprecise evidence from a single study (Table 43).

Table 42 Grief and trauma intervention with coping skills and trauma narrative processing versus grief and trauma intervention with coping skills: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Salloum, 2012^62^ | | No between-group difference in changes in clinically significant PTSD or PTSD symptoms (UCLA PTSD-I: range not reported) [underlined: UCLA PTSD-I of 38+ (clinically significant PTSD)] Pretreatment: G1: 46.2% G2: 39.4% Within-group change at 12 months: G1: -40.3% G2: -29.4% Between-group change at 12 months: -10.9%, p=NR [underlined: UCLA PTSD-I, mean] Pretreatment: G1: 46.82 (SD=13.00) G2: 42.80 (SD=10.77) Within-group change at post-treatment: G1: -15.64, d=0.92, p=NR G2: -15.23, d=0.78, p=NR Between-group change at post-treatment: -0.41, p=NR Within-group change at 3 months: G1: -16.94, d=1.06, p=NR G2: -16.50, d=0.78, p=NR Between-group change at 3 months: -0.44, p=NR Within-group change at 12 months: G1: -22.08, d=1.83, p=NR (RCI, 70.59% improved, 2.94% deteriorated) G2: -17.27, d=1.50, p=NR (RCI, 60% improved, 3.33% deteriorated) Between-group change at 12 months: -4.81, ANOVA time*treatment interaction p=NS; RCI difference p=NS | No between-group difference in changes in clinically significant depression or depressive symptoms (MFQ-C: range not reported) [underlined: MFQ-C of 29+ (clinically significant depression)] Pretreatment: G1: 43.6% G2: 27.3% Within-group change at 12 months: G1: -43.6% G2: -20.8% Between-group change at 12 months: -22.8%, p=NR [underlined: MFQ-C, mean] Pretreatment: G1: 27.62 (SD=10.18) G2: 22.83 (SD=8.65) Within-group change at post-treatment: G1: -9.12, d=0.91, p=NR G2: -9.00, d=0.99, p=NR Between-group change at post-treatment: -0.12, p=NR Within-group change at 3 months: G1: -9.18, d=0.87, p=NR G2: -8.00, d=0.85, p=NR Between-group change at 3 months: -1.18, p=NR Within-group change at 12 months: G1: -13.94, d=1.43, p=NR (RCI, 52.9% improved, 0% deteriorated) G2: -9.00, d=0.97, p=NR (RCI, 43.33% improved, 3.33% deteriorated) Between-group change at 12 months: -4.94, ANOVA time*treatment interaction p=NS; RCI difference p=NS No between-group difference in traumatic grief (EGI, range not reported) Pretreatment: G1: 53.03 (SD=17.75) G2: 46.00 (SD=21.83) Within-group change at post-treatment: G1: -16.90, d=0.92, p=NR G2: -16.69, d=0.78, p=NR Between-group change at post-treatment: -0.39, p=NR Within-group change at 3 months: G1: -19.62, d=0.96, p=NR G2: -16.62, d=1.18, p=NR Between-group change at 3 months: -3.00, p=NR Within-group change at 12 months: G1: -26.72, d=1.61, p=NR (RCI, 68.75% improved, 0% deteriorated) G2: -19.00, d=0.91, p=NR (RCI, 55.17% improved, 3.45% deteriorated) Between-group change at 12 months: -7.72, ANOVA time*treatment interaction p=NS; RCI difference p=NS No between-group difference in general distress (GD, range not reported) Pretreatment: G1: 2.71 (SD=1.32) G2: 2.72 (SD=1.13) Within-group change at post-treatment: G1: -0.80, d=0.60, p=NR G2: -1.03, d=0.86, p=NR Between-group change at post-treatment: 0.23, p=NR Within-group change at 3 months: G1: -1.36, d=1.06, p=NR G2: -1.34, d=0.78, p=NR Between-group change at 3 months: -0.02, p=NR Within-group change at 12 months: G1: -1.53, d=1.19, p=NR G2: -1.24, d=1.06, p=NR Between-group change at 12 months: -0.29, ANOVA time*treatment interaction p=NS | NR | No between-group difference in changes in clinically significant parent-reported internalizing problem behavior or internalizing symptoms (CBCL: range not reported) [underlined: CBCL t-score of 63+ (clinically significant parent-reported internalizing problem behavior)] Pretreatment: G1: 20.5% G2: 12.1% Within group change at 12 months: G1: -14.6% G2: 1.2% Between-group change at 12 months: -15.8%, p=NR [underlined: CBCL, parent-reported internalizing symptoms, mean] Pretreatment: G1: 9.50 (SD=7.33) G2: 8.76 (SD=5.69) Within-group change at post-treatment: NR Between-group change at post-treatment: NR Within-group change at 3 months: G1: -2.00, d=0.29, p=NR G2: -1.33, d=0.21, p=NR Between-group change at 3 months: -0.67, p=NR Within-group change at 12 months: G1: -3.61 , d=0.58, p=NR (RCI, 17.86% improved, 0% deteriorated) G2: -1.52, d=0.26, p=NR (RCI, 14.29% improved, 4.76% deteriorated) Between-group change at 12 months: -2.09, ANOVA time*treatment interaction p=NS; RCI difference p=NS Unknown significance of between-group difference in changes in parent-reported externalizing symptoms; ITT analysis shows significant greater reduction CBCL, parent-reported externalizing symptoms, mean Pretreatment: G1: 12.39 (SD=7.49) G2: 10.05 (SD=8.73) Within-group change at post-treatment: NR Between-group change at post-treatment: NR Within-group change at 3 months: G1: 0.97, d=0.12, p=NR G2: 0.05, d=0.006, p=NR Between-group change at 3 months: 0.92, p=NR Within-group change at 12 months: G1: -2.78, d=0.35, p=NR G2: 0.57, d=0.06, p=NR Between-group change at 12 months: -2.21, ANOVA time × treatment interaction using ITT analysis: F(2,108)=3.81, p=0.026

ANOVA = analysis of variance; CBCL = Child Behavior Checklist; d = effect size; EGI = Extended Grief Inventory; GD = general distress; GTI-C = Grief and Trauma Intervention with coping skills; GTI-CN = Grief and Trauma Intervention with coping skills and trauma narrative processing; ITT = intent to treat; MFQ-C = Mood and Feelings Questionnaire–Child Version; NR = not reported; NS = not sufficient; PTSD = post-traumatic stress disorder; RCI = Reliable Change Index; SD = standard deviation; UCLA PTSD-I = University of California, Los Angeles Posttraumatic Stress Disorder Index

Table 43 Grief and trauma intervention with coping skills and trauma narrative processing versus grief and trauma intervention with coping skills: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
GTI-CN | 1; 72 (64) | Clinically significant PTSD | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in clinically significant PTSD Insufficient
GTI-CN | 1; 72 (64) | PTSD symptoms | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in PTSD symptoms Insufficient
GTI-CN | 1; 72 (64) | Clinically significant depression | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in clinically significant depression Insufficient
GTI-CN | 1; 72 (64) | Depressive symptoms | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in depressive symptoms Insufficient
GTI-CN | 1; 72 (64) | Traumatic grief | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in traumatic grief Insufficient
GTI-CN | 1; 72 (64) | Traumatic grief | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in traumatic grief Insufficient
GTI-CN | 1; 72 (64) | Global distress | RCT Low | Unknown | Direct | Imprecise | No statistically significant difference in change in global distress Insufficient
GTI-CN | 1; 72 (64) | Clinically significant internalizing problem behavior | RCT Low | Unknown | Indirect | Imprecise | No statistically significant difference in change parent-rated clinically significant internalizing problem behaviors
GTI-CN | 1; 72 (64) | Internalizing symptoms | RCT Low | Unknown | Indirect | Imprecise | No statistically significant difference in change in parent-rated internalizing symptoms Insufficient
GTI-CN | 1; 72 (64) | Externalizing symptoms | RCT Low | Unknown | Indirect | Imprecise | No statistically significant difference in change in parent-rated externalizing symptoms Insufficient

GTI-CN = Grief and Trauma Intervention with coping skills and trauma narrative processing; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 Emotion Regulation Therapy

#### Description of Included Studies

We found one RCT49 rated medium risk of bias, testing an emotion regulation therapy, Trauma Affect Regulation: Guide for Education and Therapy (TARGET), versus an enhanced treatment-as-usual (ETAU) relational supportive therapy.

This study recruited 59 delinquent girls, ages 13 to 17 years, with exposure to multiple trauma types who met criteria for full or partial PTSD. The inclusion criteria were self-reported delinquency determined by National Delinquency Study criteria and full or partial PTSD in past month as determined by CAPS-CA structured diagnostic interview. Exclusion criteria included substantial cognitive impairment determined by scores <16 on Orientation, Attention, and Recall sections of the Mini Mental State Exam; on 1-to-1 suicide watch; under age 13 or over age 18. The intervention consisted of 12 50-minute weekly TARGET sessions or ETAU sessions for the treatment and control groups, respectively.

Follow-up data were collected at post-treatment. Assessments were done using a standardized, interview using the CAPS-CA to assess full (criteria B, C, and D) and partial PTSD diagnosis (criterion B and one but not both of criteria C and D) as well as PTSD symptom severity (total score). The Trauma Symptom Checklist for Children (TSCC) was used to assess depression, anxiety, and anger.

See Table 44 for study characteristics.

Table 44 Emotion regulation therapy versus relational supportive therapy: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Number | Risk of Bias
Ford, 2012^49^ | Delinquent females ages 13–17 | Mixed, multiple | RCT 12 50-minute weekly sessions | G1: TARGET (emotion regulation therapy) G2: ETAU (relational supportive therapy) | Randomized: G1: 33 G2: 26 Analyzed: G1: 26 G2: 20 | Medium

ETAU = enhanced treatment as usual; G = group; RCT = randomized controlled trial; TARGET = Trauma Affect Regulation: Guide for Education and Therapy

This study was funded by the Department of Justice, Office of Juvenile Justice and Delinquency Programs.

This study is applicable to adolescent females ages 13 to 17 living in a residential facility with multiple trauma exposures and full or partial PTSD.

#### Key Points

- PTSD symptoms: Participants in the TARGET (emotion regulation therapy) group had no difference in changes in PTSD symptoms pre- to post-treatment than those in the ETAU (relational supportive therapy) group in a single RCT49 (insufficient SOE).
- Anxiety symptoms: Participants in the TARGET (emotion regulation therapy) group had no difference in changes in anxiety symptoms pre- to post-treatment than those in the ETAU (relational supportive therapy) group in a single RCT49 (insufficient SOE). Participants in the early psychological intervention group had no difference in changes in depressive symptoms pre- to post-treatment than those in usual care in a single RCT49 (insufficient SOE).
- Depression symptoms: Participants in the TARGET (emotion regulation therapy) group had no difference in changes in depression symptoms pre- to post-treatment than those in the ETAU (relational supportive therapy) group in a single RCT49 (insufficient SOE).
- Anger symptoms: Participants in the TARGET (emotion regulation therapy) group had no difference in changes in anger symptoms pre- to post-treatment than those in the ETAU (relational supportive therapy) group in a single RCT49 (insufficient SOE).

#### Detailed Synthesis

One RCT49 found no significant differences in changes in PTSD symptoms, anxiety symptoms, depression symptoms, or anger symptoms between pretreatment and post-treatment among adolescent girls ages 13 to 17 living in a residential facility, comparing those who received TARGET (emotion regulation therapy) with those who received ETAU (relational supportive therapy (Table 45). We graded the SOE as insufficient because of imprecise evidence from a single study (Table 46).

Table 45 Emotion regulation therapy versus relational supportive therapy: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Ford, 2012^49^ | G1: TARGET G2: ETAU | No between-group difference in changes in PTSD symptoms (CAPS-CA: range not reported) [underlined: CAPS-CA, subscale B] Symptoms, Mean Pretreatment: G1: 19.4 (SD=9.2) G2: 13.3 (SD=3.8) Within-group change at post-treatment: G1: -8.7 (SD=8.6) d=1.01 G2: -4.6 (SD=4.8) d=0.95 Between-group change at post-treatment: -4.1 (SD=6.4); 95% CI (calculated) -0.22, 8.42; d=0.64 [underlined: CAPS-CA, subscale C] Symptoms, Mean Pretreatment: G1: 22.5 (SD=8.0) G2: 18.8 (SD=5.9) Within-group change at post-treatment: G1: -8.5 (SD=8.2) d=1.04 G2: -4.9 (SD=6.6) d=0.75 Between-group change at post-treatment: -3.5 (SD=8.4); 95% CI (calculated) -0.93, 8.13; d=0.42 [underlined: CAPS-CA, subscale D] Symptoms, Mean Pretreatment: G1: 17.4 (SD=8.2) G2: 15.4 (SD=6.3) Within-group change at post-treatment: G1: -7.4 (SD=7.4) d=0.99 G2: -7.4 (SD=6.1) d=1.23 Between-group change at post-treatment: 0.02 (SD=7.5); 95% CI (calculated) -4.12, 4.12; d=0.00 [underlined: CAPS-CA, Total] Score: Mean Pretreatment: G1: 58.9 (SD=20.7) G2: 47.5 (SD=10.6) Within-group change at post-treatment: G1: -24.4 (SD=19.5) d=1.26 G2: -17.0 (SD=12.6) d=1.35 Between-group change at post-treatment: -7.4 (SD=14.1); 95% CI (calculated) -16.96, 2.16; d=0.53 PTCI, Mean Pretreatment: G1: 108.2 (SD=32) G2: 104.6 (SD=33) Within group change at post-treatment: G1: -17.9 (SD=33.6) d=0.53 G2: -10.6 (SD=33.4) d=0.32 Between group change at post-treatment: 7.2 (SD=34.3); 95% CI (calculated) -12.79, 27.39; d=0.21 | No between-group difference in anxiety, depression, or anger symptoms (TSCC: range not reported) [underlined: TSCC, Anxiety] Mean, Pretreatment: G1: 7.2 (SD=3.6) G2: 6.8 (SD=4.5) Within-group change at post-treatment: G1: -2.4 (SD=3.9) d=0.61 G2: -1.3 (SD=4.7) d=0.27 Between-group change at post-treatment: -1.2 (SD=3.6); 95% CI (calculated) -1.46, 3.66; d=0.32 [underlined: TSCC, Depression] Mean, Pretreatment: G1: 7.4 (SD=3.7) G2: 6.9 (SD=4.1) Within-group change at post-treatment: G1: -2.3 (SD=3.6) d=0.65 G2: -2.6 (SD=4.0) d=0.65 Between-group change at post-treatment: 0.3 (SD=3.6); 95% CI (calculated) -2.56, 1.96; d=-0.10 [underlined: TSCC, Anger] Mean, Pretreatment: G1: 8.8 (SD=7.1) G2: 8.3 (SD=6.0) Within-group change at post-treatment: G1: -1.0 (SD=7.4) d=0.13 G2: -2.5 (SD=5.4) d=0.46 Between-group change at post-treatment: 1.5 (SD=4.9); 95% CI (calculated) -5.46, 2.46; d=-0.30 | NR | NR

CAPS-CA = Clinician-Administered Posttraumatic Stress Disorder Scale for Children and Adolescents; CI = confidence interval; d = effect size; ETAU= enhanced treatment as usual; G = group; NR = not reported; PTCI = Post-Traumatic Cognitions Inventory; PTSD = post-traumatic stress disorder; SD = standard deviation; TARGET = Trauma Affect Regulation: Guide for Education and Therapy; TSCC = Trauma Symptom Checklist for Children

Table 46 Emotion regulation therapy versus relational supportive therapy: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Early psychological intervention | 1; 59 (46) | PTSD symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference in change in PTSD symptoms Insufficient
Early psychological intervention | 1; 59 (46) | Anxiety symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant change in anxiety symptoms. Insufficient
Early psychological intervention | 1; 59 (46) | Depression symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant change in depression symptoms. Insufficient
Early psychological intervention | 1; 59 (46) | Anger symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant change in anger symptoms Insufficient

PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 Eye Movement Desensitization and Reprocessing

#### Description of Included Studies

We found one study63 addressing eye movement desensitization and reprocessing (EMDR). This study was a randomized controlled trial (RCT) with wait-list control.63 We rated this study as having a medium risk of bias.63

This study identified 27 children ages 6 to 12 years an average of 8 months after admission to a hospital emergency room after a motor vehicle accident. The children had to have at least moderate post-traumatic stress symptoms. Children were excluded if they were on psychotropic medicine, had concurrent psychological conditions, a past history of abuse or neglect, or a serious head injury. Children were randomized to active treatment with EMDR or a 6-week wait-list control. Participants participated in four 60-minute sessions of EMDR over 4 weeks. Outcomes measured included traumatic stress symptoms and diagnostic criteria for PTSD (PTSD Revised Index [RI] scores), depressive symptoms (Children's Depression Scale), parent-reported internalizing and externalizing symptoms (Child Behavior Checklist), and parent-reported traumatic stress symptoms (Parent PTS Reaction Index [RI]). See Table 47 for study characteristics.

Table 47 Eye movement and desensitization reprocessing versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Kemp, et al., 2010^63^ | Male and female children ages 6-12 with score of at least 12 on Child PTSD-RI or at least 2 DSM-IV criteria for PTSD | Motor vehicle accident | RCT w/wait-list control Four sessions of 1 hour delivered over 4 weeks | G1: EMDR G2: Wait-list control | Randomized: G1: 13 G2: 14 Analyzed: G1: 12 G2: 12 | Medium

DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; EMDR = Eye movement and desensitization reprocessing; G = group; PTSD-RI =Post Traumatic Stress Disorder-Revised Index; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

This study does not report funding source.

This study is applicable to children who experienced a motor vehicle accident severe enough to receive evaluation in an emergency department and who display moderate symptoms of post-traumatic stress.

#### Key Points

- Children meeting two or more DSM-IV criteria: Significantly greater reduction in PTSD diagnosis (two or more DSM-IV criteria for PTSD) in the EMDR group than in the wait-list control group (low strength of evidence [SOE]).
- Reduction in PTSD symptoms: Participants in the EMDR group had significant reductions in PTSD symptoms reported by the child and parent compared with the wait-list control group63 (low SOE).

#### Detailed Synthesis

One RCT63 showed a significant reduction in the number of children with two or more DSM-IV criteria for PTSD (Table 48). The study also reported a significant reduction in PTSD symptom scores as reported by the child receiving EMDR compared with wait-list control. There were no significant decreases in depressive symptoms, anxiety state, anxiety trait, general health, and general function. We graded the SOE as low for PTSD diagnosis and PTSD symptom scores because of the presence of a single study with few subjects and medium risk of bias (Table 49). For all other outcomes, we graded the SOE as insufficient; the results were not statistically significant.

Table 48 Eye movement desensitization reprocessing versus wait list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Kemp, et al., 2009^63^ | G1: EMDR school-based psychotherapy G2: Wait-list control | Greater reduction in number of children with 2 or more DSM-IV criteria for PTSD (PTSD [DSM-IV] diagnostic criteria based on systematic clinical assessment) Pretreatment G1: 100% G2: 100% Within-group change in proportion at post-treatment: G1: -75% G2: 0% Between-group change at post-treatment: -75% (calculated) X2 (1, n=24) = 14.40, p<0.001)] Greater reduction of PTSD symptoms (PTSD-RI) Pretreatment G1: 25.92 (SD=12.18) G2: 27.29 (SD=12.58) Magnitude of effect not specified by intervention type MANCOVA controlling for group differences at pretreatment for number of DSM-IV PTSD criteria and Child PTSD-RI scores F(2, 17) = 9.32, p<.01 A priori contrasts identified a significant pre- to postreduction in the number of DSM-IV PTSD criteria [t (11) = 4.17, p < .01] and Child PTSD-RI scores [t (11)=4.26, p=.001] for the EMDR group but not for the wait-list group | No between-group differences in change in anxiety symptoms (STAIC, range 20-60) Pretreatment G1: 28.50 (SD=4.68) G2: 32.33 (SD=8.37) Within-group change: G1: 0.33 (calculated) G2: -0.66 (calculated) Between-group change (95% CI): 0.99 (calculated) p=NS No between-group differences in change in anxiety-trait (STAIC, range 20-60) Pretreatment G1: 35.42 (SD=7.51) G2: 39.58 (SD=7.23) Within-group change: G1: -1.92 (calculated) G2: -3.41(calculated) Between-group change (95% CI): 1.49 (calculated) p=NS No between-group differences in change in depression symptoms (Children's Depression Scale, range 66-330) Pretreatment G1: 138.42 (SD=24.72) G2: 137.50 (SD=27.87) Within-group change: G1: -2.67 (calculated) G2: -6.25 (calculated) Between-group change (95% CI): 3.58 (calculated) p=NS | No between-group differences in change in general health (GHQ; range 0-12) Pretreatment G1: 1.09 (SD=1.92) G2: 4.25 (SD=4.11) Within-group change: G1: 0.82 (calculated) G2: -0.42 (calculated) Between-group change (95% CI): 1.24 (calculated) p=NS | No between-group differences in change in behavioral problems (CBCL-parent rating: range 30-100) Pretreatment G1: 36.73 (SD=22.49) G2: 30.10 (SD=34.16) Within-group change: G1: -8.28 (calculated) G2: 13.07 (calculated) Between-group change (95% CI): -21.35 (calculated) p=NS No between-group differences in change in general functioning (General functional scale, range 12-36) Pretreatment G1: 21.00 (SD=4.38) G2: 19.21 (SD=4.55) Within-group change: G1: -1.27 (calculated) G2: -0.13 (calculated) Between-group change (95% CI): -1.14 (calculated) p=NS

CBCL = Child Behavior Checklist; CI = confidence interval; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; EMDR = Eye movement and desensitization reprocessing; G = group; GHQ = General Health Questionnaire; MANCOVA = multivariate analysis of covariance; NS = not significant; PTSD = post-traumatic stress disorder; PTSD-RI = Post-Traumatic Stress Reaction Index; SD = standard deviation; STAIC = State Trait Anxiety Inventory for Children

Table 49 Eye movement desensitization reprocessing versus wait list control: strength of evidence

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
EMDR | 1; 27 (24) | PTSD criteria | RCT Medium | Unknown | Direct | Precise | Between-group difference in proportion of children with two or more DSM-IV criteria in EMDR group vs. wait-list control group of 75% Low
EMDR | 1; 27 (24) | PTSD symptoms (child report) | RCT Medium | Unknown | Direct | Precise | Significant greater reduction in PTSD symptoms in EMDR group than wait-list group. Magnitude of effect not reported by intervention type Low
EMDR | 1; 27 (24) | Depression symptoms | RCT Medium | Unknown | Direct | Imprecise | No statistically significant difference between groups Insufficient
EMDR | 1, 27 (24) | Anxiety-state | RCT Medium | Unknown | Direct | Imprecise | No difference between groups Insufficient
EMDR | 1; 27 (24) | Anxiety-trait | RCT Medium | Unknown | Direct | Imprecise | No difference between groups Insufficient
EMDR | 1; 27 (24) | Internalizing behavior | RCT Medium | Unknown | Direct | Imprecise | No difference between groups Insufficient
EMDR | 1; 27 (24) | Externalizing behavior | RCT Medium | Unknown | Indirect | Imprecise | No difference between groups Insufficient
EMDR | 1: 27 (24) | General health | RCT Medium | Unknown | Indirect | Imprecise | No difference between groups Insufficient
EMDR | 1; 27 (24) | General functioning | RCT Medium | Unknown | Indirect | Imprecise | No difference between groups Insufficient

DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; EMDR = Eye movement and desensitization reprocessing; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

### Key Question 2 School-Based Interventions

#### Description of Included Studies

We found three RCTs, each rated medium risk of bias,65,66 addressing two distinct school-based interventions for KQ 2.

The first trial65 compared trauma and grief component therapy (TGCT) for adolescents group therapy plus usual care (classroom-based psychoeducation and skills training) to usual care only (Table 50). Participants included 159 male and female adolescents ages 13 to 18 from Bosnia exposed to trauma before, during, or after the war who also had significant traumatic distress and functional impairment. School counselors, who delivered the intervention, received training via four 2-day training seminars led by the authors and mental health professionals. Every 2 to 4 weeks during the intervention, each counselor met with a local supervisor to monitor adherence to protocol. The treated adolescents received 17 to 20 weekly group TGCT sessions at school, lasting 60 to 90 minutes each for the duration of the school year (7 months minus breaks for school holidays and examination week). Outcomes assessed included PTSD symptoms via the UCLA Post-Traumatic Stress Disorder Reaction Index-Revised and depression symptoms via the Depression Self-Rating Scale (DSRS). Funding for this study was provided by UNICEF Bosnia and Herzegovina, the Brigham Young University Family Studies Center, the David M. Kennedy Center for International Studies, the Bing Fund, and Tony Bennett.

Table 50 Trauma and grief component therapy for adolescents plus classroom-based psychoeducation and skills training versus classroom-based psychoeducation and skills training: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Layne, et al., 2008^65^ | Male and female adolescents ages 13-18 in Bosnia who had (1) trauma exposure before, during, or after the war; (2) significant current distress; and (3) significant functional impairment | War-exposed in Bosnia | RCT 17-20 weekly group sessions for an entire school year (7 months minus breaks for school holidays and examination week) lasting 60-90 minutes each | G1: TGCT group therapy plus classroom-based psychoeducation and skills training G2: Classroom-based psychoeducation and skills training only | Randomized: G1: 77 G2: 82 Analyzed: G1: 66 G2: 61 | Medium

G = group; RCT = randomized controlled trial; TGCT = trauma and grief component therapy for adolescents

The second trial66 recruited 403 male and female school children in Poso, Indonesia, with mean ages of 10.08 and 9.78 for the treatment and wait-list groups, respectively (Table 51). Each participant had exposure to one or more traumatic events (mainly resulting from poverty and political violence/instability) as well as significant PTSD symptoms (at least 11) and anxiety complaints (at least 5). Interventionists who delivered the treatment had at least a high school education, generally did not have formal mental health training but some experience as volunteers in humanitarian programs, and lived in the local target communities. The interventionists received a 2-week training program prior to program implementation. Multiple independent research assessors judged the fidelity of interventionists to the treatment manual using a structured checklist. The treatment group received 15 sessions over 5 weeks that consisted of trauma-processing activities, cooperative play, and creative expressive elements delivered in groups at school. The comparison group consisted of wait-list controls who received the intervention after the study concluded. Assessments, which occurred 1 week and 6 months postintervention, included child-reported PTSD symptoms (Post-Traumatic Stress Scale), depression symptoms (DSRS), anxiety symptoms (Self Report for Anxiety Related Disorders: SCARED-5), and functional impairment (contextually constructed 10-item checklist), as well as parent-reported functional impairment and aggression (Children's Aggression Scale for Parents). This trial was funded by PLAN Netherlands (an international nongovernmental child-focused development agency) and implemented in collaboration with Church World Services Indonesia.

Table 51 Cognitive behavioral therapy/creative expressive school-based group intervention versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Tol, et al., 2008^66^ | Male and female school children in Poso, Indonesia (mean age 10.08 and 9.78 for treatment and wait-list groups, respectively) who were exposed to ≥1 events, or had significant (≥11) PTSD symptoms and anxiety complaints (≥5) | Poverty and political violence/instability | Cluster-RCT w/wait-list control 15 sessions over 5 weeks | G1: School-based group intervention including CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements G2: Wait-list control | Randomized: G1: 182 G2: 221 1-week followup G1: 182 G2: 211 6-month followup G1: 177 G2: 191 Analyzed: G1: 182 G2: 221 | Medium
Tol, et al., 2012^67^ | Male and female school children in Sri Lanka aged 9-12 (mean age=11.03) who screened positive on the CPDS for existence of risk factors and absence of protective factors | War/political violence/instability | Cluster-RCT w/wait-list control 15 sessions over 5 weeks | G1: School-based group intervention including CBT and creative expressive elements G2: Wait-list control | Randomized: 399 G1: 199 G2: 200 1-week followup G1: 199 G2: 200 3-month followup G1: 198 G2: 199 Analyzed: G1: 198 G2: 199 | Medium

CBT = cognitive behavioral therapy; CPDS = Child Psychosocial Distress Screener; G = group; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

The third trial67 recruited 399 male and female school children ages 9 to 12 (mean=11.03 years) from the Jaffna district in northern Sri Lanka (Table 51) and compared an intervention consisting of CBT and creative expressive elements, similar to the treatment described in Tol et al., 2008.^66^ Each participant had exposure to trauma resulting from living in a politically violent/unstable/war-torn area and screened positive on the Child Psychosocial Distress Screener (CPDS) for existence of risk factors and lack of protective factors. A small group of children reporting severe mental health problems were provided individual supportive therapy in addition to being enrolled in the study (n=19, treatment-group specific n not reported). Interventionists who delivered the intensive (3 times per week) treatment were nonspecialized personnel with at least a high school education who lived in the area. The interventionists received a year-long training program prior to program implementation. Assessment of the fidelity of interventionists to the treatment manual was not reported. The treatment group received 15 sessions over 5 weeks that consisted of trauma-processing activities, cooperative play, and creative expressive elements delivered in groups at school. The comparison group consisted of wait-list controls who received the intervention after the study concluded. Assessments, which occurred 1 week and 3 months postintervention, included child-reported PTSD symptoms (CPSS), depression symptoms (DSRS), anxiety symptoms (SCARED-5), psychological difficulties and prosocial behavior (from subscales of the SDQ), conduct problems (investigator-developed scale), supernatural complaints (investigator-developed scale), and functional impairment (contextually constructed 10-item checklist). This trial was funded by PLAN Netherlands.

The applicability of these interventions is limited to the specific populations recruited for each study. Thus, the TGCT study65 findings apply to adolescents exposed to war with distress and impairment; the second school-based intervention66 findings apply to younger school-aged students exposed to poverty and political violence/instability with significant PTSD and anxiety symptoms; the third school-based intervention67 findings apply to school children ages 9 to 12 exposed to war and political violence/instability with significant psychological distress.

#### Key Points

We found three school-based interventions that addressed KQ 2.

##### Trauma and Grief Component Therapy for Adolescents Plus Classroom-Based Psychoeducation and Skills Training Versus Classroom-Based Psychoeducation and Skills Training

- PTSD symptoms: Participants in the trauma and grief component therapy (TGCT) plus classroom-based psychoeducation and skills training group had significantly greater improvements in PTSD symptoms between baseline and followup than participants in the classroom-based psychoeducation and skills training only group (low SOE).
- Depression symptoms: Participants in the TGCT plus classroom-based psychoeducation and skills training group had significantly greater improvements in depression symptoms between baseline and followup than participants in the classroom-based psychoeducation and skills training only group (low SOE).

##### Cognitive Behavioral Therapy/Creative Expressive School-Based Group Intervention Versus Wait-List Control

- PTSD symptoms: Participants in the CBT/creative expressive school-based group had significantly greater reduction in PTSD symptoms between baseline and followup than wait-list control participants in one study and no significant difference in the other study (insufficient SOE).
- Depression symptoms: Participants in the CBT/creative expressive school-based group did not have significantly different changes in depression symptoms than wait-list control participants in either study (insufficient SOE).
- Anxiety symptoms: Participants in the CBT/creative expressive school-based group did not have significantly different decreases in anxiety symptoms than wait-list control participants in either study (insufficient SOE).
- Functional impairment: Participants in the CBT/creative expressive school-based group did not have significantly different changes in child-rated functional impairment than wait-list control participants in either study (insufficient SOE).
- Functional impairment (parent-rated): Participants in the CBT/creative expressive school-based group did not have significantly different changes in parent-rated functional impairment than wait-list control participants in one study. We found the evidence insufficient to draw a conclusion about the efficacy of CBT/creative expressive school-based group therapy versus wait-list control (insufficient SOE).
- Aggression (parent-rated): Participants in the CBT/creative expressive school-based group did not have significantly different changes in parent-rated aggression than wait-list control participants in one study. We found the evidence insufficient to draw a conclusion about the efficacy of CBT/creative expressive school-based group therapy versus wait-list control (insufficient SOE).
- Psychological difficulties: Participants in the CBT/creative expressive school-based group did not have significantly different changes in psychological difficulties than wait-list control participants in a single study (insufficient SOE).
- Prosocial behaviors: Participants in the CBT/creative expressive school-based group did not have significantly different changes in prosocial behaviors than wait-list control participants in a single study (insufficient SOE).
- Supernatural complaints: Participants in the CBT/creative expressive school-based group did not have significantly different changes in supernatural complaints than wait-list control participants in a single study (insufficient SOE).
- Conduct problems: Participants in the CBT/creative expressive school-based group had significantly greater decreases in conduct problems as compared with wait-list control participants in a single study (low SOE).

#### Detailed Synthesis

##### Trauma and Grief Component Therapy for Adolescents Plus Classroom-Based Psychoeducation and Skills Training Versus Classroom-Based Psychoeducation and Skills Training

One RCT65 found a statistically significant difference in change in PTSD symptoms and change in depression symptoms favoring the treatment arm (Table 52). We graded the SOE as low for both PTSD and depression symptom outcomes given that only one study met inclusion criteria and between-group change scores were significant, favoring the TGCT group (Table 52).

Table 52 Trauma and grief component therapy for adolescents plus classroom-based psychoeducation and skills training versus classroom-based psychoeducation and skills training: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Layne et al., 2008^65^ | G1: TGCT group therapy plus classroom-based psychoeducation and skills training G2: Classroom-based psychoeducation and skills training only | Greater reduction in PTSD symptoms (UCLA PTSD RI-R, range=0-68) Pretreatment G1: 36.37 (SD=14.27) G2: 33.02 (SD=10.27) Within-group change: G1 (95% CI): -11.85 (-15.28, -8.42) G2 (95% CI): -5.67 (-8.93 to -2.42) Between-group difference: -6.18 (calculated) MANOVA between-group time × treatment group interaction F= 6.77, df=1,125, p=0.01. NS | Greater reduction in depression symptoms (DSRS, range=0-72) Pretreatment G1: 32.61(SD=11.39) G2: 28.61 (SD=9.86) Within-group change: G1 (95% CI): -2.69 (-5.33 to -0.06) G2 (95% CI): 1.91 (-0.68 to 4.51) Between-group difference: -2.78 (calculated) MANOVA between-group time × treatment group interaction F= 6.16, df=1,125, p<0.05. | NR | NR

CI = confidence interval; df = degrees of freedom; DSRS = Depression Self-Rating Scale; G = group; MANOVA = multivariate analysis of variance; NR = not reported; NS = not significant; PTSD = post-traumatic stress disorder; SD = standard deviation; TGCT = trauma and grief component therapy for adolescents; UCLA PTSD RI-R = UCLA Post-Traumatic Stress Disorder Reaction Index-Revised

##### Cognitive Behavioral Therapy/Creative Expressive School-Based Group Intervention Versus Wait-List Control

Two RCTs66,67 found no statistically significant difference in change in depression or anxiety symptoms or child-rated functional impairment (Table 53). In addition, one study66 found no differences between the school-based intervention arm and the wait-list arm on parent-rated functional impairment or parent-rated aggression; the other study67 found no differences between the school-based intervention arm and the wait-list arm on psychological difficulties, prosocial behavior, and supernatural complaints. One study66 found the school-based treatment group had significantly greater decreases in PTSD symptoms than the wait-list control group but the other67 found no significant differences in changes in PTSD symptoms. One study67 found the school-based CBT-creative expressive therapy group had greater decreases in conduct problems compared with the wait-list group. Thus, we graded the SOE as low for conduct problems and insufficient for all other outcomes with nonsignificant findings between groups in both studies or mixed findings (e.g., significant PTSD symptoms in one study but not the other) between groups, given that only two studies met inclusion criteria (Table 54).

Table 53 Cognitive behavioral therapy/creative expressive school-based group intervention versus wait-list control: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Tol, et al., 2008^66^ | G1: School-based group intervention including CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements G2: Wait-list control | Greater reduction of PTSD symptoms at 6-month followup (Child Post-Traumatic Stress Scale, range=0-68) Pretreatment G1: 20.92 (SD=8.75) G2: 22.35 (SD=8.39) Within-group change at 1 week: G1: -9.10 (SD=9.20) G2: -4.85 (SD=9.49) Within-group change at 6 months: G1: -10.35 (SD=8.89) G2: -6.15 (SD=10.04) Between-group difference at 1 week (95% CI): d=0.55 (0.35 to 0.75) Between-group difference at 6 months: Mixed method regression analysis mean change difference adjusted for school mean (95% CI): 2.78 (1.02 to 4.53); d(95% CI): 0.44 (0.24 to 0.64) | No difference between groups in change in depression symptoms at 6-month followup (DSRS, range=0-36) Pretreatment G1: 12.29 (SD=3.33) G2: 12.55 (SD=3.47) Within-group change at 1 week: G1: -0.80 (SD=3.88) G2: 0.50 (SD=4.33) Within-group change at 6 months: G1: -0.82 (SD=3.82) G2: 0.16 (SD=4.73) Between-group difference at 1 week (95% CI): d=0.31 (0.12 to 0.51) Between-group difference at 6 months: Mixed method regression analysis mean change difference adjusted for school mean (95% CI): -0.70 (-0.08 to 1.49); d (95% CI): 0.24 (0.04 to 0.43) No difference between groups in change in anxiety symptoms at 6-month followup (SCARED-5, range=0-10) Pretreatment G1: 4.38 (SD=1.76) G2: 4.46 (SD=1.87) Within-group change at 1 week: G1: -0.97 (SD=2.16) G2: -0.65 (SD=2.32) Within-group change at 6 months: G1: -1.06 (SD=2.45) G2: -0.96 (SD=2.49) Between-group difference at 1 week (95% CI): d=0.14 (-0.05 to 0.34) Between-group difference at 6 months: Mixed method regression analysis mean change difference adjusted for school mean (95% CI): -0.12 (-0.31 to 0.56); d (95% CI): 0.04 (-0.16 to 0.24) | NR | No difference between groups in change in (child-reported) functional impairment at 6-month followup (child-reported through contextually constructed 10-item checklist, range=10-40) Pretreatment G1: 18.03 (SD=5.61) G2: 17.90 (SD=5.39) Within-group change at 1 week: G1: -3.30 (SD=5.52) G2: -1.11 (SD=4.98) Within-group change at 6 months: G1: -3.48 (SD=5.70) G2: -2.06 (SD=5.07) Between-group difference at 1 week (95% CI): d=0.42 (0.22 to 0.61) Between-group difference at 6 months: Mixed method regression analysis mean change difference adjusted for school mean (95% CI): -0.52 (-0.43 to 1.46); d (95% CI): 0.26 (0.07 to 0.46) No between group difference in change in parent-reported functional impairment at 6-month followup (parent-reported through contextually constructed 10-item checklist, range=10-40) Pretreatment G1: 14.04 (SD=4.24) G2: 14.20 (SD=4.43) Within-group change at 1 week: G1: -1.44 (SD=4.72) G2: -1.16 (SD=4.23) Within-group change at 6 months: G1: -2.03 (SD=4.71) G2: -1.48 (SD=4.69) Between-group difference at 1 week (95% CI): d=0.10 (-0.09 to 0.29) Between-group difference at 6 months (95% CI): d=0.07 (-0.12 to 0.26) No between-group differences in change in parent-reported aggression at 6-month followup (parent-reported through Children's Aggression Scale for Parents, range=33-132) Pretreatment G1: 42.18 (SD=9.09) G2: 44.63 (SD=12.08) Within-group change at 1 week: G1: -1.44 (SD=4.72) G2: -1.16 (SD=4.23) Within-group change at 6 months: G1: -2.03 (SD=4.71) G2: -1.48 (SD=4.69) Between-group difference at 1 week: d=0.06 (-0.13 to 0.25) Between-group difference at 6 months (95% CI): d=0.12 (-0.07 to 0.31)
Tol, et al., 2012^67^ | G1: School-based group intervention including CBT techniques and creative expressive elements G2: Wait-list control | No between-group differences in change in PTSD symptoms (CPSS, range 0-51) Pretreatment G1: 15.03 (SD=8.89) G2: 15.70 (SD=9.12) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): 0.281 (0.332); p=NS | No between-group differences in change in depressive symptoms (DSRS, range 0-36) Pretreatment G1: 8.39 (SD=4.54) G2: 8.56 (SD=4.37) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): 0.115 (0.112); p=NS No between-group differences in change in anxiety symptoms (SCARED-5, range 0-10) Pretreatment G1: 3.29 (SD=2.13) G2: 3.17 (SD=2.16) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): -0.037 (0.065); p=NS No between-group differences in change in psychological difficulties (4 subscales consisting of 20 items from SDQ, range 0-40) Pretreatment G1: 10.74 (SD=5.57) G2: 10.29 (SD=5.44) Within-group change at post-treatment: G1: NR G2: NR | | Greater reduction in conduct problems (8-item scale, range 0-24) Pretreatment G1: 2.00 (SD=2.84) G2: 1.99 (SD=2.23) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): -0.132 (0.045); p<0.01 No between-group differences in change in prosocial behavior (5-item subscale from SDQ, range 0-10) Prosocial behavior: Pretreatment G1: 8.21 (SD=1.82) G2: 8.34 (SD=1.72) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): -0.016 (0.052); p=ns No between-group differences in change in functional impairment (10-item scale, range 0-30) Pretreatment G1: 3.64 (SD=4.47) G2: 3.23 (SD=4.37) Within-group change at post-treatment: G1: NR G2: NR
Tol, et al., 2012^67^ | | | Between-group change at post-treatment: NR LGCM estimate (SE): -0.198 (0.280); p=NS No between-group differences in change in supernatural complaints (6-item scale, range 0-18) Pretreatment G1: 2.21 (SD=2.59) G2: 1.97 (SD=1.92) Within-group change at post-treatment: G1: NR G2: NR Between-group change at post-treatment: NR LGCM estimate (SE): -0.121 (0.064); p<0.06 | | Between-group change at post-treatment: NR LGCM estimate (SE): -0.036 (0.143); p=NS

CBT = cognitive behavioral therapy; CI = confidence interval; CPSS = Child PTSD Symptom Scale; d = effect size; DSRS = Depression Self-Rating Scale; G = group; LGCM = latent growth curve modeling; NR = not reported; PTSD = Post-Traumatic stress disorder; SCARED-5 = Self-Report for Anxiety-Related Disorders; SD = standard deviation; SDQ = Strengths and Difficulties Questionnaire; SE = standard error

Table 54 Strength of evidence for Key Question 2: school-based interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TGCT group therapy plus classroom-based psycho-education and skills training vs. classroom based psycho-education and skills training | 1; 159 (127) | PTSD symptoms | RCT Medium | Unknown | Direct | Precise | Greater reduction in PTSD symptoms in treatment group (calculated mean between-group difference= -6.18, MANOVA time × treatment group interaction p=0.01) Low
TGCT group therapy plus classroom-based psycho-education and skills training vs. classroom based psycho-education and skills training | 1; 159 (127) | Depression symptoms | RCT Medium | Unknown | Direct | Precise | Greater reduction in depression symptoms in treatment group (calculated mean between-group difference= -2.78, MANOVA time × treatment group interaction p<0.05) Low
CBT/creative expressive school-based group intervention vs. wait-list control | 2; 802 (800) | PTSD symptoms | RCT Medium | Inconsistent | Direct | Imprecise | Significantly greater decrease in PTSD symptoms for treatment group at 6 months postintervention (mixed method regression analysis mean change difference adjusted for school mean (95% CI): 2.78 (1.02, 4.53) in one study; no difference in change in PTSD symptoms between groups in the second study Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 2; 802 (800) | Depression symptoms | RCT Medium | Consistent | Direct | Imprecise | No difference in change in depressive symptoms between groups in either study Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 2; 802 (800) | Anxiety symptoms | RCT Medium | Consistent | Direct | Imprecise | No difference in change in anxiety symptoms between groups in either study Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 2; 802 (800) | Functional impairment (child-reported) | RCT Medium | Consistent | Direct | Imprecise | No difference in change in (child-reported) functional impairment between groups in either study Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | Functional impairment (parent-reported) | RCT Medium | Unknown | Indirect | Imprecise | No difference in change in (parent-reported) functional impairment at 6-month followup between groups Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | Aggression (parent-reported) | RCT Medium | Unknown | Indirect | Imprecise | No difference in change in (parent-reported) aggression at 6-month followup between groups Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 399 (397) | Psychological difficulties | RCT Medium | Unknown | Direct | Imprecise | No difference in change in psychological difficulties between groups Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 399 (397) | Supernatural complaints | RCT Medium | Unknown | Direct | Imprecise | No difference in change in supernatural complaints between groups Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 399 (397) | Conduct problems | RCT Medium | Unknown | Direct | Precise | Significantly greater reduction in conduct problems in treatment group than wait-list group (LGCM estimate, SE: -0.132, 0.045; p<0.01) Low
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 399 (397) | Prosocial behavior | RCT Medium | Unknown | Direct | Imprecise | No difference in change in prosocial behavior between groups Insufficient

CBT = cognitive behavioral therapy; CI = confidence interval; LGCM = latent growth curve modeling; MANOVA = multivariate analysis of variance; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; SE = standard error; TGCT = trauma and grief component therapy for adolescents

### Key Question 2 Antidepressant Medication

#### Description of Included Studies

Study authors found three RCT studies evaluating antidepressants for KQ 2. One study68 tested the tricyclic antidepressant imipramine versus chloral hydrate in PTSD symptoms in thermally injured children. Another study69 tested imipramine versus the selective serotonin reuptake inhibitor (SSRI) fluoxetine versus placebo medication also in thermally injured children with PTSD symptoms. While both of these studies were undertaken prior to the 30-day period necessary for a diagnosis of PTSD, the symptoms were the same and inclusion was based on having a diagnosis of acute stress disorder rather than on exposure. The final study evaluated the SSRI sertraline against placebo medication in children with PTSD from multiple traumas.70 The studies on the SSRI medications69,70 were rated as having low risk of bias whereas the first imipramine study68 was rated as having a medium risk of bias. Study characteristics are reported in Table 55.

Table 55 Antidepressant medication interventions: study characteristics

Author, Year | Inclusion criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Robert, et al., 1999^68^ | Male and female thermally injured children ages 2-19 with acute stress disorder symptoms for at least 2 days | Thermal injury | Parallel RCT 1 week of medication nightly, burn treatment including physical rehabilitation and pain, itching, and anxiety control | G1: Imipramine G2: Chloral hydrate | Randomized G1: 12 G2: 13 Analyzed G1: 12 G2: 13 | Medium
Robert, et al., 2008^69^ | Male and female thermally injured children ages 4-18 with acute stress symptoms | Thermal injury | Parallel RCT 1 week of medication nightly and standard burn treatment | G1: Imipramine G2: Fluoxetine G3: Placebo | Randomized G1: 21 G2: 19 G3: 22 Analyzed G1: 20 G2: 18 G3: 22 | Low
Robb, et al., 2010^70^ | Male and female children ages 6-17 with PTSD from multiple traumas | Multiple (sexual abuse, traumatic news, physical abuse, car and other accidents, fire or natural disaster, or witness to violence) | Parallel RCT 10 weeks of medication | G1: Sertraline G2: Placebo | Randomized G1: 67 G2: 62 Analyzed G1: 67 G2: 61 | Low

G = group; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

The two studies on imipramine looked at similar populations: thermally injured male and female children with PTSD symptoms in a burn center in the United States. The age ranges of the two studies varied somewhat: the first study looked at 25 children ages 2 to 19 years68 and the second study looked at 62 children ages 4 to 18.^69^ While in the first imipramine study, racial makeup was not reported, the second imipramine study had a predominantly Hispanic racial makeup (88.3% of participants).

The first study evaluated 7 days of imipramine at 1 mg/kg with a maximum dosage of 100 mg versus 7 days of chloral hydrate at 25 mg/kg with a maximum dosage of 500 mg. Imipramine is a tricyclic antidepressant that was hypothesized to treat multiple symptoms of PTSD in children and was used historically to treat depression and anxiety symptoms in adults. This medication was compared with the more traditional treatment chloral hydrate, a sleep aid used mainly to treat sleep disturbance alone in children with PTSD. The second imipramine study evaluated the same dosage and timing of imipramine. However, comparison was made with another experimental group taking fluoxetine at 5 mg, 10 mg, or 20 mg depending on weight and with control placebo medication. Fluoxetine is an SSRI used to treat a variety of anxiety and depressive states in children and adults. In both studies, medication was started within 30 days of the accident and participants were included owing to severity of or number of PTSD symptoms. In both studies, patients were either coded as responders or nonresponders after 1 week of medication and then the study was terminated. Also in both studies, participants and assessors were blinded to study arm.

Applicability for both studies was limited to the population of participants recruited, which were burned children. Limitations of applicability include racial makeup, which was not reported in the first imipramine study68 and was mainly Hispanic in the second study.69 While sex of participants was fairly well-distributed in the first study, only 26 percent of recruited participants were female in the second study.

The sertraline study70 evaluated 129 male and female children ages 6 to 17 with PTSD from multiple traumas treated at 21 outpatient centers within the United States. Sertraline is an SSRI medication used to treat PTSD in adults along with a number of depressive and anxiety states. Traumas experienced in participants recruited included sexual abuse, traumatic news, physical abuse, car and other accidents, fire or natural disaster, and witness to violence. The study did comment on recruitment and adherence to the study protocol and followup. Sertraline was given for 10 weeks and started at 25 mg in week 1 and 50 mg in week 2 and titrated every other week to a maximum dosage of 200 mg as clinically indicated. This regimen was compared with placebo medication. Both participants and evaluators were blinded to the experimental or control group status. Prior to the 10 weeks of medication, there was a 2-week washout/baseline period. Evaluations were undertaken at baseline and at week 10 of medication.

Applicability was limited to the participants recruited. Trauma type, sex, and racial makeup of the study were relatively well-distributed and could be applicable to the outpatient population with PTSD. Limits to applicability related mainly to the adolescent group, which was greater than 75 percent female.

#### Key Points

We found three studies that tested antidepressant medication that addressed KQ 2.

##### Imipramine Versus Chloral Hydrate or Placebo

We identified one RCT comparing the efficacy of imipramine versus chloral hydrate and one RCT comparing the efficacy of imipramine versus fluoxetine versus placebo as treatment of PTSD symptoms in traumatized children and adolescents.68,69 The studies targeted children and adolescents ages 2 to 19 years68 and children and adolescents ages 4 to 18 years69 in a burn unit who had suffered thermal injury.

- PTSD symptom severity: In the first study, participants in the imipramine medication group had significantly greater proportion of acute stress disorder (ASD) symptom responders than the chloral hydrate medication group.68 In the second study, no significant differences were found between groups for changes in ASD symptoms or ASD symptom response.69

##### Fluoxetine Versus Placebo

We identified one RCT comparing the efficacy of fluoxetine versus imipramine versus placebo for treatment of PTSD symptoms in traumatized children and adolescents.69 The study targeted children and adolescents ages 4 to 18 years69 in a burn unit who had suffered thermal injury.

- PTSD symptom severity: No significant differences in changes in ASD symptoms or ASD symptom response were found by study arm.69

##### Sertraline Versus Placebo

We identified one RCT comparing the efficacy of sertraline versus placebo for treatment of PTSD symptoms in traumatized children and adolescents.70 The study targeted children and adolescents ages 6 to 17 years in outpatient clinics who had suffered multiple traumas.70 The study also reports the more conservative estimate of differences based on the last observation carried forward (LOCF).

- PTSD symptoms: Participants in the sertraline medication group had no significant differences in interviewer-assessed or clinician-rated PTSD symptom changes compared with participants in the placebo group. The placebo group had greater decreases in parent-rated PTSD symptoms compared with sertraline group. We graded the SOE as low for no benefit since participants in the placebo group had significantly greater decreases in parent-reported PTSD symptoms compared with participants in the sertraline group.
- PTSD severity: Participants in the placebo group had greater decreases in clinician-rated PTSD severity compared with sertraline group. We rated the SOE as low for no benefit since participants in the placebo group had significantly greater decreases in clinician-rated PTSD severity compared with participants in the sertraline group.
- Depressive symptoms: No significant between-group differences were found for change in depressive symptom scores. We rated the SOE as insufficient for the efficacy of sertraline to improve depressive symptoms in children and adolescents with PTSD based on the results of one study.
- Quality of life: Participants in the placebo group had greater improvement in quality of life compared with participants in the sertraline group. We rated the SOE as low for no benefit since participants in the placebo group had significantly greater increases in quality of life as compared with participants in the sertraline group.

#### Detailed Synthesis

##### Imipramine Versus Chloral Hydrate or Placebo

One RCT68 recruited children and adolescents ages 2 to 19 years to imipramine medication treatment or chloral hydrate medication treatment and found statistically significant differences in PTSD symptom response by study arm (Table 56). One RCT69 recruited children and adolescents ages 4 through 18 years to imipramine medication treatment, fluoxetine medication treatment, or placebo and found no significant differences in PTSD symptom changes between groups. We graded the SOE as insufficient for PTSD symptoms because of two studies with conflicting data, although the estimates were rated as precise given that the second study was powered to detect significant differences between the imipramine and placebo groups (Table 57).

Table 56 Antidepressant medication interventions: results

Author, Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Robert, et al., 1999^68^ | G1: 7 days of imipramine medication dosed at 1 mg/kg with max dosage of 100 mg with standard burn treatment including physical rehabilitation and pain, itching, and anxiety control G2: 7 days of chloral hydrate medication dosed at 25 mg/kg with a max dosage of 500 mg with standard burn treatment including physical rehabilitation and pain, itching, and anxiety control | Greater ASD symptom response (via interview, and quantifying number and intensity of symptoms) ASD symptom responders at post-treatment: G1: 83% G2: 38% Between-group difference in relieving ASD symptoms, X^2^=5.24, df=1, p=0.04 | NR | NR | NA
Robert, et al., 2008^69^ | G1: 7 days of imipramine medication dosed at 1 mg/kg with max dosage of 100 mg with standard burn treatment G2: 7 days of fluoxetine medication dosed at 5 mg, 10 mg, or 20 mg based on weight criteria (<40 kg, 40-60 kg, >60 kg) with standard burn treatment G3: 7 days of placebo medication with standard burn treatment | No between-group differences in change in ASD symptoms (Acute Stress Disorder Checklist) Pretreatment mean G1: 42.6 (SD=12.4) G2: 47.6 (SD=15.0) G3: 44.6 (SD=14.0) Within-group % change in mean score post-treatment G1: -62.6% (SD 39.5) G2: -73.6% (SD 40.4) G3: -65.1% (SD 41.5) Between-group difference in % change in mean score post-treatment: p=NS % responders at post-treatment G1: 60.0% G2: 72.2% G3: 54.5% Between-group difference in % responders at post-treatment p=NS | NR | NR | NA
Robb, et al., 2010^70^ | G1: 10 weeks of sertraline started at 25 mg daily for week 1, increased to 50 mg for next 2 weeks, then increased as clinically indicated every 2 weeks to max dosage of 200 mg daily G2: 10 weeks of placebo medication | No between-group difference in change in PTSD symptoms (UCLA PTSD-I, range 0-68) Pretreatment G1: 43.8 (SD=8.5) G2: 42.1 (SD=8.8) Within-group LS mean change LOCF: G1: -20.4 (SD=2.1) G2: -22.8 (SD=2.1) Between-group LS mean change score difference LOCF 95% CI,-7.6 to 2.9 p=0.373 Worse improvement in parent-rated PTSD symptom scores (placebo having greater reduction in symptoms) (CSDC, range 0-30) Pretreatment G1: 33.5 (SD=10.5) G2: 34.1 (SD=10.4) Within-group LS mean change LOCF: G1: -12.4 (SD=1.7) G2: -17.3 (SD=1.9) Between-group LS mean change score difference LOCF 95% CI,-9.1 to -0.6 p=0.025 Worse improvement in clinician-rated PTSD severity (placebo having greater reduction in severity) (CGI-S, range 0-7) Pretreatment G1: 4.5 (SD=0.6) G2: 4.4 (SD=0.6) Within-group LS mean change LOCF: G1: -1.4 (SD=0.2) G2: -1.8 (SD=0.2) Between-group LS mean change score difference LOCF 95% CI, -0.8 to 0.0 p=0.031 No between-group difference in change in clinician-rated PTSD symptom improvement (CGI-I, range 0-7) Pretreatment G1: NA G2: NA Within-group LS mean change LOCF: G1: 2.4 (SD=0.2) G2: 2.2 (SD=0.2) Between-group LS mean change score difference LOCF 95% CI, -0.6 to 0.3, p=0.415 | No between-group difference in change in clinician-rated depression symptoms (CDRS, range 0-17) Pretreatment G1: 40.3 (SD=14.4) G2: 41.2 (SD=14.2) Within-group LS mean change LOCF: G1: -10.0 (SD=1.5) G2: -12.3 (SD=1.6) Between-group LS mean change score difference LOCF 95% CI, -6.0 to 1.3 p=0.210 | NR | Worse improvement in change in quality of life scores (placebo having greater improvement) (PQ-LES-Q. range 0-17) Pretreatment G1: 49.6 (SD=9.5) G2: 49.5 (SD=10.4) Within-group LS mean change LOCF: G1: 7.2 (SD=1.3) G2: 10.7 (SD=1.5) Between-group LS mean change score difference LOCF 95% CI, 0.2 to 6.8 p=0.037

ASD = acute stress disorder; CDRS-R = Children's Depression Rating Scale, Revised; CGI-I = Clinical Global Impressions-Improvement; CGI-S = Clinical Global Impressions-Severity; CI = confidence interval, CSDC = Child Stress Disorder Checklist; df = degrees of freedom; G = group; kg = kilograms; LOCF = last observation carried forward; LS = least squares; mg = milligrams; NA = not applicable; NR = not reported; NS = not significant, PQ-LES-Q = Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; PTSD = post-Traumatic stress disorder; SD = standard deviation; UCLA PTSD-I = University of California, Los Angeles Post-Traumatic Stress Disorder Reaction Index

Table 57 Strength of evidence for Key Question 2: antidepressant medication interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Imipramine medication vs. chloral hydrate or placebo | 2; 87 (85) | PTSD symptoms | RCT Medium | Inconsistent | Indirect | Precise | One study68 found group treated with imipramine to have significantly greater proportion of ASD symptom responders than group treated with chloral hydrate (p=0.04) in thermally injured children. The other study69 found no significant differences between groups of imipramine vs. placebo for change in ASD symptoms or ASD symptom response.^a^ Insufficient
Fluoxetine medication vs. placebo | 1; 62 (60) | PTSD symptoms | RCT Low | Unknown | Indirect | Imprecise | No significant differences between groups for change in ASD symptoms or ASD symptom response. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | PTSD symptoms | RCT Low | Unknown | Direct | Imprecise | No difference between groups for interviewer-assessed PTSD symptoms or clinician-rated PTSD symptom improvement. Placebo group had greater decreases in parent-rated PTSD symptoms compared with sertraline group (between-group LS mean change score difference 95% CI, -9.1 to -0.6, p=0.025). Low for no benefit, as sertraline had worse improvements in parent-reported PTSD symptoms.
Sertraline medication vs. placebo | 1; 129 (128) | PTSD severity | RCT Low | Unknown | Direct | Imprecise | Placebo group had greater decreases in clinician-rated PTSD severity compared with sertraline group (between-group LS mean change score difference 95% CI, -0.8 to 0, p=0.031). Low for no benefit, as sertraline had worse improvement in clinician-rated PTSD severity.
Sertraline medication vs. placebo | 1; 129 (128) | Depressive symptoms | RCT Low | Unknown | Direct | Imprecise | No difference between groups. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Quality of life | RCT Low | Unknown | Direct | Precise | Placebo group had greater improvement compared with sertraline group (between-group LS mean change score difference 95% CI, 0.2 to 6.8 p=0.037). Low for no benefit, as sertraline group had worse improvements in quality of life.

ASD = acute stress disorder; CI = confidence interval; LS = least squares; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

a Study powered at 0.85 with alpha error of 0.05

##### Fluoxetine Versus Placebo

One RCT69 recruited children and adolescents ages 4 through 18 years to fluoxetine or imipramine medication treatment or placebo and found no significant difference in PTSD symptom severity and response to medication by study arm (Table 56). We graded the SOE as insufficient for PTSD symptom severity because only one study met the inclusion criteria and because of lack of precision in the estimates of effect (Table 57).

##### Sertraline Versus Placebo

One RCT70 recruited children and adolescents ages 6 through 17 years to sertraline medication treatment or placebo and found a statistically significant difference in ASD symptoms and severity by study arm, with placebo being superior to sertraline on ratings of symptoms via the parent-rating and severity via clinician-rating(Table 56). This study also found no significant differences in PTSD symptoms assessed via interview or clinician rating. The study found no statistically significant differences in change in depressive symptoms by study arm. Quality-of-life improvement was significantly greater in the placebo group compared with the sertraline group. We graded the SOE as low for no benefit for parent-rated PTSD symptoms, clinician-rated PTSD severity, and quality-of-life outcomes given that the sertraline participants fared worse than placebo group participants for these outcomes (Table 57).

## Key Question 3 Subgroup Differences in Efficacy of Interventions Targeting Children Exposed to Trauma, Some of Whom Already Have Symptoms

### Description of Included Studies

We found one study51 that examined subgroup differences in efficacy of interventions targeting children exposed to trauma and one study71 that examined subgroup differences in efficacy of interventions targeting children exposed to trauma who already had symptoms. These studies tested the differences in the effect of treatment on outcomes by subgroup via interaction effects. Both studies were rated medium risk of bias.

The first study51 examined the efficacy of trauma-focused cognitive behavioral therapy (TF-CBT) using a prospective cohort study design (Table 58). This study identified four schools in a single city severely affected by an earthquake. Children in the sixth and seventh grades (mean age=13.2 years) were selected for therapy 1.5 years after the earthquake. All children were exposed to serious direct threats to life, including witnessing mutilating injuries, agonizing screams of distress, and cries for help. Children were selected based on exposure to therapy, not based on diagnosis or symptom score. No children were receiving psychotropic medicine or other mental health treatment. Two schools closest to the study staff's clinics were chosen for treatment and two other schools served as the control condition. Participants participated in four group sessions (30 minutes) and two individual sessions (60 minutes) of TF-CBT over 3 weeks. Subgroup comparisons included comparing the effectiveness of the intervention of both PTSD and depression symptoms for boys versus girls. The follow-up assessment was made 1.5 years after the baseline assessment.

Table 58 Trauma-focused cognitive behavioral therapy versus usual care: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study design and duration | Comparison Groups | Baseline Number | Risk of Bias
Goenjian, et al., 1997^51^ | Male and female students in grades 6 and 7 from 4 schools in Gumri, Armenia | Natural disasters Sex | Prospective cohort 12 weekly sessions of 1.5 hours (18 hours total) | G1: Trauma-focused cognitive behavioral therapy G2: Comparison schools | Randomized G1: 35 G2: 29 Analyzed (baseline): G1: 35 G2: 19 Analyzed (1.5-year followup): G1: 34G2: 29 | Medium

G = group

The second trial,71 also described in the prior publication from the same authors detailed in the KQ 2 section above,66 recruited 403 male and female school children in Poso, Indonesia, with mean ages of 10.08 and 9.78 for the treatment and wait-list groups, respectively (Table 59). Each participant had exposure to one or more traumatic events (mainly resulting from poverty and political violence/instability) as well as significant PTSD symptoms (at least 11) and anxiety complaints (at least 5). The treatment group received 15 sessions over 5 weeks that consisted of trauma-processing activities, cooperative play, and creative expressive elements delivered in groups at school. The comparison group consisted of wait-list controls who received the intervention after the study concluded. Assessments compared across subgroups were made at 6 months postintervention and included child-reported PTSD symptoms (Post-Traumatic Stress Scale) and functional impairment (contextually constructed 10-item checklist). Subgroup comparisons included age, exposure to violence, and sex.

Table 59 Cognitive behavioral therapy/creative expressive school-based group intervention versus wait-list control: study characteristics

Author, Year | Inclusion Criteria (Sex and Age Group) | Type of Trauma/Subgroup | Study Design and Duration | Comparison Groups | Baseline Number | Risk of Bias
Tol, et al., 2010^71^ | Male and female school children in Poso, Indonesia (mean age 10.08 and 9.78 for treatment and wait-list groups, respectively) who were exposed to ≥1 events, or had significant (≥11) PTSD symptoms and anxiety complaints (≥5) | Poverty and political violence/instability Age, exposure to violence, sex | Cluster-RCT with wait-list control 15 sessions over 5 weeks | G1: School-based group intervention including CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements G2: Wait-list control | Randomized: 403 G1: 182 G2: 221 1-week followup G1: 182 G2: 211 6-month followup G1: 177 G2: 191 Analyzed: G1: 182 G2: 221 | Medium

CBT = cognitive behavioral therapy; G = group; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

The applicability of these interventions is limited to the specific populations recruited for each study. Thus, the TF-CBT study findings51 are applicable to children in resource-poor settings suffering from severe natural disasters who may not have significant post-traumatic stress symptoms but are at high risk for developing these symptoms. The findings of the school-based intervention66 apply to younger school-age students exposed to poverty and political violence/instability with significant PTSD and anxiety symptoms.

### Key Points

To address KQ 3, we found two studies that examined subgroup differences in the effectiveness or efficacy of interventions targeting exposure to trauma (n=1) and exposed to trauma and already experiencing symptoms (n=1).

#### Trauma-Focused Cognitive Behavioral Therapy Versus No Treatment

We identified one prospective cohort study comparing the effectiveness of a TF-CBT school-based intervention versus no treatment.51 This study targeted children in the sixth and seventh grades (mean age=13.2 years) 1.5 years after exposure to an earthquake resulting in serious direct threats to life, including witnessing mutilating injuries, agonizing screams of distress, and cries for help. Two schools closest to the study staff's clinics were chosen for treatment and two other schools served as the control condition. The effectiveness of the intervention on outcomes was compared for girls versus boys.

- PTSD symptoms:
  – Sex: There were not significant differences in the effectiveness of the intervention on PTSD symptoms by sex (insufficient SOE).
- Depression symptoms:
  – Sex: There were not significant differences in the effectiveness of the intervention on PTSD symptoms by sex (insufficient SOE).

#### Cognitive Behavioral Therapy /Creative Expressive School-Based Group Intervention Versus Wait-List Control

We identified one RCT comparing the efficacy of a CBT/creative expressive school-based group intervention with that of a wait-list control.71 This study targeted children exposed to poverty or political violence/instability war who had significant PTSD and anxiety symptoms. Subgroup differences examined included age, exposure to violence, and sex.

- PTSD symptoms:
  – Age: There were no significant differences in efficacy of the intervention on PTSD symptoms by age (insufficient SOE).
  – Exposure to violence: There were no significant differences in efficacy of the intervention on PTSD symptoms by exposure to violence (insufficient SOE).
  – Sex: Intervention effect on reducing PTSD symptoms was significantly greater for female than male students (low SOE).
- Functional impairment:
  – Age: There were no significant differences in efficacy of the intervention on functional impairment by age (insufficient SOE).
  – Exposure to violence: There were no significant differences in efficacy of the intervention on functional impairment by exposure to violence (insufficient SOE).
  – Sex: Intervention effect on reducing functional impairment was significantly greater for female than male students (low SOE).

### Detailed Synthesis

#### Trauma-Focused Cognitive Behavioral Therapy Versus No Treatment

One prospective cohort study51 recruited children from four schools in an area hit by an earthquake to receive TF-CBT or no treatment and compared intervention effects on PTSD and depression symptoms by sex. This trial found that no significant differences in the effectiveness of the intervention on PTSD or depression symptoms by sex (Table 60). We graded the SOE as insufficient for outcomes with nonsignificant findings in effectiveness of the intervention by subgroup (sex), given that only one study met inclusion criteria for this intervention (Table 61).

Table 60 Trauma-focused cognitive behavioral therapy versus no treatment: results

Author, Year | Comparison Groups | Subgroups Examined | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Goenjian, et al., 1997^51^ | G1: TF-CBT G2: comparison schools (no treatment) | Sex | No significant differences in effectiveness of intervention on PTSD symptoms by sex. (CPTSD-RI, range=0-68) 1.5 years postintervention Sex (mean change) G1 male: -11.2 G1 female:-14.0 G2 male: 2.4 G2 female: 8.4 Interaction term sex* treatment not significant | No significant differences in effectiveness of intervention on depression symptoms by sex. (DSRS, range=0-72) 1.5 years postintervention Sex (mean change) G1 male: -2.5 G1 female: 0 G2 male: 5.0 G2 female: 4.9 Interaction term Sex by treatment not significant | NR | NR

CPTSD-RI = Child Post-Traumatic Stress Scale-Reaction Index; DSRS = Depression Self-Rating Scale; G = group; NR = not reported; PTSD = post-traumatic stress disorder; TF-CBT = trauma-focused cognitive behavioral therapy

Table 61 Cognitive behavioral therapy/creative expressive school-based group intervention versus wait-list control: results

Author, Year | Comparison Groups | Subgroups Examined | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Tol, et al., 2010^71^ | G1: School-based group intervention including CBT techniques, trauma-processing activities, cooperative play, and creative expressive elements G2: Wait-list control | Age, exposure to violence, sex | No significant differences in efficacy of intervention on PTSD symptoms by age or level of exposure to violence Intervention effect on reducing PTSD symptoms significantly greater for female than male students (Child Post-Traumatic Stress Scale, range=0-68) 6 months postintervention Age β (95% CI) G1: 0.018 (-0.017 to 0.053) G2: -0.012 (-0.047 to 0.023) p=0.19 Exposure β (95% CI) G1: -0.018 (-0.042 to 0.006) G2: -0.024 (-0.048 to 0.000) p=0.54 Sex (female) β (95% CI) G1: -0.090 (-0.161 to -0.019) G2: 0.060 (-0.011 to 0.131) p=0.004 | NR | NR | No significant differences in efficacy of intervention on functional impairment by age or level of exposure to violence Intervention effect on reducing functional impairment significantly greater for female than male student (Child-reported through contextually constructed 10-item checklist, range=10-40) 6 months postintervention Age β (95% CI) G1: 0.018 (-0.006 to 0.042) G2: 0.000 (-0.024 to 0.024) p=0.346 Exposure β (95% CI) G1: -0.012 (-0.036 to 0.012) G2: -0.006 (-0.018 to 0.006) p=0.698 Gender (female) β (95% CI) G1: -0.120 (-0.179 to -0.061) G2: 0.012 (-0.047 to 0.071) p=0.004

CBT = cognitive behavior therapy; CI = confidence interval; G = group; NR = not reported; PTSD = post-traumatic stress disorder

- PTSD symptoms:
  – Sex: There were not significant differences in the effectiveness of the intervention on PTSD symptoms by sex (insufficient SOE).
- Depression symptoms:
  – Sex: There were not significant differences in the effectiveness of the intervention on PTSD symptoms by sex (insufficient SOE).

##### Cognitive Behavioral Therapy/Creative Expressive School-Based Group Intervention Versus Wait-List Control

One RCT71 recruited children with a mean age of 10 years to receive a school-based group intervention based on CBT and creative expressive principles and compared the intervention effects by age, exposure to violence, and sex. This trial found no significant differences in the efficacy of the intervention on PTSD symptoms or functional impairment by age or exposure to violence. Females, however, had a significantly better response to treatment than males in terms of reducing PTSD symptoms and reducing functional impairment (Table 62). We graded the SOE as low for outcomes with significant differences in efficacy of the intervention by subgroups (sex for PTSD symptoms and functional impairment) and insufficient for outcomes with nonsignificant findings in efficacy of the intervention by subgroup (age and exposure to violence for PTSD symptoms and functional impairment), given that only one study met inclusion criteria for this intervention (Table 62).

Table 62 Strength of evidence for Key Question 3: subgroup comparisons

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Subgroup | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TF-CBT vs. no treatment | 1; 64 (53) | PTSD symptoms | Sex | Medium | Unknown | Direct | Imprecise | No significant differences in effectiveness of intervention on PTSD symptoms by sex (p=NS) Insufficient
TF-CBT vs. no treatment | 1; 64 (53) | Depression symptoms | Sex | Medium | Unknown | Direct | Imprecise | No significant differences in effectiveness of intervention on depression symptoms by sex (p=NS) Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | PTSD symptoms | Age | Medium | Unknown | Direct | Imprecise | No significant differences in efficacy of intervention on PTSD symptoms by age or level of exposure to violence (G1: 0.018 [-0.017 to 0.053], G2: -0.012 [-0.047 to 0.023]) Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | PTSD symptoms | Exposure to violence | | | | Imprecise | No significant differences in efficacy of intervention on PTSD symptoms by age or level of exposure to violence (G1: -0.018 [-0.042 to 0.006], G2: -0.024 [-0.048 to 0.000]) Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | PTSD symptoms | Sex | | | | Precise | Intervention effect on reducing PTSD symptoms significantly greater for female than male students (G1: -0.090 [-0.161 to -0.019], G2: 0.060 [-0.011 to 0.131]) Low
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | Functional Impairment (child-reported) | Age | Medium | Unknown | Direct | Imprecise | No significant differences in efficacy of intervention on functional impairment by age or level of exposure to violence (G1: 0.018 [-0.006 to 0.042], G2: 0.000 [-0.024 to 0.024]) Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | Functional Impairment (child-reported) | Exposure to violence | | | | Imprecise | No significant differences in efficacy of intervention on functional impairment by age or level of exposure to violence (G1: -0.012 [-0.036 to 0.012], G2: -0.006 [-0.018 to 0.006]) Insufficient
CBT/creative expressive school-based group intervention vs. wait-list control | 1; 403 (403) | Functional Impairment (child-reported) | Sex | | | | Precise | Intervention effect on reducing functional impairment significantly greater for female than male students (G1: -0.120 [-0.179 to -0.061], G2: 0.012 [-0.047 to 0.071]) Low

CBT = cognitive behavioral therapy; G = group; NS = not significant; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; TF-CBT = trauma-focused cognitive behavioral therapy

## Key Question 4 Harms in Interventions Targeting Children Exposed to Trauma: Psychotherapy Interventions

### Description of Included Studies

We identified nine studies focusing on psychotherapy targeting children exposed to trauma and/or experiencing traumatic stress symptoms. We present retention rates for all nine psychotherapy studies in Table 63: low rates of retention could be a proxy measure for unidentified adverse events or harms.

Table 63 Psychotherapy interventions: study characteristics

Author, Year | Intervention Type | Study Addressed Harms? (Yes/No) | Number Randomized Number Analyzed | Retention %
Berkowitz, et al., 2011^53^ | CFTSI G1: CFTSI G2: Wait-list control | No | Randomized total: 112 Analyzed total: 106 (6 excluded after randomization) G1: 53 G2: 53 3-month followup: 83 G1: NR G2: NR | Total: 78.3% G1: NR G2: NR Study reported no difference in retention between G1 and G2
Smith, et al., 2007^58^ | TF-CBT G1: TF-CBT G2: Wait-list control | Yes No adverse events reported | Randomized total: 38 Analyzed: 24 (9 excluded after randomization) G1: 12 G2: 12 All dropouts occurred prior to initiation of intervention | Total: 82.8% G1: NR G2: NR No dropouts in either group after initiation of intervention
Zehnder, 2010^50^ | Early psychological intervention G1: Early psychological intervention G2: Usual care | No | Randomized total: 101 G1: 51 G2: 50 Analyzed at 2 months: 100 G1: 50 G2: 50 Analyzed at 6 months: 99 G1: 49 G2: 50 | 2-month total: G1: 98.0% G2: 100% 6-month total: G1: 96.1% G2: 100%
Ahrens, et al., 2002^59^ | CPT G1: CPT G2: Wait-list control | No | Randomized total: 38 G1: 19 G2: 19 Analyzed total: 38 G1: 19 G2: 19 | Total: 100% G1: 100% G2: 100%
Kemp, et al., 2010^63^ | EMDR G1: EMDR G2: Wait-list control | No | Randomized total: 27 G1: 13 G2: 14 Analyzed total: 24 G1: 12 G2: 12 | Overall: 88.9% G1: 92.3% G2: 85.7%
Catini, et al., 2009^60^ | G1: Narrative exposure therapy (KIDNET) G2: Meditation-relaxation therapy | No | Randomized total: 31 G1: 16 G2: 15 Analyzed at 1 month: 31 G1: 16 G2: 15 Analyzed at 6 months: 30 G1: 16 G2: 14 | 1 month overall: 100% G1: 100% G2: 100% 6 months overall: 96.8% G1: 100% G2: 93.3%
Salloum, et al., 2008^61^ | G1: Group grief- and trauma-focused intervention G2: Individual grief- and trauma-focused intervention | No | Randomized total: 56 G1: 28 G2: 28 Analyzed total: 45 G1: 23 G2: 22 | Overall: 80.4% G1: 82.1 G2: 78.6 Completers did not differ significantly from noncompleters in reported post-traumatic stress (p=0.787) or depression (p=0.286)
Salloum, 2012^62^ | G1: Group grief- and trauma-focused intervention with coping skills and trauma narrative processing G2: Individual grief- and trauma-focused intervention with coping skills only | No | Randomized total: 72 G1: 39 G2: 33 Analyzed at post-treatment: 66 G1: 34 G2: 32 Analyzed at 3 months: 64 G1: 34 G2: 30 Analyzed at 6 months post-treatment: 64 G1: 34 G2: 30 | Overall: 80.4% G1: 82.1 G2: 78.6 Completers did not differ significantly from noncompleters in reported post-traumatic stress (p = 0.787) or depression (p = 0.286)
Ford, 2012 49 | Emotion regulation therapy G1: TARGET (emotion regulation therapy) G2: ETAU (relational supportive therapy) | No | Randomized total: 59 G1: 33 G2: 26 Analyzed total: 46 G1: 26 G2: 20 | Overall: 78.0% G1: 78.8% G2: 76.9%

CBITS = Cognitive Behavioral Intervention for Trauma in Schools; CFTSI = Child and Family Traumatic Stress Intervention; CPT = cognitive processing therapy; EMDR = eye movement desensitization and reprocessing; ETAU = enhanced treatment as usual; G = group; KIDNET = Narrative Exposure Therapy for children; NR = not reported; TARGET = Trauma Affect Regulation: Guide for Education and Therapy; TF-CBT = trauma-focused cognitive behavioral therapy

Of the nine studies, only one study mentioned possible harms or adverse effects for KQ 4.^58^ This study examined TF-CBT versus a wait-list control group (described in detail previously).

#### Key Points

- Attrition for psychotherapy interventions: Because attrition may be an indicator of undetected harms, we evaluated the retention rates in intervention and control groups for nine psychotherapy interventions. The studies reported small or nonsignificant differences in retention between intervention and control groups. The small sample sizes and absence of information on reasons for attrition in many included studies makes it challenging to interpret this evidence as suggesting equivalence: we therefore grade the evidence as insufficient because the studies do not all always attribute reasons for discontinuation.
- Overall adverse events for TF-CBT: Participants in the TF-CBT in both intervention and control groups did not exhibit any adverse events. We rated the evidence as insufficient because the small sample size was not likely to be powered adequately to test for equivalence in adverse events.

#### Detailed Synthesis

Harms in Trauma-Focused Cognitive Behavioral Therapy Versus Wait-List Control

One RCT found no mental health harms, physical harms, or other adverse events in either intervention or control study arm (Table 64); we graded the evidence as insufficient (Table 65).

Table 64 Psychotherapy interventions: results

Author, Year | Intervention Type | Mental Health Harms | Physical Harms | Other Effects
Smith, et al., 2007^58^ | TF-CBT | No adverse effects reported | No adverse effects reported | No adverse effects reported

TF-CBT = trauma-focused cognitive behavioral therapy

Table 65 Strength of evidence for Key Question 4: psychotherapy interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TF-CBT vs. wait-list control | 1; 38 (24) | Overall adverse events/harms | RCT Low | Unknown | Direct | Imprecise | No adverse events found with TF-CBT or wait-list control; significance was not reported Insufficient

KQ = Key Question; RCT = randomized controlled trial; TF-CBT = trauma-focused cognitive behavioral therapy

## Key Question 4 Harms in Interventions Targeting Children Exposed to Trauma: School-Based Interventions

### Harms in School-Based Interventions

We found nine studies examining KQ 1 and KQ 2 with school-based interventions. Table 66 summarizes these interventions and includes information on attrition: high attrition could be a proxy measure for unidentified adverse events or harms such as retraumatization.

Table 66 School-based interventions: study characteristics

Author, Year | Intervention Type | Study Addressed Harms? (Yes/No) | Number Randomized Number Analyzed | Retention %
Berger, et al., 2009^54^ | ERASE Stress G1: ERASE Stress G2: Wait-list control | No | Randomized total: 166 G1: 84 G2: 82 Analyzed total: 166 G1: 84 G2: 82 | Total: 100% G1: 100% G2: 100%
Gelkopf, et al., 2009^55^ | ERASE Stress G1: ERASE Stress G2: Wait-list control | No | Randomized total: 107 G1: 58 G2: 49 Analyzed: 107 G1: 58 G2: 49 | Total: 100% G1: 100% G2: 100%
Stein, et al., 2003^64^ | CBITS G1: CBITS G2: Wait-list control | No | Randomized total: 126 G1: 61 G2: 65 Analyzed, 3-month, total: 117 G1: 54 G2: 63 6-month followup: 113 G1: NR G2: NR | 3-month total: 92.9% G1: 88.5% G2: 96.9% 6-month total: 89.6% G1: NR G2: NR
Jaycox, 2009^47^ | CBITS G1: SSET (CBITS) G2: Wait-list control | No | Randomized total: G1: 39 G2: 39 Analyzed total: G1: 39 G2: 37 | Total: G1: 100% G2: 94.9%
Layne, et al., 2008^65^ | TGCT G1: TGCT + classroom-based psychoeducation and skills training G2: Classroom-based psychoeducation and skills training | Yes | Randomized total: 159 G1: 77 G2: 82 Completed post-treatment assessment total: 127 G1: 66 G2: 61 4-month followup: 67 G1: 36 G2: 31 | Post-treatment assessment: 79.4% G1: 85.7% G2: 74.4% 4-month followup: 41.9% G1: 46.8% G2: 37.8%
Berger, et al., 2007^56^ | OTT G1: OTT G2: Wait-list control | No | Randomized total: 142 G1: 70 G2: 72 Analyzed total: 142 G1: 70 G2: 72 | Total: 100% G1: 100% G2: 100%
Tol, et al., 2008;^66^ Tol, et al., 2010^71^ | CBT/creative expressive school-based group Intervention G1: Intervention G2: Wait-list control | No | Randomized total: 403 G1: 182 G2: 221 Analyzed at 1-week total: 393 G1: 182 G2: 211 6-month followup: 368 G1: 177 G2: 191 | 1-week total: 97.5% G1: 100% G2: 95.5% 6-month total: 91.3% G1: 97.3% G2: 86.4%
Tol et al., 2012^67^ | CBT/creative expressive school-based group intervention G1: School-based group intervention including CBT and creative expressive elements G2: Wait-list control | No | Randomized total: 399 G1: 199 G2: 200 Only two participants were not African American at randomization, so these two participants were not analyzed at baseline or in any of the followup Analyzed at 1-week and 3-month followup: 397 G1: 198 G2: 199 | Total: 100% G1: 100% G2: 100%
Goenjian et al., 1997,^51^ Goenjian et al., 2005^52^ | TF-CBT G1: School-based TF-CBT G2: Comparison schools | No | Randomized total: 64 G1: 35 G2: 29 Analyzed at 18 months: 64 G1: 35 G2: 29 Analyzed at 3 years: 62 G1: 35 G2: 27 | 18-month total: 100% G1: 100% G2: 100% 3-year total: 96.9% G1: 100% G2: 93.1%

CBT = cognitive behavioral therapy; CBITS = Cognitive Behavioral Intervention for Trauma in Schools; ERASE Stress = Enhancing Resilience among Students Experiencing Stress; G = group; NR = not reported; OTT = Overshadowing the Threat of Terrorism; SSET = Support for Students Exposed to Trauma; TF-CBT = trauma-focused cognitive behavioral therapy; TGCT = trauma and grief component therapy for adolescents

Of the nine school-based interventions, only one study mentioned possible harms or adverse effects for KQ 4.^65^ This trial evaluated an intervention of TGCT with classroom-based psychoeducation and skills training versus the classroom-based psychoeducation and skills training alone and addressed KQ 4.

The authors calculated the Reliable Change Index (RCI) for post-traumatic stress, depression, traumatic grief, and existential grief in order to quantify the number of reliably deteriorated cases. The RCI is based on the standard error (SE) of the difference between two test scores and denotes whether differences in test scores (with chance of error typically calculated at p<.05) reflect statistically reliable (i.e., significant) change instead of random fluctuation. RCI values consist of a difference score (e.g., pretreatment minus post-treatment, pretreatment minus followup) divided by the SE of the difference set at p<.05 and can be used to classify study participants according to treatment response on a given outcome variable. Those whose difference scores are positive and exceed the SE are reliably improved cases, those whose difference scores are negative and exceed the SE are reliably deteriorated cases, and those whose difference scores do not exceed the SE are treatment nonresponders. An RCI score was calculated for each participating student on each measured outcome variable. Those who reliably deteriorated were included under harms of the study intervention compared with the comparator.

#### Key Points

- Adherence for school-based interventions: Because adherence may be an indicator of undetected harms, we evaluated the adherence rates in intervention and control groups for six school-based interventions. The studies reported small differences in adherence between intervention and control groups. The small sample sizes and absence of information on reasons for low adherence in many included studies makes it challenging to interpret this evidence as suggesting equivalence: we therefore grade the evidence as insufficient because the studies do not all always attribute reasons for discontinuation or low adherence.
- Posttraumatic stress for TGCT: Participants in the TGCT intervention group did not exhibit any significant increase in reliable deterioration in post-traumatic stress. Because of the small sample size with wide confidence intervals, we graded the strength of evidence (SOE) as insufficient for the results of one study with imprecise estimates.
- Depression for TGCT: Participants in the TGCT intervention group did not exhibit any significant increase in reliable deterioration in depression. Because of the small sample size with wide confidence intervals, we graded the SOE as insufficient for the results of one study with imprecise estimates.
- Traumatic grief for TGCT: Participants in the TGCT intervention group did not exhibit any significant increase in reliable deterioration in traumatic grief. Odds ratios and confidence intervals were unable to be calculated owing to lack of participants with reliable deterioration. We graded the SOE as insufficient for the results of one study with imprecise estimates.
- Existential grief for TGCT: Participants in the TGCT intervention group did not exhibit any significant increase in reliable deterioration in existential grief. Odds ratios and confidence intervals were unable to be calculated owing to lack of participants with reliable deterioration. We graded the SOE as insufficient for the results of one study with imprecise estimates.

#### Detailed Synthesis

##### Harms in Trauma and Grief Component Therapy for Adolescents with Classroom-Based Psychoeducation and Skills Training Versus Classroom-Based Psychoeducation and Skills Training Control

One RCT65 found no significant differences in reliable deterioration for post-traumatic stress, depression, traumatic grief, and existential grief by study arm at post-treatment or at 4-month followup (Table 67). Because the evidence on post-traumatic stress, depression, traumatic grief, and existential grief comes from a single study with imprecise estimates, we graded the SOE as insufficient (Table 68).

Table 67 School-based interventions: results

Author, Year | Intervention Type | Mental Health Harms | Physical Harms | Other Effects
Layne, et al., 2008^65^ | TGCT | No significant differences in “reliable deterioration” (RCI) for post-traumatic stress (UCLA Reaction Index-Revised Total Scale Score) G1: 3/66 significantly deteriorated G2: 6/61 significantly deteriorated Odds ratio for reliable deterioration at post-treatment = 0.46 (95% CI, 0.12 to 1.77) Odds ratio not calculable at 4-month followup because no reliably deteriorated cases No significant differences in reliable deterioration for depression (Depression Self-Rating Scale) G1: 6/65 significantly deteriorated G2; 10/60 significantly deteriorated Odds ratio for reliable deterioration at post-treatment = 0.55 (95% CI, 0.21 to 1.43) Odds ratio not calculable at 4-month followup because no reliably deteriorated cases No significant differences in reliable deterioration for traumatic grief (UCLA Grief Index, Traumatic Grief Subscale) G1: 0/40 significantly deteriorated G2: 2/24 significantly deteriorated Odds ratio not calculable because no reliably deteriorated cases at post-treatment No significant differences in reliable deterioration for existential grief (UCLA Grief Index, Existential Grief Subscale) G1: 0/40 significantly deteriorated G2: 4/26 significantly deteriorated Odds ratio not calculable because no reliably deteriorated cases at post-treatment | NR | NR

CI = confidence interval; G = group; NR = not reported; RCI = Reliable Change Index; TGCT = trauma and grief component therapy for adolescents; UCLA = University of California, Los Angeles

Table 68 Strength of evidence for Key Question 4: trauma and grief component therapy for adolescents

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
TGCT with classroom-based psychoeducation and skills training vs. classroom-based psychoeducation and skills | 1; 160 (127) | Deterioration in post-traumatic stress | RCT Medium | Unknown | Direct | Imprecise | No greater deterioration in post-traumatic stress; results were not found to be significant Insufficient
TGCT with classroom-based psychoeducation and skills training vs. classroom-based psychoeducation and skills | 1; 160 (127) | Deterioration in depression | RCT Medium | Unknown | Direct | Imprecise | No greater deterioration in depression; results were not found to be significant Insufficient
TGCT with classroom-based psychoeducation and skills training vs. classroom-based psychoeducation and skills | 1; 160 (127) | Deterioration in traumatic grief | RCT Medium | Unknown | Direct | Imprecise | No greater deterioration in traumatic grief; results were not found to be significant Insufficient
TGCT with classroom-based psychoeducation and skills training vs. classroom-based psychoeducation and skills | 1; 160 (127) | Deterioration in existential grief | RCT Medium | Unknown | Direct | Imprecise | No greater deterioration in existential grief; results were not found to be significant Insufficient

RCT = randomized controlled trial; TGCT = trauma and grief component therapy for adolescents

## Key Question 4 Harms in Interventions Targeting Children Exposed to Trauma: Medication Interventions

### Description of Included Studies

Four studies evaluated medication interventions. Table 69 describes retention rates for all medication interventions.

Table 69 Medication management harms: study characteristics

Author, Year | Intervention Type | Study Addressed Harms? (Yes/No) | Number Randomized Number Analyzed | Retention %
Robb, et al., 2010^70^ | Sertraline G1: Sertraline G2: Placebo | Yes | Randomized total: 131 G1: 67 G2: 62 Analyzed total: 128 G1: 67 G2: 61 Completed study: 98 G1: 47 G2: 51 | Total: 76.0% G1: 70.1% G2: 82.3% Study looked at dropouts due to medication adverse events
Nugent, et al., 2010^57^ | Propranolol G1: Propranolol G2: Placebo | No | Randomized total: 29 G1: 14 G2: 15 Analyzed: 26 G1: 12 G2: 14 6 patients were nonadherent | Total: 68.9% G1: 64.3% G2: 73.3%
Robert, et al., 2008^69^ | G1: Imipramine G2: Fluoxetine G3: Placebo | Yes | Randomized total: 62 G1: 21 G2: 19 G3: 22 Analyzed total: 60 G1: 20 G2: 18 G3: 22 | Total: 96.8% G1: 95.2% G2: 94.7% G3: 100% Dropouts were due to consent and staffing issues, not to adverse effects of medications
Robert, et al., 1999^68^ | G1: Imipramine G2: Placebo | Yes | Randomized total: 25 G1: 12 G2: 13 Analyzed total: 25 G1: 12 G2: 13 | Total: 100% G1: 100% G2: 100%

G = group

Three of four medication studies mentioned possible harms or adverse effects for KQ 4.^68-70^ One study evaluated harms for sertraline versus placebo, including overall adverse events, dropouts because of adverse events, any severe adverse events, any serious adverse events, increase in suicidality ratings, active suicidality, disturbed sleep, agitation, headache, abdominal pain, nausea, pharyngitis, vomiting, accidental injury, respiratory tract infections, diarrhea, dizziness, hyperkinesis, rhinitis, dry mouth, and dysmenorrhea.70 One study68 recorded any adverse events for imipramine versus usual care in the form of chloral hydrate medication for sleep. Another study69 evaluated adverse events in a trial comparing outcomes for children treated with imipramine, fluoxetine, or a placebo.

#### Key Points: Imipramine Versus Chloral Hydrate or Placebo

- Retention: The studies did not report differential dropout rates; we graded the evidence as insufficient.
- Overall adverse events or harms: Participants in the imipramine intervention group did not exhibit any adverse events or harms in two studies.68,69 Because of the small sample sizes of each study, short duration of treatment, no significance given, and imprecise estimates, we graded the SOE as insufficient for the results.

#### Key Points: Fluoxetine Versus Placebo

- Retention: The study reported a 5.3 percent difference in dropouts; we graded the evidence, based on a single small study, as insufficient.
- Overall adverse events or harms: Participants in the fluoxetine intervention group did not exhibit any adverse events or harms in the study69;we graded the evidence, based on a single small study, as insufficient.

#### Key Points: Sertraline Versus Placebo

A single study comparing sertraline to placebo reported numerous adverse events but no significant differences between study arms. As a result, we graded the following outcomes as insufficient for:

- Any adverse events
- Disturbed sleep
- Agitation
- Headache/abdominal pain
- Nausea
- Pharyngitis
- Vomiting
- Accidental injury
- Respiratory tract infections
- Diarrhea
- Dizziness
- Hyperkinesis
- Rhinitis

The study also reported some incidents of severe adverse events (undefined), serious adverse events (undefined), dry mouth, and dysmenorrhea among patients taking sertraline compared with none for patients in the placebo arm. The authors did not run statistical tests that adjusted for zero-cell counts in the placebo arm. The study reported higher incidents of dropouts due to adverse events, increased suicidality ratings, and active suicidality in the sertraline arm compared with the placebo arm but did not report the results of statistical significance tests. We rated these outcomes also as insufficient.

#### Detailed Synthesis: Imipramine

##### Harms in Imipramine Versus Chloral Hydrate or Placebo

Two RCTs68,69 found no mental health, physical, or other adverse events or harms in either study arm (Table 70). We graded the SOE as low for harms. Two studies met inclusion criteria; however, they were small, of short duration, without significance, and lacking precision in the estimates of effect (Table 71).

Table 70 Medication management: results

Author, Year | Intervention Type | Mental Health Harms | Physical Harms | Other Effects
Robb, et al., 2010^70^ | G1: Sertraline G2: Placebo | Increased suicidality G1: 6 (9.0%) G2: 4 (6.5%) Risk ratio, NR Active suicidality G1: 1 G2: 0 Risk ratio, NR No significant increased risk of disturbed sleep G1: 7 (10.4%) G2: 8 (12.9%) Risk ratio, 0.81; 95% CI, 0.31 to 2.10 No significant increased risk of agitation G1: 4 G2: 2 Risk ratio=1.85, 95% CI, 0.35 to 9.75 | No significant increased risk of headache G1: 17 (25.4%) G2: 12 (19.4%) Risk ratio, 1.31; 95% CI, 0.68 to 2.52 No significant increased risk of abdominal pain G1: 10 (14.9%) G2: 13 (21.0%) Risk ratio, 0.71; 95% CI, 0.34 to 1.50 No significant increased risk of nausea G1: 9 (13.4%) G2: 6 (9.7%) Risk ratio, 1.39; 95% CI, 0.52 to 3.67 No significant increased risk of pharyngitis G1: 7 (10.4%) G2: 6 (9.7%) Risk ratio, 1.08; 95% CI, 0.38 to 3.04 No significant increased risk of vomiting G1: 9 (13.4%) G2: 3 (4.8%) Risk ratio, 2.78; 95% CI, 0.79 to 9.79 No significant increased risk of accidental injury G1: 6 (9.0%) G2: 6 (9.7%) Risk ratio, 0.93; 95% CI, 0.32 to 2.72 No significant increased risk of respiratory tract infection G1: 6 (9.0%) G2: 4 (6.5%) Risk ratio, 1.39; 95% CI, 0.41 to 4.69 No significant increased risk of diarrhea G1: 6 (9.0%) G2: 3 (4.8%) Risk ratio, 1.85, 95% CI, 0.48 to 7.08 No significant increased risk of dizziness G1: 3 (4.5%) G2: 5 (8.1%) Risk ratio, 0.56, 95% CI, 0.14 to 2.23 No significant increased risk of hyperkinesis G1: 7 (10.4%) G2: 1 (1.6%) Risk ratio, 6.48, 95% CI, 0.82 to 51.16 No significant increased risk of rhinitis G1: 5 (7.5%) G2: 1 (1.6%) Risk ratio, 4.63, 95% CI, 0.56 to 38.51 Dry mouth G1: 5 (7.5%) G2: 0 (0%) Risk ratio, NC Dysmenorrhea G1: 0 (0%) G2: 2 (5.3%) Risk ratio, NC | No significant increased risk of any adverse events G1: 51 (76.1%) G2: 47 (75.8%) Risk ratio, 1.00; 95% CI, 0.83 to 1.22 Any severe adverse event G1: 5 (7.5%) G2: 0 (0%) Risk ratio, NC Any serious adverse event (hospitalization for agitation and hyperactivity; 12-year-old with herpes zoster with hysterical reaction and suicidal ideation) G1: 2 (3.0%) G2: 0 (0%) Risk ratio, NC Dropouts due to adverse events from study medication G1: 5 (7.5%) G2: 2 (3.2%) Risk ratio, NR
Robert, et al., 2008^69^ | G1: Imipramine G2: Fluoxetine G3: Placebo | Authors reported no adverse events | Authors reported no adverse events | Authors reported no adverse events
Robert, et al., 1999^68^ | G1: Imipramine G2: Placebo | Authors reported no adverse events | Authors reported no adverse events | Authors reported no adverse events

CI = confidence interval; G = group; NC = not calculable, NR = not reported

Table 71 Strength of evidence for Key Question 4: medication interventions

Intervention | Number of Studies; Subjects (Analyzed) | Outcome | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect and Strength of Evidence
Imipramine medication vs. chloral hydrate or placebo | 2; 87 (85) | Overall adverse events/harms | RCT Medium | Consistent | Direct | Imprecise | No harms were found in either study for imipramine vs. chloral hydrate or vs. placebo. Significance was not reported for either study nor was manner of assessment. Low
Fluoxetine medication vs. placebo | 1; 62 (60) | Overall adverse events/harms | RCT Low | Unknown | Direct | Imprecise | No harms or adverse events were found in one study for fluoxetine vs. placebo. Significance was not reported nor was manner of assessment. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Overall adverse events/harms | RCT Low | Unknown | Direct | Imprecise | Risk ratio for overall adverse events with sertraline was 1.00 compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Dropouts due to adverse events | RCT Low | Unknown | Indirect | Imprecise | Sertraline with a greater than double increase in dropouts compared with placebo due to adverse events from study medication. Significance was not provided. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Disturbed sleep | RCT Low | Unknown | Direct | Imprecise | Sertraline with a risk ratio of 0.81 of disturbing sleep compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Headache | RCT Low | Unknown | Direct | Imprecise | Sertraline with a risk ratio of 1.31 of increasing headache compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Dysmenorrhea | RCT Low | Unknown | Direct | Imprecise | Sertraline had fewer episodes of dysmenorrhea compared with placebo (0 to 2). Significance was not reported. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Dry mouth | RCT Low | Unknown | Direct | Imprecise | Sertraline had 5 episodes of dry mouth compared with 0 from the placebo group. Significance was not reported. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Rhinitis | RCT Low | Unknown | Indirect | Imprecise | Sertraline had a risk ratio of 4.63 of patients having rhinitis compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Hyperkinesis | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 6.48 of increasing hyperkinesis compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Dizziness | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 0.56 of patients having dizziness compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Diarrhea | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 1.85 of patients having diarrhea compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Respiratory tract infection | RCT Low | Unknown | Indirect | Imprecise | Sertraline had a risk ratio of 1.39 in increasing respiratory tract infections compared with placebo. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Abdominal pain | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 0.71 compared with placebo of increasing abdominal pain. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Nausea | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 1.39 compared with placebo of increasing nausea symptoms. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Pharyngitis | RCT Low | Unknown | Indirect | Imprecise | Sertraline had a 1.08 risk ratio compared with placebo of increasing pharyngitis. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Vomiting | RCT Low | Unknown | Direct | Imprecise | Sertraline had a 2.78 risk ratio compared with placebo of increasing vomiting. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Accidental injury | RCT Low | Unknown | Direct | Imprecise | Sertraline had a risk ratio of 0.93 compared with place of increasing accidental injuries. 95% CI was wide and result not found to be significant. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Increased suicidality | RCT Low | Unknown | Direct | Imprecise | Sertraline had more cases of increases in suicide ratings than placebo (6 to 4). Significance was not provided. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Active suicidality | RCT Low | Unknown | Direct | Imprecise | Sertraline had 1 case of active suicidality vs. 0 cases for placebo. Significance was not provided. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Any serious adverse event | RCT Low | Unknown | Direct | Imprecise | Sertraline had 2 serious adverse events compared with 0 in the placebo group. Significance was not reported. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Any severe adverse event | RCT Low | Unknown | Direct | Imprecise | Sertraline had 5 severe adverse events compared with 0 in the placebo group. Significance was not provided. Insufficient
Sertraline medication vs. placebo | 1; 129 (128) | Agitation | RCT Low | Unknown | Direct | Imprecise | Sertraline was shown to have a risk ratio of 1.85 to increase agitation. 95% CI was wide and result not found to be significant. Insufficient

CI = confidence interval; RCT = randomized controlled trial

#### Detailed Synthesis: Fluoxetine

##### Harms in Fluoxetine Versus Placebo Control

One single small RCT69 found no mental health, physical, or other adverse events or harms in either study arm (Table 70); we graded the SOE as insufficient (Table 71).

##### Harms in Sertraline Intervention Versus Placebo Control

One RCT70 found no significant increase in overall adverse events, disturbed sleep, agitation, headache, abdominal pain, nausea, pharyngitis, vomiting, accidental injury, respiratory tract infections, diarrhea, dizziness, hyperkinesis, or rhinitis, by study arm. The study did not report tests of statistical significance for differences in study arms (favoring placebo) for dropouts due to adverse events, increase in suicidality ratings, or active suicidality. The authors reported incidents of any serious adverse events, any severe adverse events, dry mouth, and dysmenorrhea in the sertraline arm but none in the placebo arm (Table 70). We graded the SOE as insufficient for all reported harms (Table 71).