# References

1 Copeland WE, Keeler G, Angold A, et al. Traumatic events and posttraumatic stress in childhood. Arch Gen Psychiatry. May. 2007;64(5):577-84. [pmid: 17485609].
2 Giaconia RM, Reinherz HZ, Silverman AB, et al. Traumas and posttraumatic stress disorder in a community population of older adolescents. J Am Acad Child Adolesc Psychiatry. Oct. 1995;34(10):1369-80. [pmid: 7592275].
3 Gabbay V, Oatis MD, Silva RR, et al. Epidemiological aspects of PTSD in children and adolescents. Silva RR, editor. Posttraumatic Stress Disorder in Children and Adolescents: Handbook. New York. Norton. 2004:1-17.
4 Fergusson DM, Horwood LJ, Lynskey MT. Childhood sexual abuse and psychiatric disorder in young adulthood: II. Psychiatric outcomes of childhood sexual abuse. J Am Acad Child Adolesc Psychiatry. Oct. 1996;35(10):1365-74. [pmid: 8885591].
5 Brown J, Cohen P, Johnson JG, et al. Childhood abuse and neglect: specificity of effects on adolescent and young adult depression and suicidality. J Am Acad Child Adolesc Psychiatry. Dec. 1999;38(12):1490-6. [pmid: 10596248].
6 Saigh PA, Mroueh M, Bremner JD. Scholastic impairments among traumatized adolescents. Behav Res Ther. May. 1997;35(5):429-36. [pmid: 9149452].
7 Association AP. Diagnostic and statistical manual of mental disorders. (4th ed., text rev.) ed. Washington, DC. American Psychiatric Association. 2000.
8 Kilpatrick DG, Ruggiero KJ, Acierno R, et al. Violence and risk of PTSD, major depression, substance abuse/dependence, and comorbidity: results from the National Survey of Adolescents. J Consult Clin Psychol. Aug. 2003;71(4):692-700. [pmid: 12924674].
9 Dube SR, Anda RF, Felitti VJ, et al. Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: findings from the Adverse Childhood Experiences Study. JAMA. Dec. 2001;286(24):3089-96. [pmid: 11754674].
10 Berman SL, Kurtines WM, Silverman WK, et al. The impact of exposure to crime and violence on urban youth. Am J Orthopsychiatry. Jul. 1996;66(3):329-36. [pmid: 8827256].
11 Famularo R, Fenton T, Kinscherff R, et al. Psychiatric comorbidity in childhood post traumatic stress disorder. Child Abuse Negl. Oct. 1996;20(10):953-61. [pmid: 8902292].
12 Mehta S, Ameratunga SN. Prevalence of post-traumatic stress disorder among children and adolescents who survive road traffic crashes: A systematic review of the international literature. J Paediatr Child Health. Oct. 2012;48(10):876-85. [pmid: 21535287].
13 Scott KM, Smith DR, Ellis PM. Prospectively ascertained child maltreatment and its association with DSM-IV mental disorders in young adults. Arch Gen Psychiatry. Jul. 2010;67(7):712-9. [pmid: 20603452].
14 Scrimin S, Moscardino U, Capello F, et al. Trauma reminders and PTSD symptoms in children three years after a terrorist attack in Beslan. Soc Sci Med. Mar. 2011;72(5):694-700. [pmid: 21255892].
15 Gillespie CF, Phifer J, Bradley B, et al. Risk and resilience: genetic and environmental influences on development of the stress response. Depress Anxiety. 2009;26(11):984-92. [pmid: 19750552].
16 Cohen J. Practice Parameter for the Assessment and Treatment of Children and Adolescents With Posttraumatic Stress Disorder. J Am Acad Child Adolesc Psychiatry. Apr. 2010;49(4):414-30. [pmid: 20410735].
17 Scheeringa MS. Developmental considerations for diagnosing PTSD and acute stress disorder in preschool and school-age children. Am J Psychiatry. Oct. 2008;165(10):1237-9. [pmid: 18829877].
18 Bryant B, Mayou R, Wiggs L, et al. Psychological consequences of road traffic accidents for children and their mothers. Psychol Med. Feb. 2004;34(2):335-46. [pmid: 14982139].
19 Scheeringa MS, Wright MJ, Hunt JP, et al. Factors affecting the diagnosis and prediction of PTSD symptomatology in children and adolescents. Am J Psychiatry. Apr. 2006;163(4):644-51. [pmid: 16585439].
20 Meiser-Stedman R, Smith P, Glucksman E, et al. The posttraumatic stress disorder diagnosis in preschool- and elementary school-age children exposed to motor vehicle accidents. Am J Psychiatry. Oct. 2008;165(10):1326-37. [pmid: 18676592].
21 Zeanah CH, Gleanson MM. Proposal to include child and adolescent age related manifestations and age related subtypes for PTSD in DSM-5. Proposed revisions: disorders usually first diagnosed in infancy, childhood,or adolescence. DSM-5 development. Arlington, VA. American Psychatric Association. 2010.
22 Scheeringa MS, Zeanah CH, Drell MJ, et al. Two approaches to the diagnosis of posttraumatic stress disorder in infancy and early childhood. J Am Acad Child Adolesc Psychiatry. Feb. 1995;34(2):191-200. [pmid: 7896652].
23 Scheeringa MS, Peebles CD, Cook CA, et al. Toward establishing procedural, criterion, and discriminant validity for PTSD in early childhood. J Am Acad Child Adolesc Psychiatry. Jan. 2001;40(1):52-60. [pmid: 11195563].
24 Scheeringa MS, Zeanah CH, Myers L, et al. New findings on alternative criteria for PTSD in preschool children. J Am Acad Child Adolesc Psychiatry. May. 2003;42(5):561-70. [pmid: 12707560].
25 Task Force on Research Diagnostic Criteria: Infancy Preschool. Research diagnostic criteria for infants and preschool children: the process and empirical support. J Am Acad Child Adolesc Psychiatry. Dec. 2003;42(12):1504-12. [pmid: 14627886].
26 De Arellano MA, Waldrop AE, Deblinger E, et al. Community outreach program for child victims of traumatic events: a community-based project for underserved populations. Behav Modif. Jan. 2005;29(1):130-55. [pmid: 15557481].
27 Cohen JA, Mannarino AP, Deblinger E. Treating trauma and traumatic grief in children and adolescents. New York, NY US. Guilford Press. 2006.
28 Lieberman AF, Van Horn P, Ippen CG. Toward evidence-based treatment: child-parent psychotherapy with preschoolers exposed to marital violence. J Am Acad Child Adolesc Psychiatry. Dec. 2005;44(12):1241-8. [pmid: 16292115].
29 Linehan MM. Cognitive-behavioral treatment of borderline personality disorder. New York, NY. Guilford Press. 1993.
30 Weiner DA, Schneider A, Lyons JS. Evidence-based treatments for trauma among culturally diverse foster care youth: Treatment retention and outcomes. Children and Youth Services Review. Nov. 2009;31(11):1199-205. ISI:000271799100008.
31 Zisser A, Eyberg SM. Treating oppositional behavior in children using parent-child interaction therapy. Weisz JR, Kazdin AE, editors. Evidence-based psychotherapies for children and adolescents. 2nd ed. New York, NY. Guilford Press. 2010.
32 Eyberg S. Parent-child interaction therapy: integration of traditional and behavioral concerns. Child and Family Behavior Therapy. 1988;10(1):33-46.
33 Shapiro F. Eye movement: desensitization and reprocessing: basic principles, protocols, and procedures. 2nd ed. New York. Guilford. 2001.
34 Schultz PN, Remick-Barlow GA, Robbins L. Equine-assisted psychotherapy: a mental health promotion/intervention modality for children who have experienced intra-family violence. Health Soc Care Community. May. 2007;15(3):265-71. [pmid: 17444990].
35 Berkowitz SJ, Marans SM. The Child Development-Community Policing Program: a partnership to address the impact of violence. Isr J Psychiatry Relat Sci. 2000;37(2):103-14. [pmid: 10994294].
36 Goldman Fraser J, Lloyd SW, Murphy RA, et al. Child Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Maltreatment. Comparative Effectiveness Review No. 89. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290 2007 10056 I). Rockville, MD. Agency for Healthcare Research and Quality. MONTH YEAR. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
37 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2011. Chapters available at: www.effectivehealthcare.ahrq.gov.
38 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
39 Hartling L, Bond K, Harvey K, et al. Developing and testing a tool for the classification of study designs in systematic reviews of interventions and exposures. Methods Research Report AHRQ Publication No. 11-EHC-007. Rockville, MD. Agency for Healthcare Research and Quality. December. 2010.
40 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Comparative Effectiveness Reviews AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/final.cfm.
41 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
42 Higgins JPT, Altman DG. Assessing risk of bias in included studies. Cochrane Handbook for Systematic Reviews of Interventions. England. Wiley Blackwell. 2008:187-241.
43 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Report. (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I) AHRQ Publication No: 10-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
44 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
45 Lawrence S, De Silva M, Henley R. Sports and games for post-traumatic stress disorder (PTSD). Cochrane Database of Syst Rev. 2010;(1):CD007171. [pmid: 20091620].
46 Scheeringa MS, Weems CF, Cohen JA, et al. Trauma-focused cognitive-behavioral therapy for posttraumatic stress disorder in three-through six year-old children: a randomized clinical trial. J Child Psychol Psychiatry. Aug. 2011;52(8):853-60. [pmid: 21155776].
47 Jaycox LH, Langley AK, Stein BD, et al. Support for Students Exposed to Trauma: a Pilot Study. School Ment Health. Jun. 1. 2009;1(2):49-60. [pmid: 20811511].
48 Schauer E. Trauma Treatment for Children in War: Build-up of an evidence-based large-scale Mental Health Intervention in North-Eastern Sri Lanka. University of Konstanz. 2008.
49 Ford JD, Steinberg KL, Hawke J, et al. Randomized trial comparison of emotion regulation and relational psychotherapies for PTSD with girls involved in delinquency. J Clin Child Adolesc Psychol. 2012;41(1):27-37. [pmid: 22233243].
50 Zehnder D, Meuli M, Landolt MA. Effectiveness of a single-session early psychological intervention for children after road traffic accidents: a randomised controlled trial. Child Adolesc Psychiatry Ment Health. 2010;4:7. [pmid: 20181120].
51 Goenjian AK, Karayan I, Pynoos RS, et al. Outcome of psychotherapy among early adolescents after trauma. Am J Psychiatry. Apr. 1997;154(4):536-42. [pmid: 9090342].
52 Goenjian AK, Walling D, Steinberg AM, et al. A prospective study of posttraumatic stress and depressive reactions among treated and untreated adolescents 5 years after a catastrophic disaster. Am J Psychiatry. Dec. 2005;162(12):2302-8. [pmid: 16330594].
53 Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: secondary prevention for youth at risk of developing PTSD. J Child Psychol Psychiatry. Jun. 2011;52(6):676-85. [pmid: 20868370].
54 Berger R, Gelkopf M. School-based intervention for the treatment of tsunami-related distress in children: a quasi-randomized controlled trial. Psychother Psychosom. 2009;78(6):364-71. [pmid: 19738402].
55 Gelkopf M, Berger R. A school-based, teacher-mediated prevention program (ERASE-Stress) for reducing terror-related traumatic reactions in Israeli youth: A quasi-randomized controlled trial. J Child Psychol Psychiatry. Aug. 2009;50(8):962-71. [pmid: 19207621].
56 Berger R, Pat-Horenczyk R, Gelkopf M. School-based intervention for prevention and treatment of elementary-students' terror-related distress in Israel: a quasi-randomized controlled trial. J Trauma Stress. Aug. 2007;20(4):541-51. [pmid: 17721962].
57 Nugent NR, Christopher NC, Crow JP, et al. The efficacy of early propranolol administration at reducing PTSD symptoms in pediatric injury patients: a pilot study. J Trauma Stress. Apr. 2010;23(2):282-7. [pmid: 20419738].
58 Smith P, Yule W, Perrin S, et al. Cognitive-behavioral therapy for PTSD in children and adolescents: a preliminary randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):1051-61. [pmid: 17667483].
59 Ahrens J, Rexford L. Cognitive processing therapy for incarcerated adolescents with PTSD. J Aggression Maltreat Trauma. 2002;6(1):201-16.
60 Catani C, Kohiladevy M, Ruf M, et al. Treating children traumatized by war and Tsunami: a comparison between exposure therapy and meditation-relaxation in North-East Sri Lanka. BMC Psychiatry. 2009;9:22. [pmid: 19439099].
61 Salloum A, Overstreet S. Evaluation of individual and group grief and trauma interventions for children post disaster. J Clin Child Adolesc Psychol. Jul. 2008;37(3):495-507. [pmid: 18645741].
62 Salloum A, Overstreet S. Grief and trauma intervention for children after disaster: exploring coping skills versus trauma narration. Behav Res Ther. Mar. 2012;50(3):169-79. [pmid: 22317753].
63 Kemp M, Drummond P, McDermott B. A wait-list controlled pilot study of eye movement desensitization and reprocessing (EMDR) for children with post-traumatic stress disorder (PTSD) symptoms from motor vehicle accidents. Clin Child Psychol Psychiatry. Jan. 2010;15(1):5-25. [pmid: 19923161].
64 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. Aug. 6. 2003;290(5):603-11. [pmid: 12902363].
65 Layne CM, Saltzman WR, Poppleton L, et al. Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Sep. 2008;47(9):1048-62. [pmid: 18664995].
66 Tol WA, Komproe IH, Susanty D, et al. School-based mental health intervention for children affected by political violence in Indonesia: a cluster randomized trial. JAMA. Aug. 13. 2008;300(6):655-62. [pmid: 18698064].
67 Tol WA, Komproe IH, Jordans MJD, et al. Outcomes and moderators of a preventive school-based mental health intervention for children affected by war in Sri Lanka: a cluster randomized trial. World Psychiatry. Jun. 2012;11(2):114-22. [pmid: 22654944].
68 Robert R, Blakeney PE, Villarreal C, et al. Imipramine treatment in pediatric burn patients with symptoms of acute stress disorder: a pilot study. J Am Acad Child Adolesc Psychiatry. Jul. 1999;38(7):873-82. [pmid: 10405506].
69 Robert R, Tcheung WJ, Rosenberg L, et al. Treating thermally injured children suffering symptoms of acute stress with imipramine and fluoxetine: a randomized, double-blind study. Burns. Nov. 2008;34(7):919-28. [pmid: 18675519].
70 Robb AS, Cueva JE, Sporn J, et al. Sertraline treatment of children and adolescents with posttraumatic stress disorder: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):463-71. [pmid: 21186964].
71 Tol WA, Komproe IH, Jordans MJ, et al. Mediators and moderators of a psychosocial intervention for children affected by political violence. J Consult Clin Psychol. Dec. 2010;78(6):818-28. [pmid: 21114342].
72 Pitman RK, Sanders KM, Zusman RM, et al. Pilot study of secondary prevention of posttraumatic stress disorder with propranolol. Biol Psychiatry. Jan. 2002;51(2):189-92. [pmid: 11822998].
73 van der Kolk BA. Developmental Trauma Disorder: toward a rational diagnosis for children with complex trauma histories. Psychiatric Annals. 2005;35(5):401-8. [pmid: 19961123].
74 Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. Jun. 2004;72(3):500-10. [pmid: 15279533].
75 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Methods Guide for Comparative Effectiveness Reviews AHRQ Publication No. 11-EHC019-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2011. http://effectivehealthcare.ahrq.gov/final.cfm.
76 Woodgate RL, Degner LF. A substantive theory of Keeping the Spirit Alive: the Spirit Within children with cancer and their families. J Pediatr Oncol Nurs. May-Jun. 2003;20(3):103-19. [pmid: 12776259].
77 Rapson LM, Wells N, Pepper J, et al. Acupuncture as a promising treatment for below-level central neuropathic pain: a retrospective study. J Spinal Cord Med. Spring. 2003;26(1):21-6. [pmid: 12830964].
78 Frydenberg E, Lewis R. Boys play sport and girls turn to others: age, gender and ethnicity as determinants of coping. J Adolesc. Sep. 1993;16(3):253-66. [pmid: 8282897].
79 Jonas DE, Cusack K, Forneris CA, et al. Psychological Treatments and Pharmacological Treatments for Adults With Posttraumatic Stress Disorder (PTSD). Comparative Effectiveness Review No. 92. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290 2007 10056 I.) AHRQ Publication No. 13-EHC011. Rockville, MD. Agency for Healthcare Research and Quality. MONTH YEAR. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
80 Eli Lilly. Prozac. Drug insert from Eli Lilly. Section 12.3.
81 Eli Lilly. Prozac. Drug insert from Eli Lilly. Section 5.12.