# Methods

We conducted this review using the research methods described in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”37 Further, we used the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) Statement38 as a guide to ensure transparent reporting.

## Topic Refinement and Protocol Review

The topic nomination resulted from a public process. With Key Informant input, the RTI International-University of North Carolina at Chapel Hill (RTI-UNC) Evidence-based Practice Center (EPC) worked on clarifying the scope of the project. After we generated an analytic framework, preliminary KQs, and preliminary inclusion/exclusion criteria in the form of population, intervention, comparators, outcomes, timing, and settings (PICOTS), AHRQ posted KQs for public comment November 15, 2011, to December 13, 2011. The RTI-UNC EPC incorporated public comments on the KQs and clinical and methodological input from a Technical Expert Panel into the final research protocol, which was also posted on the AHRQ Web site on March 26, 2012.

## Literature Search Strategy

### Search Strategy

We systematically searched, reviewed, and analyzed the scientific evidence for each KQ (Appendix A). The steps taken to accomplish the literature review are described below. To identify articles relevant to each KQ, we began with a focused PubMed search on traumatic stress disorders and psychological and pharmacological therapies using a variety of terms, medical subject headings (MeSH^®^), and major headings. We limited results to children and human-only studies published from 1990 onward. We selected this time range to ensure therapeutic modalities were currently applicable. Because of limited resources, we also limited the search to studies published in English; however, this may bias the report because more studies from English-speaking countries were included. We also searched the Cochrane Library, EMBASE^®^, PsycInfo^®^, CINAHL, International Pharmaceutical Abstracts (IPA), and Web of Science (ISI) using analogous search terms. We conducted quality checks to ensure that known studies were identified by the search. If they were not, we revised and reran our searches.

AHRQ requested Scientific Information Packets (SIPs) from the developers or distributors of the interventions identified in the literature review. SIPs allow an opportunity for the intervention developers and distributors to provide the RTI-UNC EPC with both published and unpublished data that they believe should be considered for the review. The RTI-UNC EPC reviewed the information provided in the SIPs and grey literature and included studies that met all inclusion criteria and contained enough information on the research methods used for our risk-of-bias assessment.

## Inclusion and Exclusion Criteria

In Table 1, we outline the PICOTS that define the major inclusion criteria for studies in this review. In the sections below, we provide additional detail related to each of these domains as needed. At least one outcome from each included study had to relate to the assessment of trauma symptoms or syndromes. We also included findings that showed nonbeneficial outcomes associated with the intervention (e.g., no significant changes in outcomes between groups or significantly worse outcomes in the intervention group).

Table 1 Population, intervention, comparator, outcome, timing, and setting

Domain | Description
Population | Children ages 0–17 years who have been exposed to a trauma other than maltreatment, neglect, or family violence. Specific types of trauma include terrorism, community violence, war, school violence, natural disasters, medical trauma, and death of loved ones^a^ Children ages 0–17 years who have been exposed to a trauma other than maltreatment, neglect, or family violence who already are experiencing symptoms^a^
Intervention | Interventions for children exposed to trauma; - Psychotherapy (e.g., cognitive behavioral therapy, hypnotherapy, psychodynamic therapy, community- or classroom-based interventions); - Pharmacotherapy (e.g., SSRIs, TCAs, benzodiazepines, beta blockers, alpha blockers, mood stabilizers, antipsychotics, combined therapy, other therapy); Interventions for children exposed to trauma who already have symptoms; - Psychotherapy, including trauma-focused vs. nontrauma-focused groupings (e.g., cognitive behavioral therapy, parent-child interaction therapy, child-parent psychotherapy, eye movement desensitization and reprocessing, dialectical behavior therapy, complementary and alternative therapies [e.g., equine-assisted therapy], and community- or classroom-based interventions); - Pharmacotherapy (e.g., SSRIs, TCAs, benzodiazepines, beta blockers, alpha blockers, mood stabilizers, antipsychotics, combined therapy, other therapy)
Comparator | The comparison condition as defined in the respective studies, including active controls (such as usual care) and inactive controls (such as wait-list groups)
Outcome | Outcomes for studies targeting children exposed to trauma^b^; - Prevention of or reduction in traumatic stress symptoms or syndromes (e.g., PTSD, acute stress disorder, developmental trauma disorder); - Prevention of or reduction in mental health conditions or symptoms (e.g., depression, anxiety); - Prevention of or reduction in physical health conditions or symptoms (e.g., sleep disorders, eating disorders, pain, overweight or obesity, asthma, cardiovascular problems, gastrointestinal problems, headaches); - Reduction in risk-taking behaviors (including substance use), behavioral problems (including conduct disorder and ADHD), or criminal activities; - Healthy development (including improvements in interpersonal and social functioning), or reductions in the signs of developmental regression; - School-based functioning; - Improvements in quality of life; - Decreased suicidality; - Low adherence/dropouts; - Side effects; - Retraumatization; Outcomes for studies targeting children exposed to trauma who already have symptoms^b^; - Remission of PTSD; - Reduction in severity or number of traumatic stress syndromes or symptoms; - Prevention of or reduction in co-occurring mental health conditions or symptoms (e.g., depression, anxiety); - Prevention of or reduction in co-occurring physical health conditions or symptoms (e.g., sleep disorders, eating disorders, pain, overweight or obesity, asthma, cardiovascular problems, gastrointestinal problems, headaches); - Reduction in risk-taking behaviors (including substance use), behavioral problems (including conduct disorder and ADHD), or criminal; - Healthy development (including improvements in interpersonal/social functioning), or signs of developmental regression; - School-based functioning; - Improvements in quality of life
Timing | - All outcomes included, regardless of timing of measurement
Setting | - Studies conducted in the United States or internationally; - Specialty (e.g., outpatient and inpatient primary care or mental health care settings); - Nonspecialty (e.g., schools, community-based providers, shelters); - Home-based settings and out-of-home care (e.g., residential treatment)
Publication type | - Not editorials, letters to the editor
Study design | - Included designs: systematic reviews, randomized controlled trials, nonrandomized controlled trials, prospective cohort studies, and nested case-control studies; - Excluded designs: case reports, case series, cross-sectional studies, nonsystematic reviews, retrospective cohort studies, non-nested case-control studies
Sample size | - N ≥10
Time of publication | - 1990 to present
Language of publication | - English

ADHD = attention deficit hyperactivity disorder; N = number; PTSD = post-traumatic stress disorder; SSRI = selective serotonin reuptake inhibitors; TCA = tricyclic antidepressants

a At least 95% of the sample was required to be between 0 and 17 years of age.

b At least one outcome had to relate to the assessment of trauma for the study to be included. For each study, we also included findings that showed nonbeneficial outcomes associated with the intervention (e.g., no significant changes in outcomes between groups or significantly worse outcomes in the intervention group).

## Study Design

To identify appropriate study designs, the research team used the algorithm developed by the Alberta Evidence-based Practice Center.39 Table 2 describes the study design inclusion criteria developed for this report.

Table 2 Study inclusion criteria

Category | Criteria for Inclusion | Criteria for Exclusion
Publication type | Original research | Editorials, letters to the editor
Study design | Systematic reviews, RCTs, nonrandomized controlled trials, prospective cohort studies, and nested case-control studies | Case reports, case series, cross-sectional studies, nonsystematic reviews, retrospective cohort studies, nonnested case-control studies
Study duration | No limits | NA
Sample size | N ≥ 10 | N < 10
Geography | United States and international | NA
Time of publication | 1990 to present | < 1990
Language of publication | English | All other
Risk of bias | Low or medium | High (one or more significant flaws that invalidated the findings (e.g., attrition bias of overall attrition ≥ 20% or differential attrition ≥ 15% without appropriate handing of missing data such as the use of intention-to-treat analyses), detection bias, selection bias, performance bias, an/or reporting bias)
PICOTS | All PICOTS listed in Table 1 | Having more than 5% of study participants older than 17 years old, having outcomes listed in the PICOTS but not having at least one outcome focused on traumatic stress symptoms or syndromes

N = number; NA = not applicable: PICOTS = population, intervention, comparators, outcomes, timing, and setting; RCT = randomized controlled trial

## Study Selection

All titles and abstracts identified through our literature searches were independently reviewed for eligibility against our inclusion/exclusion criteria by two trained members of the research team. Studies marked for possible inclusion by either reviewer underwent a full-text review. For studies without adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination. We tracked all results in an EndNote^®^ database.

We retrieved and reviewed the full text of all articles included during the title/abstract review phase. Each full-text article was independently reviewed by two trained members of the research team for inclusion or exclusion on the basis of the eligibility criteria described earlier. If both reviewers agreed that a study did not meet the eligibility criteria, the study was excluded. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting a third member of the review team. We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria so that we could later compile a comprehensive list of such studies.

## Data Extraction

For studies that met inclusion criteria, we abstracted relevant information into evidence tables. We designed data abstraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results, as specified in the PICOTS. Trained reviewers extracted the relevant data from each included article into the evidence tables. All data abstractions were reviewed for completeness and accuracy by a second member of the team.

KQ 3 presents outcomes of interventions categorized by child characteristics. Because the intent of KQ 3 was to evaluate whether characteristics of the child moderated the effect of the interventions, we included only those studies that tested whether the effect of an intervention on outcome differed by subgroup characteristics via an interaction term. We did not synthesize the evidence for KQ 3 from studies that met our overall inclusion criteria for KQs 1 and 2 but did not compare effects between subgroups. We elected not to summarize findings that merely presented results stratified by subgroups because of the risk of overinterpreting results from underpowered subsamples.

## Risk-of-Bias Assessment

Two independent reviewers assessed risk of bias (internal validity) for each study using predefined criteria described in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews,”40 using questions specified in the RTI Item Bank41 and the Cochrane Risk of Bias tool.42 We resolved disagreements between the two reviewers by consulting an experienced member of the team. We selected items based on relevance to the topic and anticipated sources of bias. We assessed the potential for selection bias, performance bias, attrition bias, detection bias, and reporting bias. We then rated each study as having low, medium, or high risk of bias for individual outcomes. In general, a study with a low risk of bias had a strong design, measured outcomes appropriately, used appropriate statistical and analytical methods, reported low attrition, and reported methods and outcomes clearly and precisely. Studies with a medium risk of bias did not meet all criteria required for low risk of bias. These studies had some flaws in design or execution (e.g., imbalanced recruitment, high attrition) but they provide information (say, through sensitivity analysis) to allow the reader the ability to evaluate and determine that those flaws did not likely cause major bias. Missing information often led to ratings of medium as opposed to low risk of bias. Studies with a high risk of bias had at least one or more major flaw that likely caused significant bias, and, thus, invalidated the results. Major flaws precluded the ability to draw causal inferences between the intervention and the outcome. Examples of flaws likely to result in a high risk of bias rating include poorly randomized studies that failed to account for imbalances at baseline; observational studies that failed to account for potential confounders; and studies of any design with overall attrition of 20 or more or differential attrition of 15% or more without appropriate handling of missing data, such as the use of intention-to-treat analyses.

## Data Synthesis

To determine whether quantitative analyses were appropriate, we assessed the clinical heterogeneity of the population in studies under consideration following established guidance.43 We did this by qualitatively assessing the PICOTS of the included studies, looking for similarities and differences.

We did not find quantitative analyses appropriate because of heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in reporting. Thus, we synthesized the data qualitatively.

Given the complexity of our analyses, we adopted some conventions for presenting comparative data (Table 3). We present baseline values and standard deviations (if reported) for each group, followed by within-group change scores (for continuous outcomes) or within-group difference in proportions (for dichotomous outcomes) and, if reported, standard deviations of the differences. We then present between-group change scores (for continuous outcomes) or between-group change in proportions (for dichotomous outcomes). Values calculated by us are noted in parentheses next to each value as “(calculated).” Statistically between-group differences in the change of a specific outcome over time are indicated by reporting the actual p value of the comparison and associated test statistics. If a study found no between-group differences in change over time, we report the actual p value (if reported) or “p=ns” if unspecified. Adjusted analyses are reported if conducted and noted appropriately. Separate columns indicate trauma, mental health (e.g., depressive and anxiety symptoms), and physical health (e.g., somatic complaints) outcomes, as well as other outcomes (e.g., functional impairment, aggression).

Table 3 Intervention A versus wait list control: results

First Author et al., Year | Comparison Groups | Trauma Symptom Outcomes | Mental Health Outcomes | Physical Health Outcomes | Other Outcomes
Jones, et al., 2010 | G1: Cognitive behavioral therapy G2: Wait list control | Greater reduction in PTSD symptoms (UCLA PTSD Index for DSM-IV PTSD, range 0–80) Pretreatment G1: 50.1 (SD=11.0) G2: 49.6 (SD=9.0) Within group change at post-treatment: G1: -10.3 (calculated) G2: -3.6 (calculated) Between group change at post-treatment: -6.7 (calculated) Adjusted between group ANOVA treatment*time interaction: F=4.68, df=1,35, p<0.05 | No between-group differences in changes in depressive symptoms (Brief Beck Depression Inventory, range 0–21) Pretreatment G1: 12.4 (SD=4.2) G2: 11.9 (SD=4.3) Within group change at post-treatment: G1: -4.8 (calculated) G2: -4.3 (calculated) Between group change at post-treatment: 0.5 (calculated) Adjusted between group ANOVA treatment*time interaction: F=1.39, df=1,35, p=0.42 | NR | NR

ANOVA = analysis of variance; df = degrees of freedom; DSM-IV = “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition”; G = group; NR = not reported; PTSD = post-traumatic stress disorder; SD = standard deviation

Table 3 (an example based on hypothetical data) shows that, in Jones, et al. (2010), the cognitive behavioral therapy (CBT) group had significantly greater reduction in PTSD symptoms (mean -10.3 in intervention arm versus -3.6 in control arm, ANOVA treatment*time interaction p<0.05). The between-group differences in depressive symptoms over time, however, were not significantly different between study arms (-4.8 in the CBT intervention group versus -4.3 in the wait-list control group, p=0.42).

## Strength of Body of Evidence

We graded the strength of evidence (SOE) on the basis of guidance established for the EPC Program.37,44 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. The grades of evidence that were assigned are described in Table 4. Grades reflect the strength of the body of evidence to answer the KQs on the comparative effectiveness and harms of the interventions in this review. Two reviewers assessed each domain for each key outcome listed in the framework, and conflicts were resolved by consensus.

Table 4 Grade definitions for overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect: further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect: further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect: further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens, et al., 2010^44^

At a minimum, two reviewers assessed each domain for each key outcome and resolved any differences by consensus. We used a qualitative process, considering each of the domains, to determine the overall SOE grade for each relevant outcome. The team discussed differences in overall SOE grades to reach consensus. For outcomes had only a single study to provide evidence, we evaluated consistency as not applicable. When a study having estimates of effects with confidence intervals that permitted clinically distinct conclusions, we rated that domain as imprecise. When studies provided sufficient information (i.e., standard deviation or standard error) to calculate confidence intervals around between-group changes without making assumptions about the correlation between available measures of variance, we calculated confidence intervals for the difference in the change in outcomes for the study groups. For studies that did not provide estimates of variance for between-group differences in outcomes, we relied on measures of statistical significance from between-group adjusted analyses where available or unadjusted analyses if no other data were available. We did not rely solely on measures of statistical significance to evaluate precision for differences in post-test assessment that failed to account for pretest differences. We also considered whether studies were adequately powered. For outcomes with a single study with imprecise results and for which power was not ensured, we considered this to be insufficient evidence that the estimate from the single study was robust enough to have any confidence in the finding. For a single study with precise results, we graded it as low. Therefore, although effectiveness is synonymous with neither precision nor SOE, individual studies that showed an effect generally merited a rating of low SOE.

## Applicability

We assessed the applicability both of individual studies and of the body of evidence.37 For individual studies, we examined conditions that may limit applicability based on the PICOTS structure. Such conditions may be associated with heterogeneity of treatment effect and the ability to generalize the effectiveness of an intervention to use in everyday practice. Examples include the following:

- Population: narrow eligibility criteria
- Intervention: intensity and delivery of the interventions
- Comparator: use of substandard comparators
- Outcomes: use of composite outcomes that mix outcomes of different significance to patients
- Timing: studies of different duration that may have various implications for applicability

We abstracted and reported key characteristics that may affect applicability into evidence tables. To assess the applicability of a body of evidence, we considered the consistency of results across studies that represent an array of different populations.

## Peer Review and Public Commentary

An external peer review was performed on this report. Peer Reviewers were charged with commenting on the content, structure, and format of the evidence report; providing additional relevant citations; and pointing out issues related to how we conceptualized the topic and analyzed the evidence. Our Peer Reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ also provided review from its own staff. In addition, the Scientific Resource Center placed the draft report on the AHRQ Web site (www.effectivehealthcare.ahrq.gov) for public review.