# Introduction

## Background

Approximately two-thirds of children and adolescents will experience at least one traumatic event, creating a critical need to identify effective child trauma interventions. While most children exposed to trauma do not experience long-term negative sequelae in terms of psychological and social functioning, some go on to develop traumatic stress syndromes, including post-traumatic stress disorder (PTSD).1-3 Studies have indicated that childhood traumatic stress syndromes are associated with a high degree of impairment during childhood that can carry into adolescence and adulthood. For example, childhood PTSD increases the risk of several comorbid mental disorders such as depression, substance abuse, and conduct disorder.4 Suicidality is a particularly grave concern for children with PTSD.4,5 Decreased functioning in several domains (social, home, school, relational) by children and adolescents with PTSD also has been observed (e.g., lower academic achievement6). Although several guidelines on the treatment of PTSD during childhood and adolescence exist, the recommendations are not largely based on evidence resulting from Comparative Effectiveness Reviews. Furthermore, the guidelines offer inconsistent recommendations for some interventions.

The current review is the second in a two-part series focusing on interventions that address child trauma. The first in the series focuses on the comparative effectiveness of interventions that address child exposure to trauma in the form of maltreatment (physical, sexual, and emotional/psychological abuse, and neglect). This review, the second in the series, addresses the treatment of children exposed to traumatic events other than child maltreatment or family violence, some of whom are already experiencing symptoms. Interventions for children exposed to family violence (i.e., intimate partner violence and other forms of violence exposure in the home) are not covered by either review given the heterogeneity in this population and the interventions used to treat family violence exposure. That is, children who witness but do not directly experience interpersonal violence represent different clinical populations in terms of the nature of the relationship disturbance and implications for treatment. Although the background and discussion below provide a comprehensive overview of the prevalence and types of trauma, sexual trauma and maltreatment are addressed by the child maltreatment review.

### Definitions

Given the high occurrence rate of psychological trauma among children and adolescents,1 traumatic stress in childhood has attracted considerable clinical and research interest. For the sake of brevity, we refer to children and adolescents as “children” for the remainder of the report. Although there is little doubt that symptoms of traumatic stress alone can cause impairment in children, there is considerable controversy surrounding the diagnosis of syndromes of child traumatic stress symptoms. PTSD is an anxiety disorder that can be diagnosed in children at least 1 month after exposure to a traumatic event. The “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition” (DSM-IV) diagnosis of childhood PTSD is the same as that for an adult; however, several exceptions are noted within some of the symptom cluster criteria.7 A child with PTSD may express recurrent and intrusive distressing recollections of the event through repetitive play in which themes or aspects of the trauma are expressed, recurrent distressing dreams of the event may be experienced as frightening dreams without recognizable content, and in young children, expression of acting or feeling as if the traumatic event were recurring, which can include flashbacks episodes, may be expressed through trauma-specific reenactment. Children with PTSD may also show symptoms such as loss of interest in daily activities; headaches, stomachaches, or other physical symptoms; excessive worry; and sleep or concentration problems7 and may develop repeated physical and emotional symptoms when reminded of the event.

### Prevalence

Traumatic events are common in childhood. In one longitudinal study of more than 1,400 children 9 to 16 years of age, 68 percent of children reported at least one traumatic event (with 37 percent experiencing more than one event); 13.4 percent of those experiencing trauma developed some post-traumatic symptoms. However, only 0.5 percent of these trauma-exposed children met the full criteria for PTSD.1 In a survey of adolescents 12 to 17 years of age, the 6-month prevalence for PTSD was 6.3 percent in girls and 3.7 percent in boys.8 The prevalence of PTSD in younger children is largely unknown; however, several studies have assessed the prevalence of PTSD in young children exposed to various types of violence (abuse, car crashes, and natural disasters) with high reported rates of PTSD. The rates of PTSD vary considerably in such studies and may be related to the severity, chronicity, and type of trauma.

### Types of Trauma

Children can be exposed to many types of trauma, including inflicted trauma, unintentional trauma, natural disasters, war, and neighborhood violence. One longitudinal study reported that 25 percent of its sample was exposed to or victimized by violence (excluding sexual trauma), 11 percent was exposed to sexual trauma, and 32 percent was exposed to other types of trauma (diagnosed with a physical illness, 11%; serious accident, 11.6%; natural disaster, 11.1%; fire, 5.9%).1 The Adverse Childhood Experiences Study showed high rates of childhood trauma exposure in a large adult population.9 In this population, 65 percent recalled adverse childhood experiences, many of which could be defined as traumatic events. These experiences included emotional abuse (11%), physical abuse (28%), sexual abuse (21%), battered mother (13%), household drug/alcohol abuse (27%), household mental illness (17%), parent separation or divorce (23%), and incarcerated household member (5%).9 PTSD rates vary by type of traumatic exposure, with 35 percent of children exposed to community violence10 and half of those affected by interpersonal violence.11 Road crashes, another common form of childhood trauma, were associated with rates of PTSD ranging from 13 to 25 percent between 4 and 12 months after a road crash.12 Children with agency-reported abuse had much higher rates of PTSD when compared with children without reported abuse.13 Trauma from natural disasters frequently leads to PTSD; for example, one study reported a PTSD rate of 35 percent for children surviving an earthquake.

### Risk and Protective Factors of Traumatic Stress in Children

Not all trauma-exposed children develop traumatic stress syndromes. Several risk and protective factors play a role in the development of syndromes such as PTSD. In one study of terrorism exposure, children more directly affected by terrorism were more likely to report PTSD. Likewise, those with more frequent reminders of traumatic experiences were more likely to experience PTSD, and those with support-seeking behavior were less likely to report PTSD.14 The severity of injuries resulting from motor vehicle accidents has been shown to be associated with the development of PTSD. Previous trauma and preexisting anxiety disorders increase the risk of PTSD.1 A variety of genetic and neurobiological factors play a role in the development of PTSD.15 The developmental age, number of trauma exposures, family systems, and neighborhood factors may play a role in the development of PTSD after trauma.

### Clinical Presentation of Post-Traumatic Stress Disorder and Associated Impairment

Clinicians often face several challenges in recognizing and diagnosing PTSD in children.16 Because misdiagnosis of PTSD as other psychiatric conditions such as bipolar disorder is common, clinicians need to be careful in assessing children for several key features of PTSD. To establish the diagnosis, a clinician needs to establish that a traumatic event preceded onset of the disorder, which he or she can determine either through compelling evidence or by reports given by the child or the child's caregiver. This conclusion might be difficult given that avoidance of the trauma is a core feature of PTSD in children, and a parent might deny the trauma if he or she is the perpetrator, is ashamed or embarrassed about the trauma, or is unaware of it. In some instances, referral of the child for a forensic evaluation might be necessary.

Clinical diagnosis of PTSD in children also requires the presence of three distinct symptom clusters: (1) symptoms of re-experiencing the trauma, (2) emotional numbing and persistent avoidance of trauma reminders, and (3) persistent symptoms of hyperarousal. Young children might exhibit different behaviors, such as oppositionalism, fears unrelated to the traumatic event itself, and separation anxiety. Although acute stress disorder (ASD) can be diagnosed in children as soon as 2 days after the traumatic event, at least 1 month is required to make a PTSD diagnosis in children.

### Diagnostic Issues

Much debate has surrounded the validity of the DSM-IV diagnostic criteria for PTSD in children.16,17 Part of the debate stems from the number of symptoms required within each symptom cluster to make a formal diagnosis. This is particularly so with the emotional numbing/avoidance symptom criteria, in that young children often are not developmentally able to report on these emotions nor do their parents have awareness of their children's internal states.18-20

Currently, several experts in the field of child PTSD are considering possible age-related subtypes of PTSD in preschool or school-aged children for inclusion in the forthcoming DSM-V, particularly given that the DSM-IV criteria were developed and tested on adults and only adolescents ages 15 years or older.21 Although it is known, for example, that preschool children can experience traumatic events, community studies have found PTSD prevalence rates much lower than expected. One possible explanation for the low rates involves the strict DSM-IV diagnostic criteria that might not be developmentally appropriate for this age group.17 Thus, an alternative algorithm for PTSD in young children has been proposed and refined22-24 and endorsed by field experts.25 This alternative algorithm might also apply to school-aged children, who have exhibited lower-than-expected prevalence of PTSD based on DSM-IV criteria. Because few studies have empirically tested the proposed algorithm on school-aged children, however, it is not known whether the DSM-V should incorporate alternative criteria for PTSD diagnosis in this age group.

Alternatively, several experts in the field of childhood traumatic stress believe that a diagnosis of developmental trauma disorder (DTD) more adequately captures the reality of clinical presentations of children and adolescents exposed to chronic interpersonal trauma and faulty caregiver systems. These experts believe that children suffering from DTD have disrupted affect regulation, attention, cognition, perception, and interpersonal relationships and may not meet criteria for the traditional diagnosis of PTSD. The proposed criteria for DTD include exposure to multiple or prolonged adverse events and experiences of affective and physiological dysregulation with attention and behavioral dysregulation and self and relational dysregulation, in addition to experiencing these post-traumatic spectrum symptoms for at least 6 months at levels severe enough to cause functional impairment in at least two areas of functioning (scholastic, familial, peer group, legal, health, or vocational).

## Intervention Strategies

The continued uncertainties of trauma identification and PTSD diagnosis increase the clinical challenges of addressing this population appropriately. Interventions designed to prevent or treat traumatic stress symptoms exist within the domains of psychotherapy, pharmacotherapy, complementary and alternative treatments, and other therapies such as systems or combination therapies. To provide a comprehensive review, we include all intervention domains for questions of treatments targeting children exposed to trauma, some of whom are already experiencing symptoms. Some of the intervention examples specified below focus solely on interventions for children exposed to trauma without requiring the presence of any traumatic syndromes (treatment based on exposure), and others focus on interventions for children exposed to trauma and already experiencing traumatic symptoms or syndromes that exceed a predetermined threshold (treatment based on symptoms). For children who have been exposed to trauma but have not yet developed symptoms or syndromes, interventions are intended to prevent the onset of traumatic stress syndromes or PTSD. For children already experiencing such symptoms, treatments are intended to result in remission of PTSD, a reduction of symptoms, and improved functioning.

We also note settings when relevant. Interventions other than pharmacotherapy may be carried out at an individual, family, or group level. They may be carried out in various settings (including the outpatient versus inpatient setting) or in communities, schools, or classrooms. Many programs attempt to bring one of a variety of psychotherapeutic techniques into the home. In these circumstances, the training that parents and children receive differs very little from general psychotherapeutic techniques. The goal of these interventions, rather, is to improve access and outcomes in populations that are traditionally harder to reach such as ethnic minorities, rural populations, or people of low socioeconomic status.26 In addition to attempting to prevent PTSD or traumatic stress symptoms, these interventions are often directed at associated symptoms such as aggression or delinquency.

### Psychotherapy: Interventions for Preventing or Treating Post-Traumatic Stress Disorder or Traumatic Stress Symptoms in Children Following a Potentially Traumatic Event

Several different psychotherapeutic interventions have been designed to prevent or treat PTSD or traumatic stress symptoms in children. Most of the approaches incorporate elements of cognitive behavioral interventions, and many include the caregiver(s) as an important component of the treatment. School-based interventions are unlikely to involve the primary caregivers in the treatment but have the advantage of intervening with larger numbers of children through group treatment. Cognitive behavioral components of these treatments may include psychoeducation, cognitive restructuring, relaxation training, and exposure therapy/desensitization (often through development of a trauma narrative).

Interventions also vary in degree of structure, with the intervention manualized with specific concepts or techniques reviewed or taught during specific sessions. These manualized interventions may have the advantage of easier replication and may offer more guidance to the clinician. These time-limited approaches may be especially advantageous when used in groups (e.g., school-based interventions); at an individual level, more flexibility in the number of sessions and material covered in each session may be beneficial.

The following interventions have cognitive behavioral components and are used in both the prevention and treatment of traumatic stress symptoms: cognitive behavioral therapy (CBT), trauma-focused cognitive behavioral therapy (TF-CBT), cognitive processing therapy (CPT), child-parent psychotherapy (CPP), Skills Training in Affective and Interpersonal Regulation/Narrative Story-Telling (STAIR/NST), trauma and grief component therapy (TGCT), and Cognitive Behavioral Intervention for Trauma in Schools (CBITS).

CBT is a form of psychotherapy used to treat many psychiatric problems, including depression, anxiety, and PTSD. CBT combines elements of cognitive therapy and behavioral therapy. In CBT, maladaptive thought patterns are identified and targeted through cognitive restructuring, and maladaptive behaviors are targeted through behavioral techniques that may include exposure/desensitization, relaxation skills, and stress inoculation training or teaching an individual how to reduce anxiety. In addition to the more traditional use of CBT with individuals who are experiencing symptoms of traumatic stress, its components may be appropriate for use with children exposed to traumatic events.

TF-CBT is a psychotherapeutic technique that has specifically adapted CBT for use with children exposed to trauma and those presenting symptoms of traumatic stress. In TF-CBT, children and parents learn skills to help process thoughts and feelings related to traumatic life events and to manage and resolve distressing thoughts, feelings, and behaviors also related to those same events. Components of treatment include psychoeducation about trauma; parenting skills; relaxation skills; coping skills to deal with trauma-related thoughts, feelings, and behaviors; and child exposure tasks via narratives, drawings, or other imaginal methods. Safety and social skills training may also be a component of treatment.27

CPT is a manualized 12-session cognitive behavioral treatment for PTSD that has a primary focus on challenging and modifying maladaptive beliefs related to the trauma but also includes a written exposure component. Clients are asked to write about the impact and content of the traumatic event. Associated problems such as depression, guilt, and anger are also addressed in CPT.

CPP is a relationship-based treatment that integrates modalities derived from psychodynamic, attachment, trauma, cognitive behavioral, and social learning theories. The child-parent relationship is used to target the child's improvement in emotional, cognitive, and social domains of functioning. The interventions focus on promoting affect regulation in the child and parent; changing maladaptive behaviors in the child, the mother, and their interaction; supporting and encouraging developmentally appropriate interactions and activities; and assisting the child and the mother in creating a joint trauma narrative.28 CPP has more traditionally been implemented with populations in which there were clinical concerns about the child's behavior or the mother's parenting after the child witnessed or overheard marital violence and also with maltreating families. However, this intervention may also be appropriate for children soon after exposure to other traumatic events.

STAIR/NST is a two-module treatment focused on reducing symptoms of PTSD and other trauma-related symptoms (including depression and dissociation) and on building and enhancing specific social and emotional competencies that are frequently disturbed in youths who have experienced multiple traumas and/or sustained trauma. This intervention might also be used to prevent the development of traumatic stress symptoms when implemented after exposure to a traumatic event. STAIR/NST includes 10 treatment sessions conducted in group or individual format that target social and emotional competency building. The sessions focus on developing emotional regulation and social skills, positive self-definition exercises, and goal setting and achievement. The NST phase of treatment is conducted in 6 individual sessions that focus on the emotional processing of traumas in detail while developing a positive life narrative and future plan.

TGCT is a group treatment program for traumatically bereaved older school-aged children and adolescents. The target population includes youths affected by community violence, school violence, gang violence, war/ethnic cleansing, and natural and manmade disasters. TGCT has several areas of focus, including the processing of traumatic experiences, coping with reminders of trauma and loss, coping with post-traumatic adversities, managing traumatic grief, and resuming developmental progression. This intervention may be appropriate for children exposed to traumatic events and for those experiencing traumatic stress symptoms.

Psychotherapeutic interventions have also been developed specifically for use in schools.

CBITS is a skills-based, group intervention for children exposed to trauma who are typically between the ages of 10 and 15 years; it may be appropriate not only for intervening early after exposure to a traumatic event but also for treating traumatic stress symptoms. The CBITS program consists of 10 group sessions designed to provide education about reactions to trauma, teach relaxation skills, provide cognitive therapy to challenge upsetting thoughts, teach social problem solving, and work on processing traumatic memories and grief. These skills are learned through the use of drawings and by talking in both individual and group settings. Between sessions, children complete assignments and participate in activities that reinforce the skills they have learned. Parent and teacher education sessions are also included.

Cognitive behavioral approaches are less applicable when working with younger children because of developmental issues, though the caregiver may benefit from cognitive behavioral treatment. For this population, intervention approaches tend to be relationship based, and the primary focus of the intervention is centered around supporting the caregiver-child relationship as a strategy for treating traumatic stress in the young child.

In addition, psychotherapy treatment is sought traditionally when an individual is already experiencing symptoms of distress. However, professionals recognize that an effective strategy for reducing traumatic stress symptoms and disorders in children can be to intervene soon after an exposure to a potentially traumatic event but prior to the development of symptoms or a traumatic stress disorder. One intervention developed specifically to treat children exposed to a potentially traumatic event is the Child and Family Traumatic Stress Intervention (CFTSI). CFTSI is a four-session caregiver-child early intervention and secondary prevention model that focuses on increasing communication between children and their caregivers about feelings, symptoms, and behaviors with the goal of increasing the caregivers' support of the child and teaching specific behavioral skills to both caregiver and child to assist the child in coping with symptoms. CFTSI's focus is informed by findings that indicate the role of family support as a primary protective factor for children exposed to a potentially traumatic event.

Other psychotherapy approaches that may be beneficial in the treatment of children presenting with traumatic stress symptoms and disorders include dialectical behavior therapy (DBT), Structured Psychotherapy for Adolescents Responding to Chronic Stress (SPARCS), parent-child interaction therapy (PCIT), eye movement desensitization and reprocessing (EMDR), and trauma systems therapy (TST).

DBT is a psychotherapeutic approach that helps clients learn to both regulate and tolerate their emotions and may be appropriate for treating traumatic stress symptoms. Concrete skills are taught and practiced, including mindfulness practices from Eastern medicine. DBT combines standard cognitive behavioral techniques for emotion regulation with concepts of distress tolerance, acceptance, and mindfulness.29

SPARCS is based on DBT. SPARCS is a group intervention designed to address the needs of chronically traumatized adolescents who may be living with ongoing stress and is intended to take place in a variety of settings, including schools, agencies, and residential treatment centers; it has been shown to decrease PTSD symptoms.30 These adolescents may experience problems in several areas of functioning, including difficulties with affect regulation and impulsivity, self-perception, relationships, somatization, dissociation, numbing, and avoidance. SPARCS is predominantly cognitive behavioral; key components of the program include mindfulness, problem solving, relationship building/communication skills, and distress tolerance.

PCIT is a treatment that targets improvement in the quality of the parent-child relationship. Parents are taught skills that facilitate the establishment of a nurturing and secure relationship with their child while increasing the child's prosocial behavior and decreasing negative behavior. The treatment includes a child-directed interaction that is similar to play therapy, with the goal of strengthening the parent-child relationship, and a parent-directed interaction, in which parents learn to use behavior management techniques as they play with their child. PCIT has been adapted for children who have experienced trauma31,32 and is most appropriate as a treatment of traumatic stress symptoms rather than as prevention of traumatic stress symptoms after exposure to a traumatic event.

EMDR is a psychotherapeutic approach in which the patient attends to past memories, present triggers, or anticipated future experiences while simultaneously moving his or her eyes back and forth following the therapist's fingers as they move across the patient's field of vision. Graduated imaginal exposure to the traumatic event(s) is combined with having the child visually track the therapist's hand movements. The theoretical basis for EMDR is that PTSD symptoms result from insufficient processing or integration of sensory, cognitive, and affective components of the traumatic memory, and the eye movements are proposed to facilitate information processing and integration, thereby allowing patients to fully process traumatic memories.33 EMDR is an intervention that targets individuals who experience symptoms of traumatic stress.

TST is targeted toward children and adolescents who are having difficulty regulating their emotions as a result of the interaction between the traumatic experience and stressors in the social environment. TST is appropriate for individuals who are experiencing traumatic stress symptoms, but it might also be relevant for preventing traumatic stress symptoms when implemented after exposure to a traumatic event. Interventions include a focus on both the emotional regulation capacities of the traumatized child and the ability of the child's social environment and system of care to help the child manage his or her emotions or to protect the child from threat. Treatment modules include home and community-based services, services advocacy, emotional regulation skills training, cognitive processing, and psychopharmacology.

### Pharmacotherapy: Interventions for Preventing Post-Traumatic Stress Disorder or Traumatic Stress Symptoms in Children

Medication use in children who have experienced acute trauma or during their exposure to trauma to prevent the development of PTSD is intended to target memory consolidation and physiologic hyperarousal. A similar rationale supports use of the opioid analgesic morphine in the acute care setting in the prevention of PTSD, especially in the pediatric intensive care setting. In addition to treating the pain from invasive medical procedures, morphine diminishes the memory consolidation that may accompany this pain. In addition, other medications, such as the alpha-agonist clonidine, are intended to diminish the physiologic symptoms of hyperarousal immediately following or during a traumatic event. Other medications that target physiologic hyperarousal and memory consolidation may also be used to prevent PTSD in exposed children.

### Pharmacotherapy: Interventions for Treating Post-Traumatic Stress Disorder or Traumatic Stress Symptoms in Children

Selective serotonin-reuptake inhibitors, or SSRIs, are a class of antidepressants that are among the most studied medications for PTSD treatment in children. SSRIs work by inhibiting the reuptake of serotonin and, therefore, increase the amount of serotonin in the synaptic cleft available to receptors on the postsynaptic neuron. Because they are the first-line treatments for PTSD in adults, they are some of the most common medications used to treat PTSD in children as well. However, there has been no clear indication established for SSRI use as monotherapy (i.e., without psychotherapy) in children with PTSD.

Some studies conducted with the SSRIs sertraline and citalopram have indicated some therapeutic benefit in children and adolescents. In contrast, there have been few studies of fluoxetine or other SSRIs aimed at improving PTSD in children.

#### Other Antidepressants

Atypical antidepressants, such as bupropion, venlafaxine, and mirtazapine, are also commonly used to treat PTSD symptoms or PTSD-associated symptoms. Imipramine is a tricyclic antidepressant that has shown promise as a PTSD treatment and was used frequently before the development of the SSRIs; however, cardiac side effects have significantly limited its use. In addition, the restricted diet that patients on monoamine oxidase inhibitors (MAOIs) must follow has also limited the use of MAOIs as a PTSD treatment.

#### Other Medications

Because childhood PTSD is so often associated with other comorbid mental conditions, numerous other medications are used to treat PTSD and have been studied. These medications are thought to work through various mechanisms.

- Stimulants such as methylphenidate and its derivatives and amphetamine preparations are used to treat PTSD-related symptoms of inattention and externalizing behaviors that are often confused with or misdiagnosed as attention deficit hyperactivity disorder (ADHD). Because PTSD often causes hyperarousal and associated physiologic changes, medications that treat these physiologic effects have also been studied in patients with PTSD. As mentioned earlier, the alpha agonist clonidine is thought to mainly target hyperarousal symptoms in PTSD. Propranolol, a beta-adrenergic blocking agent, has also had promising results as a treatment for PTSD in childhood.
- Antipsychotics have also been studied as a PTSD treatment because of their effects on comorbid aggression or psychotic symptoms. These medications include risperidone and quetiapine. In addition, clozapine has been shown to reduce both hallucinations and flashbacks to a traumatic event while reducing the number of medications required to treat children with PTSD. Because PTSD can often be accompanied by severe behavior problems and mood fluctuations, the mood stabilizers valproic acid, carbamazepine, and lithium have been studied in children with PTSD and are frequently used clinically.
- Benzodiazepines, another class of medication, have also been used to treat the severe anxiety that often accompanies PTSD. Medications in this class include clonazepam, diazepam, alprazolam, and lorazepam. The American Association of Child and Adolescent Psychiatry (AACAP) has advocated that these medications not be used to treat PTSD in children because of the risk for long-term cognitive effects, sedation, and the potential for tolerance and addiction.

### Complementary and Alternative Interventions for Preventing or Treating Post-Traumatic Stress Disorder or Traumatic Stress Symptoms in Children

Equine-assisted psychotherapy is a specialized experiential approach to psychotherapy that uses a horse as a therapeutic tool. The goal is to encourage client insight through horse examples, addressing self-esteem and personal confidence; communication and interpersonal effectiveness; trust, boundaries, and limit setting; and group cohesion. Work is performed through the horse and supports and encourages the identification and expression of emotions.34

### Other Interventions for Preventing Post-Traumatic Stress Disorder and Traumatic Stress Symptoms in Children

Given that many traumatic events such as natural disasters or acts of terrorism can affect whole communities, community-based approaches have been developed to combat PTSD at its source or where chronic harm may be occurring. These approaches are outside of the traditional clinic setting and often allow clinicians an inside view of the context of the problem, which the patient is often unable to express during a clinic visit. These can be home- or school-based intervention programs or programs that partner with first responders or law enforcement to attempt to prevent or improve PTSD. Interventions may also encompass system-level, multicomponent, or other approaches (e.g., Web based). Two interventions designed to intervene early after exposure to traumatic events are critical incident stress debriefing (CISD) and Child Development-Community Policing (CD-CP). CISD is an intervention that targets individuals who have recently been exposed to a traumatic event. CISD is one of the first interventions created for police officers, first responders, and emergency medical technicians to use in the field with a survivor of a traumatic event during the first 72 hours. The CD-CP program is a collaborative early intervention program that targets individuals exposed to violence and is the product of a partnership between mental health professionals at the Yale University Child Study Center and the New Haven Police Department. The goals of the program are to help children cope with traumatic events and prevent the development of traumatic stress symptoms.35

## Current Child Traumatic Stress Guidelines

Although there are no existing guidelines for other syndromes of childhood traumatic stress, three organizations—the AACAP, the International Society for Traumatic Stress Studies (ISTSS), and the National Institute for Health and Clinical Excellence (NICE)—have published guidelines on the treatment of PTSD during childhood and adolescence. These guidelines largely stem from expert consensus based on existing evidence and clinical practice rather than on formal Comparative Effectiveness Reviews. These guidelines use different categories of interventions to summarize evidence and offer inconsistent recommendations for some treatment categories or interventions. For instance, the AACAP notes that SSRIs can be considered as a treatment for children with PTSD; NICE concludes that there is insufficient evidence to recommend the use of any medication in young people with PTSD. Similarly, ISTSS considers the evidence on EMDR to be insufficient to make a definitive recommendation for the acute period; NICE suggests that EMDR shows promise despite the lack of rigorous testing in randomized controlled trials. The guidelines do suggest agreement on some issues. For example, both AACAP and ISTSS agree on the importance of considering comorbid psychiatric conditions and school-based treatment approaches. These guidelines are summarized below.

### American Academy of Child and Adolescent Psychiatry

The 2010 Practice Parameter for the Assessment and Treatment of Children and Adolescents with Post-Traumatic Stress Disorder recommends early identification of PTSD, stresses the importance of gathering information from both children and parents to make valid diagnostic decisions, and highlights the importance of assessing and treating comorbid conditions of PTSD in children. Based on published randomized controlled trials (RCTs) conducted on children with PTSD from 1996 to 2006, AACAP made seven recommendations regarding best treatment practices in accordance with the strength of the empirical evidence or clinical support for each treatment type. Recommendations based on rigorous empirical evidence and/or overwhelming clinical consensus (minimum standard) are as follows:

- Treatment planning should consider a comprehensive treatment approach that includes consideration of the severity and degree of impairment of the child's PTSD symptoms.
- Treatment planning should incorporate appropriate interventions for comorbid psychiatric disorders.
- Trauma-focused psychotherapies should be considered first-line treatments for children and adolescents with PTSD.

Recommendations that are acceptable based on emerging empirical evidence or clinical opinion but lack strong empirical evidence and/or strong clinical consensus (option) are as follows:

- SSRIs can be considered for the treatment of children and adolescents with PTSD.
- Medications other than SSRIs may be considered for children and adolescents with PTSD.

The recommendation based on strong empirical evidence and/or strong clinical consensus (clinical guideline) is as follows:

- Treatment planning may consider school-based accommodations.

The recommendation known to be ineffective or contraindicated (not endorsed) is as follows:

- The use of restrictive rebirthing therapies and other techniques that bind, restrict, withhold food or water, or are otherwise coercive is not endorsed.

### International Society for Trauamtic Stress Studies

Six guidelines for the treatment of PTSD in children and adolescents were published in 2009 in “Effective Treatments for PTSD, Second Edition”:

- Acute interventions: Current evidence is insufficient to make a definitive recommendation regarding intervention selection or timing for systemic approaches, art and massage therapies, EMDR, debriefing, or cognitive behavioral approaches in the acute period.
- CBT: Several effective forms of CBT are available for clinicians to use with traumatized children and adolescents of diverse cultures. Trauma-focused forms of CBT effectively decrease PTSD symptoms and improvements with comorbid mental problems (e.g., depression and anxiety), behavioral problems, shame, grief, and adaptive functioning.
- Psychopharmacology: No medications are currently Food and Drug Administration (FDA)-approved for PTSD treatment in children. Studies testing the effectiveness of psychopharmacologic agents on children lag behind studies of adults; however, medication use in children has become the standard of care. Some evidence suggests that medication can help reduce PTSD symptoms. SSRIs appear to be a good first choice of agent. Severe comorbid psychiatric conditions might improve with the selection of an agent that can treat both PTSD and the comorbid condition.
- School-based treatment: A handful of trauma-focused school-based interventions have been empirically tested and shown to reduce corresponding PTSD symptoms and improve behavior. These programs are particularly helpful for children with limited access to clinic-based treatment.
- Psychodynamic therapy: There is growing evidence for psychodynamic, relationship-based therapy involving caregivers in treating childhood PTSD. Studies have indicated associated reduction in PTSD symptoms as well as improved developmental trajectories over time.
- Creative arts therapies: These therapies are currently under development and empirical testing has not occurred to enable a definitive recommendation. Despite this limitation, however, arts therapies appear to be promising.

### National Institute for Health and Clinical Excellence

These guidelines (2005) make the following recommendations for psychological interventions for children with PTSD:

- Among children and young people who have been sexually abused, psychological interventions (specifically trauma-focused cognitive–behavioral psychotherapy) can be effective for the treatment of PTSD symptoms.
- There is very little evidence from RCTs for the efficacy of any psychological interventions for children or young people who suffer from PTSD arising from other forms of trauma.
- EMDR shows promise despite lack of rigorous testing in RCTs.
- Evidence examining the effectiveness and efficacy of PTSD treatment in children less than 7 years of age is weak, and conclusions about best practices cannot be made.
- Single-session debriefing is not recommended.

With respect to pharmacological interventions for childhood PTSD, the NICE guidelines conclude that there is insufficient evidence to recommend the use of any medication in young people.

### Need for Comparative Effectiveness Reviews

The limitations of existing guidelines underscore other clinical dilemmas. Clinicians require better guidance on the comparative benefits of pharmacotherapy and nonmanualized treatment modalities such as psychodynamic or play therapy. Similarly, clinicians require better guidance on whether specific therapies could cause retraumatization or more harm. This review evaluates the comparative effectiveness of a broad array of interventions for benefits and harms.

The challenges of the diagnostic criteria for PTSD signal the need for a comprehensive review of interventions for children with traumatic stress symptoms or PTSD. Because the diagnostic criteria for PTSD were created for adults and tested only in adolescents ages 15 years or older, they may not be entirely relevant for younger children. Often, younger children are unable to express signs and symptoms in words and are more likely to externalize or express themes during play or in drawings. In addition, many children who do not meet criteria for a diagnosis of PTSD will have symptoms that significantly impair daily functioning. Our systematic review addresses the question of whether children without a formal diagnosis of PTSD but with traumatic stress symptoms may benefit from treatment. Another clinical concern is whether outcomes of interventions vary by the presence of comorbid diagnoses such as depression, disruptive behavior disorders, ADHD, other anxieties, learning disabilities, and psychosis. Our review evaluates evidence of effectiveness for subgroups that have such comorbidities.

Another treatment dilemma is access to services for PTSD. In areas without large academic medical centers or large population centers, the treatment approach is limited to what resources are available in the immediate vicinity. Often providers are trained in only one modality of therapy or were trained many years before and have not kept abreast of recent advances in treatment. Access to school-based and community-based resources is often lacking in rural or underserved areas and often depends on the political and sociocultural climate of the area. In addition, financial factors such as price of medication, insurance coverage, and other issues of access come into play when choosing a treatment modality. In patients and families with limited resources and with limited psychological mindedness, acceptance and participation may be a challenge for proven therapies.

A comprehensive review helps identify a broad range of modalities, including those with limited dissemination, and may contribute to better uptake of effective interventions in areas with limited access to services for PTSD.

## Scope

This review examines the efficacy of interventions that target traumatic stress symptoms and syndromes among (1) children and adolescents exposed to trauma other than maltreatment or family violence and (2) children and adolescents already experiencing symptoms after exposure to trauma other than maltreatment or family violence. We exclude maltreatment and family violence from this review because a companion AHRQ-funded review examined interventions for children exposed to maltreatment.36 For the sake of brevity, we refer to children and adolescents as “children” for the remainder of the report. The review also seeks to understand whether evidence exists for differences in the efficacy of these interventions by specific child or treatment characteristics or by setting of the delivered intervention. Finally, the review attempts to identify adverse events associated with the interventions reviewed. In addition, an overarching goal of this review seeks to identify gaps in the current scientific literature and highlight important areas for future research to build the evidence base for interventions targeting traumatic stress symptoms or syndromes with children exposed to trauma other than maltreatment or family violence.

Our population, intervention, comparators, outcomes, timing, and setting (PICOTS) framework presented in the Methods section defined the population, interventions, comparators, outcomes, and settings of interest for the review. The results presented in this review, therefore, only apply to this specific set of PICOTS. We note several other differences across studies such as type or severity of trauma experienced by children included in each tested intervention as limitations to the applicability of findings.

## Key Questions

Key Question 1: What is the comparative effectiveness of different types of pharmacotherapy, psychotherapy, complementary and alternative therapy, or other therapy, such as combined, for children ages 0 to 17 years exposed to trauma other than maltreatment? Traumatic stress symptoms and syndromes, as well as other specific outcomes examined, are detailed in Figure A.

Key Question 2: What is the comparative effectiveness of different types of pharmacotherapy, psychotherapy, complementary and alternative therapy, or other therapy, such as combined, for children ages 0 to 17 years with traumatic stress symptoms from trauma other than maltreatment who are already experiencing symptoms? Traumatic stress symptoms and syndromes, as well as other specific outcomes examined, are detailed in Figure A.

Key Question 3: Do interventions targeting children who were exposed to trauma and are already experiencing symptoms vary in their effectiveness by characteristics of the child, treatment, or setting?

Key Question 4: What are the harms (e.g., low adherence/dropouts, side effects, retraumatization) associated with specific types of therapies targeting children exposed to trauma or targeting children who were exposed to trauma and are already experiencing symptoms?

## Analytic Framework

Figure 1 depicts the analytic framework that presents the KQs within the context of the PICOTS described in the previous section. KQ 1 addresses the efficacy of interventions for children exposed to trauma other than maltreatment and family violence. KQ 2 examines the efficacy of interventions for children exposed to trauma other than maltreatment and family who already have symptoms. KQ 3 evaluates the efficacy of interventions in different subpopulations, varying by child or treatment characteristics or setting. KQ 4 illustrates the harms associated with specific interventions, which include retraumatization, side effects, low adherence, and dropouts.

Figure 1 Analytic framework

KQ = Key Question; PTSD = post-traumatic stress disorder

Figure 1 is titled, “Analytic framework for comparative effectiveness of interventions addressing children exposed to trauma other than maltreatment or family violence.” The key questions (KQs) are displayed within the context of the populations, interventions, and outcomes described in the previous section. Beginning with a population of children exposed to trauma other than maltreatment (KQ 1), followed by a population of children with traumatic stress symptoms from trauma other than maltreatment who are experiencing traumatic stress symptoms (KQ 2), the figure illustrates the effect of psychological and pharmacological interventions on outcomes of traumatic stress symptoms or syndromes; prevention of or reduction in medical and psychiatric comorbid conditions; prevention of or reduction in physical health conditions or symptoms; reduction in risk-taking behaviors, behavioral problems, or criminal activities; healthy development; school-based functioning; quality of life; and decreased suicidality. Next, we examine whether interventions for prevention or treatment of traumatic stress symptoms vary in their effectiveness by characteristics of child (KQ 3a), treatment (KQ 3b), or setting (KQ 3c). Finally, harms associated with specific types of therapies for preventing or treating traumatic stress symptoms are explored in KQ 4.

## Organization of ThisReport

The remainder of this review describes our methods in detail, documents our results, and provides a discussion of our findings and recommendations for filling important research gaps. Appendixes provide details of the search strategy (Appendix A), forms used for review and abstraction (Appendix B), studies excluded at the full-text review stage (Appendix C), comprehensive evidence tables (Appendix D), risk-of-bias ratings (Appendix E), and the summary of results (Appendix F).