# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

Carl C. Bell, M.D.

President/C.E.O., Community Mental Health Council

Acting Director, Institute for Juvenile Research

Professor, Department of Psychiatry and School of Public Health

Chicago, IL

Steven Berkowitz, M.D.

Child and Adolescent Psychiatrist and Associate Professor of Clinical Psychiatry

University of Pennsylvania

Director, Penn Center for Youth and Family Trauma Response and Recovery

Philadelphia, PA

Julian Ford, Ph.D.

Professor, Department of Psychiatry

University of Connecticut Health Center

Farmington, CT

Daniel I. Galper, Ph.D

Director, Research and Special Projects

American Psychological Association

Washington, DC

Malcolm Gordon, Ph.D.

Center for Mental Health Services

Substance Abuse and Mental Health Services Administration

Rockville, MD

Penelope Knapp, M.D.

California Department of Mental Health

Sacramento, CA

Frank Putnam, M.D.

Director, Mayerson Center for Safe and Healthy Children

Trauma Treatment Replication Center

Cincinnati Children's Hospital

Advisory Board Member, National Center for School Crisis and Bereavement

Cincinnati, OH

Glenn Saxe, M.D.

Chair and Arnold Simon Professor of Child and Adolescent Psychiatry

Director, Child Study Center

New York University Langone Medical Center

New York, NY