# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

Carl C. Bell, M.D.

President/C.E.O., Community Mental Health Council

Acting Director, Institute for Juvenile Research

Professor, Department of Psychiatry and School of Public Health

Chicago, IL

John Fairbank, Ph.D.

Co-Director, National Center for Child Traumatic Stress

Department of Psychiatry and Behavioral Sciences, Duke University

Durham, NC

Julian Ford, Ph.D.

Professor, Department of Psychiatry

University of Connecticut Health Center

Farmington, CT

Daniel I. Galper, Ph.D.

Director, Research and Special Projects

American Psychological Association

Washington, DC

Malcolm Gordon, Ph.D.

Center for Mental Health Services Substance Abuse and Mental Health Services Administration

Rockville, MD

Frank Putnam, M.D.

Director, Mayerson Center for Safe and Healthy Children

Trauma Treatment Replication Center

Cincinnati Children's Hospital

Advisory Board Member, National Center for School Crisis and Bereavement

Cincinnati, OH