# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

Carl C. Bell, M.D.

President/C.E.O., Community Mental Health Council

Acting Director, Institute for Juvenile Research

Professor, Department of Psychiatry and School of Public Health

Chicago, IL

Judith Cohen, M.D.

Medical Director, Center for Traumatic Stress in Children and Adolescents Allegheny General Hospital

Professor of Psychiatry

Drexel University College of Medicine

Pittsburgh, PA

Daniel I. Galper, Ph.D.

Director of Research and Special Projects American Psychological Association

Washington, DC

Malcolm Gordon, Ph.D.

Center for Mental Health Services Substance Abuse and Mental Health Services Administration

Rockville, MD

Frank Putnam, M.D.

Director, Mayerson Center for Safe and Healthy Children

Trauma Treatment Replication Center

Cincinnati Children's Hospital

Advisory Board, National Center for School Crisis and Bereavement

Cincinnati, OH

Bessel van der Kolk, M.D.

Professor of Psychiatry

Boston University Medical School

Past President, International Society for Traumatic Stress Studies

Founder and Medical Director, Trauma Center at Justice Resource Institute

Brookline, MA