# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Joanna Siegel, R.N., S.M., S.D., and our former Task Order Officer, Sonia Tyutyulkova, M.D., Ph.D., as well as our Associate Editor for this Comparative Effectiveness Review, Thomas Trikalinos, M.D., Ph.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel, all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI-UNC EPC. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, EPC Project Manager; Sharon Barrell, Justin Faerber, Laura Small, and Jennifer Drolet, editors; and Loraine Monroe and Judy Cannada, documentation preparation specialists.