# Discussion

This section begins with a summary of key findings and strength of evidence (SOE) for each Key Question (KQ), followed by sections on the applicability of the findings, the limitations of the comparative review process, the limitations of the evidence base, and gaps in the evidence that may benefit from future research.

## Key Findings and Strength of Evidence

### Overview

Overall, the evidence from 21 trials and 1 observational study (20 articles) evaluated 6 types of interventions targeting children exposed to trauma (7 studies, 8 articles)51-57 and 13 types of interventions targeting children already experiencing traumatic stress symptoms (15 studies, 16 articles).58-61,63-66,68-71 These interventions were marked by substantial heterogeneity in components, dose, frequency, involvement of family members, and mode and method of delivery. The wide variety of approaches presented challenges to attempts to combine or categorize interventions as we had anticipated.

Although we identified numerous potential interventions in our protocol, very few studies examining these interventions met our inclusion criteria, likely because the interventions have not been implemented among children with trauma from sources other than maltreatment or sexual abuse. For example, we did not find any evidence on child-parent psychotherapy, an intervention primarily used for maltreated children.

We also dropped 35 studies for high risk of bias. We most commonly eliminated studies with high risk of bias because of selection bias (n=30), including poor randomization and lack of allocation concealment for trials and failure to control for confounding factors for observational studies (see Appendix E for further details). Other common reasons for the removal of studies with high risk of bias included attrition bias or differential attrition bias (n=12; e.g., loss to followup of ≥20% or differential loss to followup of ≥15% without appropriate handling of missing data), detection bias (n=11; e.g., bias in outcome assessment), and performance bias (n=9; e.g., not controlling for concurrently occurring or unintended interventions) Of these, we dropped 34 of 35 for multiple reasons; we dropped only 1 study with a single reason for the high risk of bias rating that invalidated all findings: a 77% drop-out rate (see Appendix E for more details). Having a study design less rigorous than a controlled trial did not drive our decision to drop the study for high risk of bias; we excluded only 4 of these 35 studies that had observational (prospective cohort) study designs. Most of these studies dropped for high risk of bias tested interventions similar to those included in our review (e.g., psychotherapeutic interventions such as cognitive behavioral therapy (CBT), eye movement desensitization and reprocessing (EMDR), exposure therapies, school-based interventions including Cognitive Behavioral Intervention for Trauma in Schools (CBITS) and pharmacotherapeutic interventions such as sertraline and other selective serotonin reuptake inhibitors [SSRIs]). Although high risk of bias studies may have added to some of the sparse evidence in this literature, their inclusion would not have materially altered strength of evidence because they would not have increased our confidence in the estimate of effect.

### Key Question 1 Treatment Based on Trauma Exposure

We sought evidence on the effectiveness of interventions targeting children exposed to trauma on a range of traumatic stress, mental health, physical health, and other outcomes. These included the following:

- Prevention of and reduction in traumatic stress symptoms or syndromes (e.g., post-traumatic stress disorder [PTSD], acute stress disorder [ASD], developmental trauma disorder [DTD])
- Prevention of or reduction in mental health conditions or symptoms (e.g., depression, anxiety)
- Prevention of or reduction in physical health conditions or symptoms (e.g., sleep disorders, eating disorders, pain, overweight or obesity, asthma, cardiovascular problems, gastrointestinal problems, headaches)
- Reduction in risk-taking behaviors (including substance use), behavioral problems (including conduct disorder and attention deficit hyperactivity disorder [ADHD]), or criminal activities
- Healthy development, including improvements in interpersonal/social functioning or reductions in signs of developmental regression
- School-based functioning
- Improvements in quality of life
- Decreased suicidality

At least one outcome from each included study had to relate to the assessment of trauma symptoms or syndromes. We also included findings that showed non-beneficial outcomes associated with the intervention (e.g., no significant changes in outcomes between groups or significantly worse outcomes in the intervention group).

#### Summary of Findings by Intervention

Seven studies (in eight articles) on six different interventions provided information on a subset of these outcomes.51-57 Five interventions evaluated a variety of psychotherapeutic approaches compared with wait-list controls,54-56 no treatment,51,52 usual care,50 and supportive therapy53; the sixth intervention evaluated the efficacy of propranolol compared with placebo.57 The propranolol study57 and the early psychological intervention study50 found no improvement in any outcomes. All other interventions reported some improvement in one or more outcomes.51-56 Notably, three of the four interventions showing evidence of benefit (trauma-focused cognitive behavioral therapy [TF-CBT] and both mixed school groups interventions, ERASE Stress and Overshadowing the Threat of Terrorism) compared outcomes from interventions with outcomes from wait-list controls or no intervention.51,52,54-56 The Child and Family Traumatic Stress Intervention (CFTSI) trial was the only study showing evidence of benefit with an active group comparator.53

#### Summary of Findings Across Interventions

Table 72 presents a summary of the SOE across all evaluated outcomes for interventions targeting children exposed to trauma. All studies evaluated traumatic stress symptoms, although the specific measure varied by study. Five studies (four treatment types) evaluated PTSD diagnosis53-57; of these, three studies (two treatment types, CFTSI and mixed school group ERASE Stress) found evidence of improvement favoring intervention arms.53-55 Four studies (three treatment types) evaluated severity of PTSD symptoms54-57; three studies representing two treatments found evidence of improvement favoring intervention arms (both school-based interventions).54-56 Three studies (one study presented in two publications) evaluating PTSD symptoms found evidence of improvement51-53,56; the early intervention study found no benefit (early psychological intervention).50

Table 72 Summary of strength of evidence grades for interventions to prevent traumatic stress symptoms (Key Question 1)

Intervention | Comparator | Number of Studies | PTSD Diagnosis | PTSD Severity | PTSD Symptoms | Anxiety | Depression | Dissociative Symptoms | Somatic Complaints | Physiological Reactivity | Functional Impairment | Behavioral Problems
Trauma-focused cognitive behavioral therapy (school group and individual) | No treatment | 1^51,52^ | NE | NE | L (+) | NE | L (+) | NE | NE | NE | NE | NE
Child and Family Traumatic Stress Intervention | Supportive therapy | 1^53^ | L (+) | NE | L (+) | L (+) | NE | I | NE | NE | NE | NE
Mixed (psychoeducational material, cognitive behavioral skills, meditative practices, bio-energetic exercises, art therapy, narrative techniques, and home assignments) ERASE Stress (school groups) | Wait-list control that received religious classes | 2^54,55^ | L (+) | L (+) | NE | NE | L (+) | NE | L (+) | NE | L (+) | NE
Mixed (psychoeducational material and skills training with meditative practices, bio-energy exercises, art therapy, and narrative techniques for reprocessing traumatic experiences) Overshadowing the Threat of Terrorism (school groups) | Wait-list control | 1^56^ | I | L (+) | L (+) | L (+) | NE | NE | L (+) | NE | L (+) | NE
Early psychological intervention | Usual care | 1^50^ | NE | NE | I | NE | I | NE | NE | NE | NE | I
Propranolol | Placebo | 1^57^ | I | NE | I | NE | NE | NE | NE | I | NE | NE

I = insufficient strength of evidence due to lack of evidence of effect; L (+) = low strength of evidence of benefit; NE = not evaluated by study authors; PTSD = post-traumatic stress disorder

Six studies evaluated mental health outcomes, specifically anxiety, depression, and dissociative symptoms.50-55,56 Both studies evaluating anxiety53,56 reported improvement in anxiety; three studies evaluating depression51,52,54,55 reported improvement in depression and the early psychological intervention found no improvement in depressives symptoms50; and one study found no improvement in dissociative symptoms.53

Four studies evaluated physical health outcomes.54-57 All three that evaluated somatic complaints found evidence of benefit favoring the intervention arm.54-56 A single study evaluating physiological reactivity found no evidence of benefit.57

Regarding other outcomes, all three studies that evaluated functional impairment found evidence of benefit.54-56 The single study that evaluated behavior problems found no evidence of benefit.50

#### Summary of Findings by Outcome

Appendix F presents detailed findings by outcome for interventions with some evidence of benefit. We rated the evidence as low for all these outcomes, based on the limited number of studies (generally no more than one study per intervention) and small sample sizes.

### Key Question 2 Treatment Based on Trauma Exposure and Already Having Symptoms

As in KQ 1, we sought evidence of the effectiveness of interventions designed to treat children exposed to trauma who were already experiencing symptoms on a variety of traumatic stress, mental health, physical health, and other outcomes. These included the following:

- Remission of PTSD
- Reduction in severity or number of traumatic stress syndromes or symptoms
- Prevention of or reduction in co-occurring mental health conditions or symptoms (e.g., depression, anxiety)
- Prevention of or reduction in co-occurring physical health conditions or symptoms (e.g., sleep disorders, eating disorders, pain, overweight or obesity, asthma, cardiovascular problems, gastrointestinal problems, headaches)
- Reduction in risk-taking behaviors (including substance use), behavioral problems (including conduct disorder and ADHD), or criminal activities;
- Healthy development including improvements in interpersonal/social functioning or reductions in signs of developmental regression
- School-based functioning
- Improvements in quality of life
- Decreased suicidality

As with KQ 1, at least one outcome from each included study had to relate to the assessment of trauma symptoms or syndromes. We also included findings that showed non-beneficial outcomes associated with the intervention (e.g., no significant changes in outcomes between groups or significantly worse outcomes in the intervention group).

#### Summary of Findings by Intervention

Fifteen studies reported on a subset of outcomes for 13 different interventions.47,49,58-70 Ten of 13 interventions (presented in 12 studies47,49,58-67) evaluated a variety of psychotherapeutic approaches; of these interventions, 5 interventions reported in 7 studies compared outcomes with wait-list controls47,58,59,63,64,66,67 and 2 with usual care.49,65

Three interventions used active comparators: one compared outcomes for narrative exposure therapy with meditation-relaxation therapy outcomes,60 one grief- and trauma-focused intervention (GTFI) compared group therapy with individual therapy,61 and a third compared outcomes for GTFI with coping skills and narrative processing with GTFI with coping skills only.62 Three of 13 interventions focused on medications: one compared imipramine to chloral hydrate,68 a second compared imipramine to fluoxetine and placebo;69 and a third compared sertraline to placebo.70

As in the cluster of studies reporting on interventions targeting children exposed to trauma, no pharmacological interventions found evidence of benefit for any outcome, and the sertraline study suggested that the intervention arm fared worse than the control arm.70 Three studies with active arms (Narrative Exposure Therapy, and both GFTI treatments) did not report evidence of benefit for any outcome.60,61 All other interventions that compared outcomes to wait-list controls found some evidence of benefit for one or more outcomes.58,59,63,64,66

#### Summary of Findings Across Interventions

Table 73 presents a summary of the SOE across all evaluated outcomes for interventions targeting children exposed to trauma who already had symptoms. All studies evaluated traumatic stress symptoms, although the specific measure varied by study.47,49,58-70 Four studies evaluated PTSD diagnosis58,60,62,63; of these, two found evidence of improvement favoring intervention arms (TF-CBT, EMDR).58,63 Fifteen studies evaluated PTSD symptoms, but only four interventions were graded as having low SOE of improvement.58,59,63,65 One study suggested evidence of worse outcomes for the intervention arm, sertraline, compared with the placebo arm for parent-rated PTSD symptoms and clinician-rated PTSD severity.70

Table 73 Summary of strength of evidence grades for interventions to treat traumatic stress symptoms (Key Question 2)

Intervention | Comparator | Number of Studies | PTSD Diagnosis/criteria | PTSD Severity | PTSD Symptoms | Anxiety | Depression | Internalizing Behavior | Physical Symptoms | General Functioning | Psychosocial Dysfunction | Acting Out/aggression | Shyness/anxiety | Learning | Quality of Life | Externalizing/Conduct Problem Behavior | Global Distress | Anger | Supernatural Complaints
Trauma-focused cognitive behavioral therapy | Wait-list control | 1^58^ | L (+) | NE | L (+) | L (+) | L (+) | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Cognitive processing therapy | Wait-list control | 1^59^ | NE | NE | L (+) | NE | L (+) | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Narrative Exposure Therapy | Meditation-relaxation therapy | 1^60^ | I | NE | I | NE | NE | NE | I | I | NE | NE | NE | NE | NE | NE | NE | NE | NE
Grief- and Trauma-Focused Intervention-Group | Grief- and trauma-focused intervention-individual | 1^61^ | NE | NE | I | NE | I | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Grief-and Trauma-Focused Intervention with Coping Skills and Narrative Processing | Grief-and trauma-focused intervention with coping skills only | 1^62^ | I | NE | I | I | I | I | NE | NE | NE | NE | NE | NE | NE | I | I | NE | NE
Emotion Regulation Therapy | Relational supportive therapy | 1^49^ | NE | NE | I | I | I | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | I | NE
Eye movement desensitization and reprocessing | Wait-list control | 1^63^ | L (+) | NE | L (+) | I | I | I | I | I | NE | NE | NE | NE | NE | I | NE | NE | NE
Cognitive Behavioral Intervention for Trauma in Schools | Wait-list control | 2^47,64^ | NE | NE | I | NE | L (+) | NE | NE | NE | L (+) | I | I | I | I | NE | NE | NE | NE
Trauma and grief component therapy (school groups) | Usual care | 1^65^ | NE | NE | L (+) | NE | L (+) | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Mixed (CBT techniques and creative expressive elements) (school groups) | Wait-list control | 2^66,67^ | NE | NE | I | I | I | NE | NE | I | I | I | NE | NE | NE | L (+) | NE | NE | I
Imipramine | Chloral hydrate or placebo | 2^68,69^ | NE | NE | I | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Fluoxetine | Placebo | 1^69^ | NE | NE | I | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE | NE
Sertraline | Placebo | 1^70^ | NE | L (-) | L (-) | NE | I | NE | NE | NE | NE | NE | NE | NE | L (-) | NE | NE | NE | NE

CBT = cognitive behavioral therapy; I = insufficient strength of evidence due to lack of evidence of effect; L (+) = low strength of evidence of benefit; L (-) = low strength of evidence of no benefit; NE = not evaluated by study authors; PTSD = post-traumatic stress disorder

Twelve studies representing 10 interventions evaluated mental health outcomes, specifically anxiety, depression, and internalizing symptoms.47,49,58,59,61-67,70 Six studies reported no improvement in one or all outcomes evaluated.49,61-63,66,70 One58 of 5 interventions reported in 6 studies49,58,62,63,66,67 evaluating anxiety symptoms reported improvements; 4 interventions reported in 5 studies47,58,59,64,65 out of 10 interventions reported in 12 studies47,49,58,59,61-67,70 were graded as having low SOE for improvement in depression; and 2 studies found no improvement in internalizing behaviors.62,63

Two studies evaluated physical symptoms or general health outcomes; neither found evidence of benefit.60, 63

Seven studies60,62-64,66,67,70 evaluated a range of other outcomes, including functional symptoms, psychosocial dysfunction, acting out or aggression, shyness/anxiety, learning problems, quality of life, externalizing/conduct problem behaviors, global distress, anger, and supernatural complaints. One study suggested evidence of worse quality of life outcomes for the intervention arm, sertraline, compared with the placebo arm.70 Two60,63 of three studies evaluating general functioning did not find evidence of benefit. A third study found mixed results.66 One study found evidence of benefit for the intervention arm on psychosocial dysfunction.64 One67 of three studies62,66,67 found evidence of benefit for the intervention arm on externalizing/conduct problem behavior. No studies found any evidence of benefit for acting out or aggression, shyness, learning problems, quality of life, externalizing/conduct problem behaviors, global distress, anger, or supernatural complaints.

#### Summary of Findings by Outcome

Appendix F presents detailed findings by outcome for interventions with some evidence of benefit. We rated the evidence as low for all of these outcomes, based on the limited number of studies (generally no more than one study per intervention and no intervention having more than two studies combined) and small sample sizes.

### Key Question 3 Treatment Subgroup Comparisons for Interventions Targeting Children Exposed to Trauma, Some of Whom Already Have Symptoms

Our review found only two studies that examined subgroup characteristics that moderated the effect of the interventions tested by an interaction term. We elected not to summarize findings that merely presented results stratified by subgroups because of the risk of overinterpreting results from underpowered subsamples. Both studies that examined subgroup characteristics that moderated the effect of an intervention on an outcome were school-based interventions: one intervention examined the effect of TF-CBT targeting children exposed to trauma51 and a second examined the effect of CBT on treatment of trauma-exposed children who already had symptoms at baseline.71 Both examined sex subgroups; in addition, one study evaluated age group and exposure to violence.71 The TF-CBT study did not find any differences in relationship between intervention and PTSD symptoms or depression.51 The CBT study found no significant differences by age group or exposure to violence with respect to PTSD symptoms or functional impairment. The study did, however, find significant differences by sex suggesting that the intervention effect on PTSD symptoms and functional impairment were greater for girls than boys.71 Table 74 presents the findings of the single trial with evidence of subgroup differences with respect to intervention efficacy.

Table 74 Summary of results for child post-traumatic stress disorder treatment subgroup comparisons (Key Question 3)

Subgroup | Intervention | Comparator | Number of Trials, Number of Participants | Outcome | Strength of Evidence and Magnitude of Effect | Type of Exposure
Sex | Mixed school group | Wait-list control | 1,^66^ 403 | PTSD symptoms | Low; intervention effect on reducing PTSD symptoms significantly greater for female than male students (G1: -0.090 [-0.161 to -0.019] vs. G2: 0.060 [-0.011 to 0.131]) | Poverty and political violence/ instability
Sex | Mixed school group | Wait-list control | 1,^66^ 403 | Functional impairment | Low; intervention effect on reducing functional impairment significantly greater for female than male students (G1: -0.120 [-0.179 to -0.061] vs. G2: 0.012 [-0.047 to 0.071]) | Poverty and political violence/ instability

G = group; KQ = Key Question; PTSD = post-traumatic stress disorder

### Key Question 4 Harms Associated With Interventions Targeting Children Exposed to Trauma, Some of Whom Already Have Symptoms

Five studies reported harms associated with interventions.58,65,68-70 One study examined harms of TF-CBT versus wait-list control and found no adverse events in study group or control.58 No mention was made of how harms were assessed or evaluated.

A second study examined the harms of trauma and grief component therapy (TGCT) for adolescents with classroom-based psychoeducation and skills training versus the classroom-based psychoeducation and skills training alone.65 The study used a Reliable Change Index (RCI) for post-traumatic stress, depression, traumatic grief, and existential grief in order to quantify the number of reliably deteriorated cases. The authors found no significant differences in reliable deterioration for post-traumatic stress, depression, traumatic grief, and existential grief by study arm at post-treatment or at 4-month followup.

Three studies evaluated the harms of medications.68-70 Two studies found no adverse events for imipramine compared with chloral hydrate68 or placebo,69 or for imipramine compared with fluoxetine.69 These studies did not, however, report how adverse events or harms were assessed. One study found no significantly increased adverse events with sertraline in any adverse events, disturbed sleep, agitation, headache, abdominal pain, nausea, pharyngitis, vomiting, accidental injury, respiratory tract infections, diarrhea, dizziness, hyperkinesis, rhinitis, or by study arm. The study also reported some incidents of severe adverse events (undefined), serious adverse events (undefined), dry mouth, and dysmenorrhea among patients taking sertraline compared with none for patients in the placebo arm. The study reported higher incidents of dropouts due to adverse events, increased suicidality ratings, and active suicidality in the sertraline arm compared with the placebo arm but did not report the results of statistical significance tests.70

## Findings in Relation to What Is Already Known

Few systematic reviews have evaluated the treatment of traumatic stress in children; those that have done so have generally combined maltreatment as a form of trauma with single-episode exposure to trauma and trauma other than maltreatment. Because of the complicated relationship dynamics between a child and an abusive or neglectful parent, interventions might impact these groups differently. Generalizing the results of treatments found to be effective with a maltreated population to children with other types of trauma may mislead clinicians and policymakers. In addition, the focus or essential components of treatments targeting maltreated children with traumatic stress may differ significantly. This review attempts to decrease the heterogeneity of the population, thereby increasing the specificity of results, by examining interventions targeting children exposed to potentially traumatic events other than child maltreatment.

Our view of the heterogeneity of this population reflects ongoing debates about diagnostic classification. Van der Kolk notes that a child who experiences trauma as a single isolated exposure may be more likely to present with a discrete conditioned or behavioral response73; this difference has led experts in the field to propose a new diagnostic classification for the “Diagnostic and Statistical Manual of Mental Disorders, 5th Edition” (DSM-V), the Complex Developmental Trauma Disorder, to capture the impact of trauma in children who may experience ongoing traumatic stress from a young age. This proposed classification is intended to capture the experience of multiple or chronic and prolonged developmentally adverse traumatic events, most often of an interpersonal nature.

Despite the heterogeneity of these populations, some interventions investigated in children with a history of maltreatment or neglect may also hold promise in treating children with traumatic stress that is not related to maltreatment. Examples include child-parent psychotherapy (CPP), an empirically validated treatment for children under the age of 6 years that has been found to be effective with children with a history of exposure to intimate partner violence,28 and parent-child interaction therapy (PCIT), an effective treatment for children with behavior problems and for children with a history of abuse.74 Both CPP and PCIT include treatment components that may offer assistance to families with a child with traumatic stress other than maltreatment, particularly because they involve close collaboration with the caregiver. We found no evidence of these interventions that met our study criteria. In addition, the companion review that evaluated treatment of maltreated children found a few studies that tested interventions such as CPP or PCIT on outcomes such as recidivism and healthy caregiver-child relationships. The companion review found similar limitations as our review in volume and type of evidence: it found sparse evidence on interventions targeting maltreated children, with most trials being single studies that could not be combined, with low sample sizes and few head-to-head comparisons. Both reviews conclude that strong recommendations cannot be made based on the findings. Differences in interventions, outcomes, and patient characteristics across the two reviews precluded additional synthesis of the findings.

Symptoms of depression and anxiety are common among children with PTSD. Pharmacological interventions such as SSRIs and psychotherapy such as CBT that are effective in the treatment of depression and anxiety in children may also be found to be effective with children exposed to traumatic stress. TF-CBT is one such treatment that has been modified for use with children with traumatic stress. We found two studies demonstrating the effectiveness of TF-CBT when compared with wait-list control groups,51,52,58 but no head-to-head trials. We found two studies on SSRIs, specifically on fluoxetine and sertraline, comparing outcomes with children in a placebo arm. Neither found evidence of effectiveness.69,70

## Implications for Clinical and Policy Decisionmaking

The lack of definitive evidence on interventions targeting children exposed to trauma, some of whom already have symptoms, makes it challenging to identify clear recommendations for clinical and policy decisionmaking. The most compelling implications of our results relate to future research. Our results clearly indicate the need for more research for all types of interventions using randomized controlled trials (RCTs) with head-to-head comparisons of interventions with active comparators, for possibly relevant interventions such as CPP and PCIT, for studies on pharmacological interventions, and for assessment of interventions more efficacious in particular subgroups. Additional research using valid and reliable measures such as clinical interviews to assess symptoms of traumatic stress and different traumatic stress syndromes such as developmental trauma disorder (DTD) is also needed. Because these trials are time-consuming and typically expensive, investigators may wish to consider alternative approaches to gathering evidence such as system monitoring and reporting on the uses of interventions in different practice settings to determine the effectiveness of interventions for children exposed to specific types of trauma.

We note the difficulty of conducting large-scale trials and maintaining retention among children with traumatic stress symptoms. The potential for commercial sponsorship of studies in this population is also unclear. One potential pathway for funders of research is the use of practice-based research. The Centers for Medicare and Medicaid Services (CMS) offers a policy of coverage with evidence development to allow reimbursement for novel or unproven interventions while simultaneously generating evidence for evaluation. This type of approach may serve as a model for public and private payers for generating new evidence on a relatively small and difficult-to-reach population that often receives off-label interventions.

Research is sparse on interventions targeting children who have been exposed to traumas other than maltreatment and family violence but who are not necessarily already exhibiting clinical syndromes (e.g., PTSD). However, some psychotherapy interventions targeting children exposed to trauma appear promising based on study design rigor and magnitude and precision of effects found, with no associated harms reported. These interventions include ERASE Stress (a mixed school-based group intervention) and CFTSI. There was less compelling evidence regarding potentially promising interventions targeting children with trauma exposure with already existing symptoms or syndromes. Although some individual psychotherapy studies found significant decreases in traumatic stress symptoms or syndromes and related psychopathology (e.g., depression, anxiety) and dysfunction, the low sample sizes, small magnitudes of effect, and low generalizability found in many of these studies preclude definitive recommendation. Based on the preliminary evidence in this systematic review, clinicians and policymakers facing a choice of options may elect to focus on therapies with some evidence of effectiveness. Because clinical care rarely comprises exact manualized interventions, clinicians might also seek to create patient-centered treatments composed of specific components of several interventions that have particular theoretical, evidence-based, or anecdotal benefits. Additional research focused on testing these specific components rather than a particular standardized intervention may further promote the creation of efficacious, individualized, treatments.

### Applicability

As noted, during the review process we systematically abstracted key factors that may affect the applicability of the evidence base. We identified these key factors a priori, using as our guidepost the definition of applicability provided by the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care (EHC) Program that defines applicability as “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under real-world conditions.”75 Additionally, we explicitly sought to identify factors that related to each element of the population, intervention, comparators, outcomes, timing, and setting (PICOTS) framework that was used to guide the review. In the following sections, we present the major issues that emerged from our analysis of factors affecting the applicability of the evidence base.

### Population

The evidence base of interventions for children exposed to traumas other than sexual trauma and family violence is limited. Although age groups represented by individual studies range from 7 to 17 years of age and in some cases older (up to 19 years of age), only 2 studies included children younger than 7 years of age.68,69 No studies that addressed KQ 1 that recruited children exposed to a traumatic event (but did not assess for already occurring symptoms) included children younger than 7 years of age. In addition, the type of exposure varied widely across studies. The studies that addressed KQ 1 included two studies of children exposed to a natural disaster, two studies of children exposed to war/terrorism, three studies of children exposed to accidents, and one study with mixed trauma types. The treatment studies that addressed KQ 2 included children who had trauma exposure and were already experiencing symptoms, but trauma type also differed across studies. Three of the four pharmacotherapy studies57,68,69 included children treated in an emergency room who had experienced accidents (motor vehicle, thermal injuries, or mixed) and were experiencing acute stress symptoms.68,69 The applicability of these findings is unknown in children exposed to mixed traumas, natural disasters, war or political violence, or other types of traumas. Thus, the applicability of the evidence is somewhat limited to characteristics of children included in each specific study.

### Intervention

The evidence base reflects the diverse range of intervention approaches in the field. Several interventions noted in the evidence base were not found in this review. Only 4 interventions (2 ERASE Stress school-based mixed intervention trials and 2 CBITS trials) addressing KQ 2 were able to be combined in the evidence table. Most interventions varied in intensity as well, with delivery ranging from 4 to 20 sessions for the psychotherapies and from 1 to 10 weeks for medication administration in the pharmacotherapeutic interventions. Most were lower intensity (up to 12 weekly sessions or approximately 3 months in duration) and only 1 intervention65 was of medium intensity (13 to 24 weekly sessions or approximately 6 months in duration). The majority of studies delivered the intervention under more ideal than real-world conditions, such as by staff with specialized training and/or under close supervision of a highly specialized clinician (often the intervention developer). As noted, the interventions analyzed in the results all indicated the use of a manual. However, the interventions appear to vary considerably in the degree to which they are ready for dissemination, and studies offer minimal discussion of fidelity in the literature we reviewed. Thus, studies do not provide clarity on whether children received interventions as manualized or adapted interventions fit to the target population. Therefore, the potential for translation of these interventions into real-world settings is unclear.

### Comparators

The evidence was primarily composed of studies that used inactive controls, usual care, or wait-list76-78 controls. For treatment studies addressing KQ 2, only two trials were head-to-head comparisons,61,62 and only one pharmacotherapy was a head-to-head comparison of two different types of antidepressants69 versus a third (control) group. The other interventions addressing KQ 1 consisted of two inactive control comparisons,51,52 two usual care comparators,50,53 and three wait-list controls,54-56 and, for the single pharmacotherapy trial, one placebo comparator. Most of the remaining KQ 2 psychotherapy trials47,58-60,63,64,66,67 utilized wait-list control comparators; two trials had usual care comparators.49,65 The KQ 2 pharmacotherapy trials used more rigorous sets of comparators, including a usual care comparator (chloral hydrate)68 and a placebo comparator.70

### Outcomes

Of the many outcomes searched for in the literature, relatively few were found in the studies included in this review. For example, no studies examined decreased suicidality as a study outcome; risk-taking behaviors such as substance use; conduct disorders; criminal activities; or individual physical health conditions such as obesity, cardiovascular disease, or sleep problems. Thus, the applicability of these types of outcomes that concern clinicians is unknown. In addition, no studies relied on clinician diagnosis of PTSD either during the baseline period or during followup. Studies that did examine PTSD diagnosis as an outcome53-58,60,63 used a self-reported diagnostic instrument such as the UCLA PTSD Index and Child PTSD Symptom Scale (CPSS). None of the mental health outcomes examined were assessed via clinician diagnosis. The evidence base for the efficacy or effectiveness of trauma interventions in improving trauma symptoms or syndromes, mental health outcomes, physical health outcomes, and other outcomes such as functional impairment and quality of life was mostly based on child self-report, with few relying on parent reports47,62-64,66 or teacher reports47,64 of impairment or behaviors. Most of the outcomes were measured at baseline and followup at the end of the intervention. Few followups were completed at multiple end points, and the long-term effects of the interventions are largely unknown. These limitations on outcome measures reduce the applicability for clinicians needing to choose a treatment based on these findings.

### Setting

Nearly half of the studies were conducted outside the United States, including Armenia,51,52 Sri Lanka,54,60,67 Israel,55,56 London,58 Bosnia,65 Switzerland50 and Indonesia.66 Several studies conducted in the Middle East and Asia that were delivered in school settings54-56,67 may not be applicable to school settings in the United States. A majority of the pharmacotherapies recruited subjects via the emergency room,57,68,69 with followup either in the hospital during an inpatient stay or in an outpatient setting.

## Limitations of the Review Process

As discussed in the previous section, the applicability of our systematic review is limited given the population, outcomes, and setting limits we placed on our included studies. Our exclusions, described in the methods, served to focus the review (particularly in relation to its companion on interventions to address child maltreatment) and to control for sources of heterogeneity. Nonetheless, these exclusions necessarily limited the scope of this review. We describe important limitations below.

First, several of our population criteria limited the review. We focused our review exclusively on children 17 years of age or younger because of the differences in intervention types, outcomes of interest, and developmental aspects of how adults and children process traumatic events. Effectiveness of adult treatments for trauma exposures are covered in a separate AHRQ review.79 We also excluded studies that examined children exposed to maltreatment or family violence, also described in a separate AHRQ review,36 because of the critical differences in these types of trauma exposures and the associated impact on type and delivery of the intervention.

Our outcome criteria also limited our review. We required studies report change in traumatic stress symptoms or syndromes as an outcome to align with our primary objective of examining intervention effectiveness on these outcomes. The criterion requiring traumatic stress symptoms or syndromes as at least 1 study outcome resulted in the exclusion of 16 articles that were identified through our search strings, but did not report on traumatic stress symptom outcomes. The nature of trauma interventions targeting other mental health conditions and functioning such as suicide or conduct problems may differ in objectives, design, and delivery from trauma interventions targeting traumatic stress symptoms or syndromes. We included these other types of outcomes as secondary outcomes of interest for studies that examined traumatic stress symptoms or syndromes as an outcome because of the importance of identifying other potential benefits that results from a single intervention.

Additional criteria served to further focus our review. We required a publication date of 1990 or later to focus on supportive evidence from currently relevant treatments because of the evolving nature of the field. We also required a sample size of 10 or more to ensure that we focused on hypothesis-testing studies rather than descriptive accounts from case series or case reports. We excluded these study designs as well as cross-sectional, nonsystematic reviews, retrospective cohort studies, and non-nested case control studies, because these types of study designs make isolating the effect of an intervention difficult to validly assess. Finally, we excluded studies that were not written in English, thus decreasing the applicability to countries where researchers publish in other languages.

Finally, as noted previously, we limited the synthesis to trials and observational studies with low and medium risk of bias. Given the limitations of the included studies and their applicability to other contexts, however, including high risk-of-bias studies would likely have increased the pool of evidence without resulting in more actionable evidence.

## Limitations of the Evidence

This Comparative Effectiveness Review finds that the field of interventions targeting children exposed to trauma other than maltreatment or family violence is still in its infancy. Although we found no evidence of publication bias from our review of scientific information packets and grey literature, we found very few trials that addressed each of the KQs of intervention efficacy, especially whether efficacy differed by subgroups or whether the interventions were associated with harms. Most were unique interventions; thus, combining the findings across studies or replicating significant findings was not permitted from the evidence base. Furthermore, several of the known types of interventions used to treat child traumatic stress (noted in the introduction section) were not found in any study included in this review. Thus, the efficacy of these types of interventions (e.g., CPP, Skills Training in Affective and Interpersonal Regulation/Narrative Story-Telling [STAIR/NST], dialectical behavior therapy [DBT], structured psychotherapy for adolescents responding to chronic stress [SPARCS], PCIT, trauma systems therapy [TST], particular antidepressants, stimulants, antipsychotics, benzodiazepines, equine-assisted psychotherapy) to treat children exposed to trauma other than maltreatment or family violence was not evaluated in this review.

Data on pharmacological interventions are sparse and marked by methodological limitations. Only one trial targeted children exposed to trauma, and three trials focused on treatment trials for children already experiencing symptoms. These pharmacologic interventions were small trials and none had findings of benefit. Two trials administered medications for only 7 days; this duration is inadequate because antidepressants typically take 1-4 weeks to become effective.80 Reaching steady-state for serum concentrations for a medication such as fluoxetine typically takes longer than 7 days.81 None of the included studies determined the actual efficacy of fluoxetine administered for longer durations in concordance with usual practices. Finally, many other types of medications routinely used to treat traumatic stress in adults and children exposed to maltreatment and family violence have not been adequately tested in this population. In addition, the heterogeneity in samples, particularly with respect to child characteristics and type of trauma, makes synthesis of the findings difficult. Furthermore, most studies did not note or study the important clinical distinctions of whether each child had experienced a single trauma or multiple traumas, or whether each child had comorbid mental health conditions that can affect the efficacy of interventions on outcomes. Very few studies included young children (ages 5 or younger), and only one71 compared efficacy of an intervention across child age. These child characteristics, which are important to clinical decisions, have not been accounted for in the evidence base of interventions targeting children exposed to trauma other than maltreatment or family violence, some of whom already have symptoms.

Another limitation of the evidence base results from outcome assessment methods. The outcomes studied were mostly based on child self-reports. Few studies used a clinical interview to assess PTSD diagnosis or other mental health outcomes. Although controversy exists regarding whether PTSD is an appropriate diagnosis for children, determining whether an intervention can affect clinically meaningful syndromes of traumatic stress symptoms requires future research. As noted earlier, few included studies assessed longer-term outcomes.

Finally, the applicability of the findings is limited by setting and type of trauma exposure. Nearly half of the included studies (11 of 23) were conducted outside the United States. In addition, the findings of individual studies are applicable only to children with similar characteristics and exposure to the same types of trauma. The types of trauma experienced by children in the included studies varied widely. For example, of the seven PTSD studies targeting exposure to trauma that addressed KQ 1, two studies included children exposed to a natural disaster, two studies included children exposed to war/terrorism, two studies included children exposed to accidents, and 1 study included children with mixed trauma types. The treatment studies that addressed KQ 2 included children with similar heterogeneity. Findings may not translate across setting, culture, economic conditions, and trauma type.

## Research Gaps

Future studies on interventions targeting children exposed to trauma other than maltreatment and family violence, some of whom already have symptoms, are warranted for several reasons. First, the evidence base for well-designed interventions that lack sufficient bias addressing child trauma other than maltreatment and family violence is small. The heterogeneity in types of interventions prevented combining the results of more than two studies per intervention, thus precluding examination of the consistency of associations. No evidence was found for several interventions commonly used to treat children with trauma exposures. A published systematic review of sports and games interventions did not find any well-designed interventions that met their inclusion criteria, thus indicating a need for additional, well-designed studies in this field.45 Although most psychotherapy interventions were manualized for delivery, several did not assess treatment fidelity. In addition, only four pharmacotherapy trials were included in this review, and those trials did not study many types of commonly prescribed medications for children exposed to trauma.

Second, the sample sizes of the studies included in this review were small to medium. Identifying children with trauma exposure and obtaining informed consent limits the feasibility of recruiting large sample sizes for randomized controlled trials. Insufficient funding also may contribute to small sample sizes.

The small sample sizes created several problems with the reliability of the analyses and rendered subgroup analysis all but impossible. Thus, several analyses were likely underpowered to detect significant associations. The lack of power becomes even more problematic when attempting to adjust analyses for important covariates that may confound the relationship between the intervention and outcomes. Loss of subjects to followup makes the issues related to sample size even more pronounced. Subgroup analyses also become difficult with small sample sizes, evidenced by the review finding only two studies that examined the intervention-outcome link across varying subgroup characteristics. This is especially problematic given that the efficacy of particular interventions is thought anecdotally to differ across factors such as developmental age of the child and/or type, severity, or experience of single versus multiple traumas. Whether this hypothesis holds true in research trials remains unknown. The difficulty of conducting studies in this population suggests that future research may require focus on observational studies, including heightened attention to research involving registry data.

Third, the outcomes reported were largely based on self-report symptomatology instead of clinical interview diagnosis. Although there is controversy surrounding the appropriateness of the PTSD diagnosis in children, the use of a standardized interview to qualify clinical syndromes rather than changes in symptoms is needed. Demonstrating that a statistically significant change in symptoms is clinically relevant is difficult. The current shift to a more inclusive diagnostic system in DSM-V focused on DTD might inform future research efforts that target and treat children based on already occurring DTD and targeting prevention of DTD among exposed children. Only one study65 used the Reliable Change Index (RCI) to quantify whether symptom changes over time were differentially significant, although RCI was used to study harms (i.e., deterioration in symptoms over time) rather than improvements in outcomes. Few studies reported actual effect sizes. In addition, several important outcomes, such as suicidality, were not not tested in any trial included in this review.

Finally, few studies assessed harms associated with participating in a particular intervention. Although study dropouts could be quantified based on reported numbers of participants at baseline and each follow-up assessment, adherence to the protocol was not assessed in any study. Future studies of child trauma interventions require formal testing for harms, especially for risk of retraumatization.