# Conclusions

Our review uncovered a modest and heterogeneous body of evidence, marked by numerous interventions with a single study. We did not find studies that attempted to replicate findings of effective interventions; rather, studies tested unique interventions. No pharmacotherapy intervention demonstrated effectiveness; in one study of sertraline, children in the intervention arm tended to fare worse than those in the placebo arm.70 Studies demonstrating improvement in outcomes generally compared results of interventions with wait-list controls. With a single exception,53 studies comparing interventions with active controls did not show benefit. Some psychotherapy interventions targeting children exposed to trauma appear promising based on the magnitude and precision of effects found. These interventions were school-based treatments with elements of CBT. There was less compelling evidence regarding potentially promising interventions targeting children exposed to traumatic events already experiencing symptoms; each such intervention also had elements of CBT.

Authors typically evaluated short-term outcomes. The body of evidence provides no insight on how interventions targeting children exposed to trauma or already experiencing traumatic stress symptoms might influence healthy long-term development. We found very little evidence on how effectiveness might vary by child characteristics and no evidence on how effectiveness might vary by treatment characteristics or setting. We also found almost no evidence on harms associated with psychological treatments. Only pharmacological interventions attempted to assess harms in this vulnerable population.

Our findings may be interpreted as a call to action: psychotherapeutic intervention may be beneficial relative to no treatment, but far more research is required to produce definitive guidance on the comparative effectiveness of psychotherapeutic or pharmacological interventions targeting children exposed to trauma, some of whom already have symptoms.