# Summary of Results

Table F-1 Summary of results for interventions targeting children exposed to trauma (KQ 1)

Outcome | Intervention | Comparator | Number of Trials, Number of Participants | Strength of Evidence and Magnitude of Effect | Type of Exposure
PTSD diagnosis | CFTSI | Supportive therapy | 1,^1^ 106 | Low; difference of 4.54 points on the UCLA PTSD-RI Index favoring CFTSI | Mixed (MVA, sexual abuse, witnessing violence, physical assaults, injuries, threats of violence)
PTSD diagnosis | Mixed ERASE Stress (school groups) | Wait-list control that received religious classes | 2,^2, 3^ 273 | Low; significantly greater decrease in PTSD diagnosis on the UCLA PTSD-I in one study (24.7% greater decrease in proportion); second study significance not reported (11.3% greater decrease in proportion) | Natural disaster (tsunami); war/terror attacks
PTSD symptoms/severity | TF-CBT | No treatment | 1,^4, 5^ 65 | Low; difference of 19.2 points on child PTSD reaction index at 18 months favoring TF-CBT | Natural disaster (earthquake)
PTSD symptoms/severity | CFTSI | Supportive therapy | 1,^1^ 106 | Low; difference of 4.71 points on the TSCC PTS Index favoring CFTSI | Mixed (MVA, sexual abuse, witnessing violence, physical assaults, injuries, threats of violence)
PTSD symptoms/severity | Mixed ERASE Stress (school groups) | Wait-list control that received religious classes | 2,^2, 3^ 273 | Low; significantly greater decrease in PTSD symptom severity on the UCLA PTSD-I in both studies (mean differences of 7.21, 9.0) | Natural disaster (tsunami); war/terror attacks
PTSD symptoms/severity | Mixed Overshadowing the Threat of Terrorism (school groups) | Wait-list control | 1,^6^ 142 | Low; significantly greater decrease in PTSD symptoms on the UCLA PTSD-I (mean difference of 4.6) and significantly greater decrease in PTSD severity (mean difference of 12.1) | War/terror attacks
Depression symptoms | TF-CBT | No treatment | 1,^4, 5^ 65 | Low; difference of 5.7 points on Depression Rating Scale at 18 months favoring TF-CBT | Natural disaster (earthquake)
Depression symptoms | Mixed ERASE Stress (school groups) | Wait-list control that received religious classes | 2,^2, 3^ 273 | Low; significantly greater decrease in depression symptoms in both studies on the Brief Beck Depression Inventory (mean differences of 1.55,1.8) | Natural disaster (tsunami); war/terror attacks
Anxiety symptoms | CFTSI | Supportive therapy | 1,^1^ 106 | Low; difference of 5.52 points on the TSCC Anxiety Index favoring CFTSI | Mixed (MVA, sexual abuse, witnessing violence, physical assaults, injuries, threats of violence)
Anxiety symptoms | Mixed Overshadowing the Threat of Terrorism (school groups) | Wait-list control | 1,^6^ 142 | Low; significantly greater decrease in generalized anxiety symptoms (mean difference of 2.8) and significantly greater decrease in separation anxiety symptoms on the SCARED (mean difference of 2.4) | War/terror attacks
Somatic complaints | Mixed ERASE Stress (school groups) | Wait-list control that received religious classes | 2,^2, 3^ 273 | Low; significantly greater decrease in somatic complaints in both studies on the DPS (mean differences of 1.01, unknown magnitude in second study) | Natural disaster (tsunami); war/terror attacks
Somatic complaints | Mixed Overshadowing the Threat of Terrorism (school groups) | Wait-list control | 1,^6^ 142 | Low; significantly greater decrease in somatic complaints on the DPS (mean difference of 1.1) | War/terror attacks
Functional impairment | Mixed ERASE Stress (school groups) | Wait-list control that received religious classes | 2,^2, 3^ 273 | Low; significantly greater decrease in functional impairment in both studies on the DPS (mean differences of 2.45, 2.0) | Natural disaster (tsunami); war/terror attacks
Functional impairment | Mixed Overshadowing the Threat of Terrorism (school groups) | Wait-list control | 1,^6^ 142 | Low; significantly greater decrease in functional impairment on 4 items from the Childhood Diagnostic Interview Schedule (mean difference of 1.8) | War/terror attacks

Abbreviations: CTSFI = Child and Family Traumatic Stress Intervention; DPS = DISC Predictive Scales; MVA = motor vehicle accident; ERASE-Stress = Enhancing Resiliency among Students Experiencing Stress; PTSD = post-traumatic stress disorder; SCARED = Screen for Child Anxiety Related Emotional Disorders; TF-CBT = trauma-focused cognitive behavioral therapy; TSCC = Trauma Symptom Checklist for Children; UCLA PTSD-I = University of California, Los Angeles Post-Traumatic Stress Disorder – Index for DSM-IV.

Table F-2 Summary of results for child PTSD treatment interventions (KQ 2)

Outcome | Intervention | Comparator | Number of Trials, Number of Participants | Strength of Evidence and Magnitude of Effect | Type of Exposure
PTSD diagnosis | TF-CBT | Wait-list control | 1,^7^ 24 | Low; Cohen effect size 2.20 on the C-RIES scale favoring TF-CBT and Cohen effect size 1.59 on the CAPS-CA scale favoring TF-CBT | Mixed: MVA, assault, witnessed violence
PTSD diagnosis | EMDR | Wait-list control | 1,^8^ 27 | Low; 75% decrease in the EMDR group versus 0% change in the wait-list control group in number of children with 2 or more DSM IV criteria | MVA
PTSD symptoms/severity | TF-CBT | Wait-list control | 1,^7^ 24 | Low; Cohen effect size 2.48 on CPSS scale favoring TF-CBT | Mixed: MVA, assault, witnessed violence
PTSD symptoms/severity | CBITS | Wait-list control | 1,^9^ 126 | Low; difference of 7 points on CPSS favoring CBITS | Community violence
PTSD symptoms/severity | CPT | Wait-list control | 1,^10^ 38 | Low; difference of 10.09 points on PSS-SR scale favoring CPT and difference of 14.19 on Impact of Events Scale favoring CPT | Mixed
PTSD symptoms/severity | EMDR | Wait-list control | 1,^8^ 27 | Low; magnitude of effect not reported by intervention type | MVA
PTSD symptoms/severity | TGCT (school groups) | Wait-list control | 1,^11^ 159 | Low; reduction in PTSD symptoms of 6.18 favoring TGCT group | War-exposed in Bosnia
PTSD symptoms/severity | Sertraline | Placebo | 1,^12^ 129 | Low for no benefit; placebo with greater decrease in parent-rated PTSD symptoms over sertraline (LS mean difference 95% CI of -9.1, -0.6 with CSDC); placebo with greater decrease in clinician-rated PTSD severity via CGI-S (LS mean difference 95% CI of -0.8, 0) | Mixed
Depression symptoms | TF-CBT | Wait-list control | 1,^7^ 24 | Low; difference of 12.6 points on the RCMAS favoring TF-CBT | Mixed: MVA, assault, witnessed violence
Depression symptoms | CBITS | Wait-list control | 1,^9^ 126 | Low; difference of 3.4 points on CDI favoring CBITS | Community violence
Depression symptoms | CPT | Wait-list control | 1,^10^ 38 | Low; difference of 7.8 points on BDI scale favoring CPT | Mixed
Depression symptoms | TGCT (school groups) | Wait-list control | 1,^11^ 159 | Low; calculated mean between group difference of 2.78 points favoring TGCT | War-exposed in Bosnia
Anxiety symptoms | TF-CBT | Wait-list control | 1,^7^ 24 | Low; difference of 9.7 points on the DSRS favoring TF-CBT | Mixed: MVA, assault, witnessed violence
Functional impairment | Mixed school group | Wait-list control | 1,^13^ 403 | Low; significantly greater decrease in functional impairment on a 10 items child-reported checklist in treatment group at 1 week (effect size 0.42) and 6 months (effect size 0.26) postintervention | Poverty and political violence/ instability
Psychosocial dysfunction | CBITS | Wait-list control | 1,^9^ 126 | Low; difference of 6.4 points on PSC favoring CBITS | Community violence
Conduct Problems | Mixed school group | Wait-list control | 1,^14^ 397 | Low; significantly greater reduction in conduct problems in treatment group than wait-list group (LGCM estimate, SE: -0.132, 0.045; p<0.01) | War and political violence/instability
Quality of Life | Sertraline | Placebo | 1,^12^ 129 | Low for no benefit; placebo with greater improvement in quality of life than sertraline (LS mean difference 95%CI 0.2, 6.8) | Mixed

Abbreviations: BDI = Beck Depression Inventory; CAPS-CA = clinician-administered PTSD scale for children and adolescents; CBITS = Cognitive Behavioral Intervention for Trauma in Schools; CDI = Child Depression Inventory; CPT = cognitive processing therapy; C-RIES = Children's Revised Impact of Event Scale; CSDC = Child Stress Disorder Checklist; LOCF: last observation carried forward; DSRS=Depression Self-Rating Scale; EMDR = eye movement desensitization and reprocessing; MVA = motor vehicle accident; PTSD = post-traumatic stress disorder; PSC = Pediatric Symptom Checklist; RCMAS = Revised Children's Manifest Anxiety Scale; TF-CBT = trauma-focused cognitive behavioral therapy; TGCT = Trauma and Grief Component Therapy

Table F-3 Summary of results for child PTSD treatment subgroup comparisons (KQ 3)

Subgroup | Intervention | Comparator | Number of Trials, Number of Participants | Outcome | Strength of Evidence and Magnitude of Effect | Type of Exposure
Sex | Mixed school group | Wait-list control | 1,^13^ 403 | PTSD symptoms | Low; intervention effect on reducing PTSD symptoms significantly greater for female than male students (G1: -0.090 [-0.161 to -0.019] vs. G2: 0.060 [-0.011 to 0.131]) | Poverty and political violence/ instability
Sex | Mixed school group | Wait-list control | 1,^13^ 403 | Functional impairment | Low; intervention effect on reducing functional impairment significantly greater for female than male students (G1: -0.120 [-0.179 to -0.061] vs. G2: 0.012 [-0.047 to 0.071]) | Poverty and political violence/ instability

Abbreviations: PTSD: post-traumatic stress disorder; vs. = versus

## References

1 Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: secondary prevention for youth at risk of developing PTSD. J Child Psychol Psychiatry. Jun. 2011;52(6):676-85. [pmid: 20868370].
2 Berger R, Gelkopf M. School-based intervention for the treatment of tsunami-related distress in children: a quasi-randomized controlled trial. Psychother Psychosom. 2009;78(6):364-71. [pmid: 19738402].
3 Gelkopf M, Berger R. A school-based, teacher-mediated prevention program (ERASE-Stress) for reducing terror-related traumatic reactions in Israeli youth: A quasi-randomized controlled trial. J Child Psychol Psychiatry. Aug. 2009;50(8):962-71. [pmid: 19207621].
4 Goenjian AK, Walling D, Steinberg AM, et al. A prospective study of posttraumatic stress and depressive reactions among treated and untreated adolescents 5 years after a catastrophic disaster. Am J Psychiatry. Dec. 2005;162(12):2302-8. [pmid: 16330594].
5 Goenjian AK, Karayan I, Pynoos RS, et al. Outcome of psychotherapy among early adolescents after trauma. Am J Psychiatry. Apr. 1997;154(4):536-42. [pmid: 9090342].
6 Berger R, Pat-Horenczyk R, Gelkopf M. School-based intervention for prevention and treatment of elementary-students' terror-related distress in Israel: a quasi-randomized controlled trial. J Trauma Stress. Aug. 2007;20(4):541-51. [pmid: 17721962].
7 Smith P, Yule W, Perrin S, et al. Cognitive-behavioral therapy for PTSD in children and adolescents: a preliminary randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):1051-61. [pmid: 17667483].
8 Kemp M, Drummond P, McDermott B. A wait-list controlled pilot study of eye movement desensitization and reprocessing (EMDR) for children with post-traumatic stress disorder (PTSD) symptoms from motor vehicle accidents. Clin Child Psychol Psychiatry. Jan. 2010;15(1):5-25. [pmid: 19923161].
9 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. Aug. 6. 2003;290(5):603-11. [pmid: 12902363].
10 Ahrens J, Rexford L. Cognitive processing therapy for incarcerated adolescents with PTSD. J Aggression Maltreat Trauma. 2002;6(1):201-16.
11 Layne CM, Saltzman WR, Poppleton L, et al. Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Sep. 2008;47(9):1048-62. [pmid: 18664995].
12 Robb AS, Cueva JE, Sporn J, et al. Sertraline treatment of children and adolescents with posttraumatic stress disorder: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):463-71. [pmid: 21186964].
13 Tol WA, Komproe IH, Susanty D, et al. School-based mental health intervention for children affected by political violence in Indonesia: a cluster randomized trial. JAMA. Aug. 13. 2008;300(6):655-62. [pmid: 18698064].
14 Tol WA, Komproe IH, Jordans MJD, et al. Outcomes and moderators of a preventive school-based mental health intervention for children affected by war in Sri Lanka: a cluster randomized trial. World Psychiatry. Jun. 2012;11(2):114-22. [pmid: 22654944].