# Risk of Bias Assessment

Table E-1 Overall risk of bias assessments

Author, Year, Trial Name | Were Outcome Assessors Masked? | Did Analyses Control for Concurrent Interventions/Unintended Exposures? | Did the Study Maintain Fidelity to Protocol? | If Overall Attrition ≥ 20% or Differential Attrition ≥ 15% Were Missing Data Appropriately Handled? | Was Length of Follow-up the Same Between Groups? | Were Inclusion/Exclusion Criteria Measures Ecqual, Valid, and Reliable? | Were Health Outcomes Measures Equal, Valid, and Reliable? | Were Harms Assessed Using Equal, Valid, and Reliable Measures? | Are Potential Outcomes Prespecified and Reported? | Does the Design and/or Analysis Account for Important Confounding and Modifying Variables? | Risk of Bias
Schauer, 2008^40^ KIDNET | Yes | No | Yes | NA | Yes | Yes | Yes | Unclear or NR | Yes | No | High
Scheeringa, 2011^41^ NA | Unclear or NR | No | Yes | No | Yes | Yes | Yes | Yes | Yes | Partial | High
Schreier, 2005^42^ NA | Unclear or NR | No | Unclear or NR | Unclear or NR | Yes | Yes | Yes | NA | Yes | Cannot determine | High
Shechtman, 2010^43^ NA | Unclear or NR | Unclear or NR | Unclear or NR | No | Yes | Yes | NA | NA | Yes | NA | High
Smith, 2007^44^ NA | Yes | Yes | Yes | NA | Yes | Yes | Yes | Yes | Yes | Yes | Low
Stallard, 2006^45^ NA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | High
Stein, 2003^46^ NA | No | No | Yes | No | Yes | Yes | Yes | Yes | Unclear or NR | Yes | Medium
Stoddard, 2012^47^ NA | Yes | Unclear or NR | Yes | No | Yes | Yes | Yes | Unclear or NR | Yes | No | High
Thabet, 2005^48^ NA | Unclear or NR | No | Yes | Yes | Yes | Yes | Yes | No | Yes | No | High
Tol et al., 2008;^49^ Tol et al., 2010^50^ NA; NA | No | Unclear or NR | Yes | NA | Yes | Yes | Yes | NA | Yes | Yes | Medium
Tol, 2012^51^ NA | Yes | No | Unclear or NR | NA | Yes | Yes | No | Unclear or NR | Yes | Partial | Medium
Vijayakumar, 2006^52^ NA | No | No | Unclear or NR | No | Yes | No | No | Unclear or NR | Yes | No | High
Wolmer, 2005^53^ NA | No | No | Unclear or NR | No | Yes | Unclear or NR | Yes | No | Yes | Partial | High
Wolmer, 2011^54^ NA | Unclear or NR | Unclear or NR | Yes | No | Yes | Unclear or NR | Yes | No | Yes | Partial | High
Wolmer, 2011^55^ NA | No | No | Yes | NA | Unclear or NR | NA | Yes | Unclear or NR | Yes | Cannot determine | High
Zehnder, 2010^56^ NA | Yes | No | Unclear or NR | NA | Yes | Yes | Yes | Yes | Yes | Yes | Medium

Abbreviations: CBI = Classroom-Based Intervention; ERASE-Stress – Enhancing Resilience among Students Experiencing Stress; ES-SL = ERASE Stress Sri Lanka; KIDNET = Narrative Exposure Therapy for children; NA = not applicable; NR = not reported; OTT = Overshadowing the Threat of Terrorism; SPC = Stepped Preventive Care; SSET = Support for Students Exposed to Trauma; TARGET = Trauma Affect Regulation: Guide for Education and Therapy; TF-CBT = Trauma-Focused Cognitive Behavioral Therapy; TGCT = Trauma and Grief Component Therapy.

Table E-2 Additional risk of bias assessments for all randomized controlled trials (RCTs), case control trials (CCTs), and cohort studies

| RCTs Only | | RCTs, CCTs, Cohorts only | | | Case Control Only | RCTs and CCTs
Author, Year, Trial Name | Was allocation concealment adequately generated? | Was allocation of treatment adequately concealed? | Did the recruitment strategy differ across study groups? | Were groups similar at baseline? | Did analysis control for baseline group differences? | Were cases and controls appropriately selected? | Were providers masked? | Were participants masked? | Did the study use ITT analyses? | Risk of bias
Adams, 2011^1^ SPC | Yes | No | No | Yes | NA | No | No | Yes | Yes | High
Ahrens, 2002^2^ NA | Unclear or NR | Unclear or NR | NA | Unclear or NR | No | NA | No | No | Unclear or NR | Medium
Berger, 2007^3^ OTT | Unclear or NR | Unclear or NR | No | Yes | NA | Yes | No | No | Yes | Medium
Berger, 2009^4^ ES-SL | Unclear or NR | Unclear or NR | No | Yes | NA | Yes | No | No | NA | Medium
Berkowitz, 2011^5^ NA | Yes | NA | No | Yes | NA | Unclear or NR | No | No | Yes | Medium
Catani, 2009^6^ NA | Yes | No | No | Yes | NA | NA | No | No | Yes | Medium
Chemtob, 2002^7^ NA | Unclear or NR | No | NA | Yes | NA | NA | NA | NA | No | High
Chemtob, 2002^8^ NA | Yes | Unclear or NR | No | Yes | NA | NA | Unclear or NR | No | No | High
CATS Consortium, 2010^9^ NA | NA | NA | Unclear or NR | No | No | NA | No | No | Unclear or NR | High
Ehntholt, 2005^10^ NA | No | No | No | No | No | NA | No | No | NA | High
Eksi, 2009^11^ NA | NA | NA | Yes | No | No | NA | NA | NA | NA | High
Ford, 2012^12^ TARGET | Yes | Yes | No | No | Yes | NA | No | No | Yes | Medium
Gelkopf, 2009^13^ ERASE-Stress | Unclear or NR | Unclear or NR | No | Yes | NA | Yes | No | No | Yes | Medium
Giannopoulou, 2006^14^ NA | NA | NA | NA | Unclear or NR | Unclear or NR | NA | NA | No | Yes | High
Gilboa-Schechtman, 2010^57^ NA | Yes | Yes | No | No | Yes | NA | No | No | Yes | High
Goenjian, 1997; 2005^58, 59^ NA; NA | NA | NA | No | #1589: Yes #840: No | Yes | Unclear or NR | No | No | Yes | Medium
Gordon, 2008^15^ NA | Yes | No | No | Unclear or NR | No | NA | No | No | No | High
Jaycox, 2009^16^ SSET | Unclear or NR | No | No | No | No | NA | No | No | Yes | Medium
Jaycox, 2010^17^ TF-CBT | Unclear or NR | Unclear or NR | Yes | No | Unclear or NR | NA | No | No | Unclear or NR | High
Jordans, 2010^18^ CBI | Yes | Yes | No | Yes | NA | Yes | No | No | Yes | High
Karairmak, 2008^19^ NA | Unclear or NR | Unclear or NR | Unclear or NR | Unclear or NR | Unclear or NR | Unclear or NR | No | Yes | Yes | High
Karam, 2008^20^ NA | NA | NA | NA | NA | NA | Yes | NA | NA | NA | High
Kataoka, 2003^21^ NA | Unclear or NR | No | No | No | Yes | NA | No | No | Unclear or NR | High
Kemp, 2010^22^ NA | Unclear or NR | No | No | Yes | NA | Yes | No | No | Yes | Medium
Kenardy, 2008^23^ NA | No | No | No | No | No | Yes | No | Unclear or NR | Yes | High
Lesmana, 2009^25^ NA | Unclear or NR | No | No | Unclear or NR | Yes | No | No | No | Unclear or NR | High
McClatchey, 2009^26^ NA | NA | NA | No | Yes | NA | NA | No | NO | Yes | High
Nixon, 2012^27^ NA | Unclear or NR | No | Unclear or NR | No | No | NA | No | No | Yes | High
Nugent, 2010^28^ NA | NA | Yes | No | Yes | NA | NA | Yes | Yes | No | Low
Pfeffer, 2002^29^ NA | No | No | No | No | Yes | NA | No | No | Yes | High
Qouta, 2012^30^ NA | Unclear or NR | Unclear or NR | Unclear or NR | No | Unclear or NR | NA | Unclear or NR | Unclear or NR | No | High
Robb, 2010^31^ NA | Yes | Yes | No | Yes | NA | NA | Yes | Yes | Yes | Low
Robert, 1999^32^ NA | Yes | Yes | No | No | No | NA | Yes | Yes | Yes | Medium
Robert, 2008^33^ NA | Yes | Yes | No | No | No | NA | Yes | Yes | Yes | Low
Ronan, 1999^34^ NA | No | No | Unclear or NR | Unclear or NR | Na | No | No | No | Yes | High
Ruf, 2010^35^ NA | Yes | No | No | No | No | Yes | No | No | Yes | High
Sadeh, 2008^36^ NA | No | No | No | Unclear or NR | No | NA | No | No | Unclear or NR | High
Salloum, 2008^37^ NA | Unclear or NR | No | No | Yes | NA | NA | No | No | Yes | Medium
Salloum, 2012^38^ NA | Yes | No | No | Unclear or NR | No | NA | No | No | Yes | Low
Schaal, 2009^39^ NA | Yes | No | No | Unclear or NR | No | NA | No | No | No | High
Schauer, 2008^40^ KIDNET | No | No | No | Yes | NA | NA | No | No | Unclear or NR | High
Scheeringa, 2011^41^ NA | Yes | Unclear or NR | No | Unclear or NR | No | NA | Unclear or NR | No | No | High
Schreier, 2005^42^ NA | Unclear or NR | Unclear or NR | No | Unclear or NR | Unclear or NR | NA | Unclear or NR | NA | Unclear or NR | High
Shechtman, 2010^43^ NA | Unclear or NR | Unclear or NR | No | No | NA | Yes | No | No | NA | High
Smith, 2007^44^ NA | Yes | NA | No | Yes | NA | Yes | Yes | NA | Yes | Low
Stallard, 2006^45^ NA | Yes | Yes | No | No | No | NA | No | Yes | Yes | High
Stein, 2003^46^ NA | Yes | Yes | No | Yes | NA | NA | No | No | No | Medium
Stoddard, 2012^47^ NA | Yes | Yes | No | No | No | NA | Yes | Yes | No | High
Thabet, 2005^48^ NA | NA | NA | No | No | No | NA | No | No | Yes | High
Tol et al., 2008;^49^ Tol et al., 2010^50^ NA; NA | Yes | Unclear or NR | No | Yes | NA | Yes | No | No | Yes | Medium
Tol, 2012^51^ NA | Unclear or NR | Unclear or NR | No | Yes | NA | NA | No | No | No | Medium
Vijayakumar, 2006^52^ NA | No | No | Yes | No | No | NA | No | No | No | High
Wolmer, 2005^53^ NA | NA | NA | Yes | Yes | NA | NA | No | No | No | High
Wolmer, 2011^54^ NA | NA | NA | Unclear or NR | No | NA | NA | No | No | No | High
Wolmer, 2011^55^ NA | Unclear or NR | No | No | Unclear or NR | No | NA | No | No | No | High
Zehnder,2010^56^ NA | Yes | Yes | No | Yes | NA | NA | No | No | Yes | Medium

Abbreviations: CBI = Classroom-Based Intervention; ERASE-Stress – Enhancing Resilience among Students Experiencing Stress; ES-LS – ERASE Stress Sri Lanka; KIDNET = Narrative Exposure Therapy for children; NA = not applicable; NR = not reported; OTT = Overshadowing the Threat of Terrorism; SPC = Stepped Preventive Care; SSET = Support for Students Exposed to Trauma; TARGET = Trauma Affect Regulation: Guide for Education and Therapy; TF-CBT = Trauma-Focused Cognitive Behavioral Therapy; TGCT = Trauma and Grief Component Therapy.

Table E-3 Quality assessment of systematic reviews

First author, year | Review based on a focused question of interest | Search strategy employed a comprehensive, systematic, literature search | Eligibility criteria for studies clearly described | At least 2 people independently review studies | Authors used a standard method of critical appraisal before including studies | Publication bias assessed | Heterogeneity assessed and addressed | Approach used to synthesize information adequate and appropriate | Risk of Bias
Lawrence, 2010^a^.60 | Yes | Yes | Yes | Yes | Yes | NA | NA | NA | Low

a This systematic review did not identify any eligible studies. A quality assessment was performed but no abstraction of data occurred.

Abbreviations: NA = not applicable.

Table E-4 Rationale for high risk of bias rating

Author, Year Trial Name | Primary Reasons for High Risk of Bias Rating
Adams, 2011^1^ SPC | High potential for selection bias:; - Intervention and control groups differed at baseline.; - 406 eligible subjects were “missed, not approached;” no comparison between these children and enroll subjects.; High potential for performance bias:; - Fidelity of the providers and participants was not assessed.; High potential for measurement bias:; - Parent characteristics were not collected and entered into models despite the fact that parents delivered the intervention.
Chemtob, 2002^7^ NA | High potential for attrition and reporting bias:; - No ITT analysis conducted.; - No data provided on means comparing G1 to G2 at followup.; - Reliability of Children's Reaction Inventory as used to measure treatment effect on PTSD symptoms unknown.
Chemtob, 2002^8^ NA | High potential for selection bias:; - One group not drawn from the randomized set.; - This intervention group came from a less traumatized group. Authors did not control for potential selection bias.; - The authors did not provide sufficient data to evaluate differences between the arms.; High potential for detection bias:; - Authors did not account for multiple comparisons; - Wait-list assessments not performed at the same points in time as the treatment group assessments.; - Blinding not clearly reported.; High potential for attrition bias:; - The clinician evaluation of outcomes comparing treatment to no treatment is based on a very small random sample of the allocated individuals (∼17% (37) of the ∼75% (214 of 284) that completed the study.; - The authors did not use ITT analysis.
CATS Consortium, 2010^9^ NA | High potential for selection bias:; - Many uncontrolled variables, including nonrandom assignments to groups, non-comparable groups (low level trauma symptoms vs. high trauma).; - Did not control for improvement over time without treatment.; - No control for extraneous events occurring with treatment.
Ehntholt, 2005^10^ NA | High potential for selection bias:; - No control of confounding variables.; - Not randomized.; - Recruitment subjective to teacher referral.; - Groups differed in age.; High potential for detection bias:; - Follow-up not uniform in groups.; High potential for small sample bias:; - Small trial.
Eksi, 2009^11^ NA | High potential for selection bias:; - Did not control for substantial differences between groups at baseline in the analysis.; High potential for detection bias; - Outcome assessors not blinded.; High potential for performance bias:; - No fidelity to protocol assessment.
Giannopoulou, 2006^14^ NA | High potential for detection bias:; - Assessors of outcomes not blinded.; High potential for selection bias:; - Arms not randomized.; - Baseline differences between groups not reported.; High potential for reporting bias:; - Combined results for the treatment and wait list control groups after reporting similar mean scores between the groups.; - Did not report significance level.; - Did not report the outcome means separately for the groups.
Gilboa-Schechtman, 2010^57^ NA | High potential for selection bias:; - The randomization failed and not controlled for in the analysis.; - Demographics of participants not reported.
Gordon, 2008^15^ NA | High potential for selection bias:; - Randomization success not reported.; - Did not report between group differences and only controlled for gender in the analysis.; High potential for attrition bias:; - Did not use ITT analysis.
Jaycox, 2010^17^ TF-CBT | High potential for attrition bias:; - Overall attrition rate high at 39%; - Differential attrition rate high at 76% in one group and 1% in the other.
Jordans, 2010^18^ CBI | High potential for performance bias:; - The fidelity to protocol not assessed.; High potential for detection bias:; - Assessors not blinded to participant assignment.
Karairmak, 2008^19^ NA | High potential for selection bias:; - Randomization method was not specified.; - Baseline characteristics of groups are not reported.; High potential for detection bias:; - Information about assessors not reported.; - Validity of the measure used (Fear Survey Schedule for Children) not clear.; High potential for performance bias:; - Did not report on the fidelity of the treatment.
Karam, 2008^20^ NA | High potential for selection bias:; - Confounding by indication. Cases and controls had significant differences on a variety of characteristics.; High potential for detection bias:; - Assessment tool (War Events Questionnaire) not reliable.; - Likely that the outcome assessors not blinded.; High potential for attrition bias:; - The only followup assessment occurred approximately 46 weeks after the end of the intervention.
Kataoka, 2003^21^ NA | High potential for selection bias:; - Quasi experimental design with failed randomization.; - Waitlist parents had twice education of Intervention parents (6 vs. 3) but data should have been skewed in the other direction.; - Did not account for parental education for PTSD outcome.; High potential for detection bias:; - Manual was not validated and used somewhat inconsistently.; - Scale had not been validated in immigrant populations.; High potential for attrition bias:; - Differential attrition.; - Did not conduct ITT analysis.; High potential for performance bias:; - Study was not blinded.
Kenardy, 2008^23^ NA | High potential for selection bias:; - Participants in intervention group reported greater feelings of horror at baseline.; - Participants were randomized by hospital which affected any potential blinding to intervention and added other possible confounding variables which were not discussed or accounted for.; - Did not control for selection bias, clustering, or any other interventions.
Lesmana, 2009^25^ NA | High potential for selection bias:; - Randomization failed. Not controlled for in the analysis.; - Demographics of participants not reported.
McClatchey, 2009^26^ NA | High potential for selection bias:; - Study not randomized.; High potential for detection bias:; - Baseline measures gathered in-person with group 1 and by phone with group 2.; - Outcome assessors not blinded.; High potential for performance bias.; - Did not assess or control for co-interventions.
Nixon, 2012^27^ NA | High potential for selection bias:; - Analyses did not adjust for significant baseline differences in anxiety and prior trauma exposures.; High potential for intervention bias:; - Small study with high drop-out (36%).
Pfeffer, 2002^29^ NA | High potential for selection bias:; - Randomization failed.; High potential for performance bias:; - Participants and providers not blinded to intervention; - Participants received care through other interventions (individual and/or family psychotherapy). Not controlled for or mentioned in analysis.; High potential for detection bias:; - Time between assessments not consistent between patients and varied between 2.5 to 4.5 mos.; High potential for attrition bias:; - High differential attrition.
Qouta, 2012^30^ NA | High potential for selection bias:; - Techniques for randomization not reported.; - Inclusion and exclusion criteria not specified.; - Unclear if study controlled for similar baseline characteristics between groups.; High potential for attrition bias:; - Analysis not done in ITT fashion.; High potential for performance bias:; - Techniques for blinding are not reported.; High potential for design bias:; - Outcomes were not pre-specified.
Ronan, 1999^34^ NA | High potential for selection bias:; - Randomized by school not individually.; Assignment to treatment group was not done by randomization, rather by school attendance, and it was unclear where control group came from; there was little discussion of trying to make up for possible bias, no long-term followup of exposure group.; High potential for attrition bias:; - High attrition rate (28 out of 69 unavailable for follow up) without assessment to see if subjects who dropped out differed from subjects who remained enrolled.
Ruf, 2010^35^ NA | High potential for selection bias:; - Randomization failed and not controlled for in analysis.; - Demographics of participants not reported.
Sadeh, 2008^36^ NA | High potential for selection bias:; - Confounding factors in clusters not controlled for in analysis.; - Samples not described.; - Success of randomization not reported.; - Did not control for all confounding variables.; High potential for detection bias:; - Instruments used were designed for the study and not validated.
Schaal, 2009^39^ NA | High potential for selection bias:; - Randomization failed and not controlled for in analysis.; - Demographics of participants not reported.
Schauer, 2008^40^ KIDNET | High potential for selection bias:; - Not truly randomized; 6 schools were chosen based on convenience/safety and all children in a given school received the intervention, while another school served as the control.; High potential for sampling bias:; - 23% of the sample experienced ongoing domestic violence.
Scheeringa, 2011^41^ NA | High potential for selection bias:; - Baseline differences not reported.; - None of the analyses adjusted for covariates other than race and type of trauma.; - Randomization procedure was abandoned midway through study due to Hurricane Katrina hitting; it is impossible to isolate the effect of hurricane Katrina on the outcomes.; High potential for attrition bias:; - Very high dropout rates (56.4% in treatment group, 52.2% in waitlist group).; - ITT analyses not utilized.; High potential for sampling bias:; - One type of trauma (n=18) was domestic violence; cannot examine relationships in children exposed to other types of trauma.
Schreier, 2005^42^ NA | High potential for selection bias:; - Cannot determine if between group differences exist; there is no demographic data reported for the intervention and control groups, only reported overall.; - Statistical methods do not explain how potential confounders were accounted for in their analysis.; - Allocation concealment and method of randomization not report.; High potential for performance bias:; - Blinding not reported.; - Potential confounding variable; do not report how many participants assessed hospital psychological services.
Shechtman, 2010^43^ NA | High potential for selection bias:; - Randomization strategy was not reported.; High potential for intervention bias:; - Adherence to manual was not reported.
Stallard, 2006^45^ NA | High potential for measurement bias:; - Baseline characteristics differ between groups; analysis did not control for baseline differences or account for confounding variables.; - Providers were not blinded to the intervention status of participants.
Stein, 2003^46^ NA | High potential for selection bias:; - Failure to account for baseline differences between groups.; - Success of randomization not reported.
Stoddard, 2012^47^ NA | High potential for detection bias:; - Assessor blinding not reported.; - Improper statistical tests used (i.e. t-tests).; High potential for attrition bias:; - Small study with no loss to followup information given; calculated loss to followup showed differential rates (with placebo having 30-40% higher drop out).; - No ITT analyses conducted.
Thabet, 2005^48^ NA | High potential for selection bias:; - Not randomized.; - Baseline demographics (age, gender, % with PTSD) differ between groups; not controlled for in analysis.; - Clustering problem not dealt with in analysis.
Vijayakumar, 2006^52^ NA | High potential for selection bias:; - Participants chosen based on ability to read and understand questions; intervention was offered to all participants.; - Control group composed of dropouts rather than random assignment.; - Self-selected for intervention and control groups, moderate differences between groups, not statistically significant but some large (like PTSD symptoms) and no control for baseline characteristic.
Wolmer, 2005^53^ NA | High potential for attrition bias:; - Overall loss to follow up from the original study was substantial (77%).
Wolmer, 2011^54^ NA | High potential for selection bias:; - Baseline difference between groups in exposure to terrorist attacks.; - Unclear how wait list control group is derived.; High potential for attrition bias:; - Substantial differential attrition at Time 3 (23.3% vs. 0%).
Wolmer, 2011^55^ NA | High potential for selection bias:; - No baseline information (either pre-exposure or pre-intervention) collected, preventing loss to followup calculations, adjustment for any baseline differences, or use of change scores in analyses.; High potential for detection bias:; - Timing of intervention (9 months prior to trauma exposure) and measurement 3 months after exposure without detailed information about what happened to participants who got exposure but then were in different grades.; High potential for performance bias:; - Cannot rule out unintentional exposures or unintended interventions affecting results.

Abbreviations: CBI = Classroom-Based Intervention; G = group; ITT = intent-to-treat; KIDNET = Narrative Exposure Therapy for children; PTSD = Post-Traumatic Stress Disorder; SPC = Stepped Preventive Care TF-CBT = Trauma-Focused Cognitive Behavioral Therapy; vs. = versus.

## References

1 Adams NL, García-España JF, Marsac ML, et al. A pilot randomized controlled trial assessing secondary prevention of traumatic stress integrated into pediatric trauma care. J Trauma Stress. 2011;24(3):252-9. [pmid: 21594900].
2 Ahrens J, Rexford L. Cognitive processing therapy for incarcerated adolescents with PTSD. J Aggression Maltreat Trauma. 2002;6(1):201-16.
3 Berger R, Pat-Horenczyk R, Gelkopf M. School-based intervention for prevention and treatment of elementary-students' terror-related distress in Israel: a quasi-randomized controlled trial. J Trauma Stress. Aug. 2007;20(4):541-51. [pmid: 17721962].
4 Berger R, Gelkopf M. School-based intervention for the treatment of tsunami-related distress in children: a quasi-randomized controlled trial. Psychother Psychosom. 2009;78(6):364-71. [pmid: 19738402].
5 Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: secondary prevention for youth at risk of developing PTSD. J Child Psychol Psychiatry. Jun. 2011;52(6):676-85. [pmid: 20868370].
6 Catani C, Kohiladevy M, Ruf M, et al. Treating children traumatized by war and Tsunami: a comparison between exposure therapy and meditation-relaxation in North-East Sri Lanka. BMC Psychiatry. 2009;9:22. [pmid: 19439099].
7 Chemtob CM, Nakashima J, Carlson JG. Brief treatment for elementary school children with disaster-related posttraumatic stress disorder: a field study. J Clin Psychol. Jan. 2002;58(1):99-112. [pmid: 11748599].
8 Chemtob CM, Nakashima JP, Hamada RS. Psychosocial intervention for postdisaster trauma symptoms in elementary school children: a controlled community field study. Arch Pediatr Adolesc Med. Mar. 2002;156(3):211-6. [pmid: 11876663].
9 Consortium C. Implementation of CBT for youth affected by the World Trade Center disaster: matching need to treatment intensity and reducing trauma symptoms. J Trauma Stress. 2010;23(6):699-707. [pmid: 21171130].
10 Ehntholt KA, Smith PA, Yule W. School-based cognitive-behavioural therapy group intervention for refugee children who have experienced war-related trauma. Clin Child Psychol Psychiatr. 2005;10(2):235-50. PMID: 2005-03937-007.
11 Eksi A, Braun KL. Over-time changes in PTSD and depression among children surviving the 1999 Istanbul earthquake. Eur Child Adolesc Psychiatry. Jun. 2009;18(6):384-91. [pmid: 19221855].
12 Ford JD, Steinberg KL, Hawke J, et al. Randomized trial comparison of emotion regulation and relational psychotherapies for PTSD with girls involved in delinquency. J Clin Child Adolesc Psychol. 2012;41(1):27-37. [pmid: 22233243].
13 Gelkopf M, Berger R. A school-based, teacher-mediated prevention program (ERASE-Stress) for reducing terror-related traumatic reactions in Israeli youth: A quasi-randomized controlled trial. J Child Psychol Psychiatry. Aug. 2009;50(8):962-71. [pmid: 19207621].
14 Giannopoulou I, Dikaiakou A, Yule W. Cognitive-behavioural group intervention for PTSD symptoms in children following the Athens 1999 earthquake: a pilot study. Clin Child Psychol Psychiatry. Oct. 2006;11(4):543-53. [pmid: 17163223].
15 Gordon JS, Staples JK, Blyta A, et al. Treatment of posttraumatic stress disorder in postwar Kosovar adolescents using mind-body skills groups: a randomized controlled trial. J Clin Psychiatry. Sep. 2008;69(9):1469-76. [pmid: 18945398].
16 Jaycox LH, Langley AK, Stein BD, et al. Support for Students Exposed to Trauma: a Pilot Study. School Ment Health. Jun. 1. 2009;1(2):49-60. [pmid: 20811511].
17 Jaycox LH, Cohen JA, Mannarino AP, et al. Children's mental health care following Hurricane Katrina: a field trial of trauma-focused psychotherapies. J Trauma Stress. Apr. 2010;23(2):223-31. [pmid: 20419730].
18 Jordans MJ, Komproe IH, Tol WA, et al. Evaluation of a classroom-based psychosocial intervention in conflict-affected Nepal: a cluster randomized controlled trial. J Child Psychol Psychiatry. Jul. 2010;51(7):818-26. [pmid: 20102428].
19 Karairmak O, Aydin G. Reducing earthquake-related fears in victim and nonvictim children. J Genet Psychol. Jun. 2008;169(2):177-85. [pmid: 18578300].
20 Karam EG, Fayyad J, Karam AN, et al. Effectiveness and specificity of a classroom-based group intervention in children and adolescents exposed to war in Lebanon. World Psychiatry. 2008;7(2):103-9. [pmid: 18560511].
21 Kataoka SH, Stein BD, Jaycox LH, et al. A school-based mental health program for traumatized Latino immigrant children. J Am Acad Child Adolesc Psychiatry. 2003;42(3):311-8. PMID: 2003-02169-013. First Author & Affiliation: Kataoka, Sheryl H. [pmid: 12595784].
22 Kemp M, Drummond P, McDermott B. A wait-list controlled pilot study of eye movement desensitization and reprocessing (EMDR) for children with post-traumatic stress disorder (PTSD) symptoms from motor vehicle accidents. Clin Child Psychol Psychiatry. Jan. 2010;15(1):5-25. [pmid: 19923161].
23 Kenardy J, Thompson K, Le Brocque R, et al. Information-provision intervention for children and their parents following pediatric accidental injury. Eur Child Adolesc Psychiatry. Aug. 2008;17(5):316-25. [pmid: 18350366].
24 Layne CM, Saltzman WR, Poppleton L, et al. Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Sep. 2008;47(9):1048-62. [pmid: 18664995].
25 Lesmana CB, Suryani LK, Jensen GD, et al. A spiritual-hypnosis assisted treatment of children with PTSD after the 2002 Bali terrorist attack. Am J Clin Hypn. Jul. 2009;52(1):23-34. [pmid: 19678557].
26 McClatchey IS, Vonk ME, Palardy G. Efficacy of a Camp-Based Intervention for Childhood Traumatic Grief. Research on Social Work Practice. Jan. 2009;19(1):19-30. PMID: WOS:000261327300002.
27 Nixon RD, Sterk J, Pearce A. A randomized trial of cognitive behaviour therapy and cognitive therapy for children with posttraumatic stress disorder following single-incident trauma. J Abnorm Child Psychol. Apr. 2012;40(3):327-37. [pmid: 21892594].
28 Nugent NR, Christopher NC, Crow JP, et al. The efficacy of early propranolol administration at reducing PTSD symptoms in pediatric injury patients: a pilot study. J Trauma Stress. Apr. 2010;23(2):282-7. [pmid: 20419738].
29 Pfeffer CR, Jiang H, Kakuma T, et al. Group Intervention for Children Bereaved by the Suicide of a Relative. J Am Acad Child Adolesc Psychiatry. 2002;41(5):505-13. [pmid: 12014782].
30 Qouta SR, Palosaari E, Diab M, et al. Intervention effectiveness among war-affected children: A cluster randomized controlled trial on improving mental health. J Trauma Stress. Jun. 2012;25(3):288-98. PMID: WOS:000305576500012. [pmid: 22648703].
31 Robb AS, Cueva JE, Sporn J, et al. Sertraline treatment of children and adolescents with posttraumatic stress disorder: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):463-71. [pmid: 21186964].
32 Robert R, Blakeney PE, Villarreal C, et al. Imipramine treatment in pediatric burn patients with symptoms of acute stress disorder: a pilot study. J Am Acad Child Adolesc Psychiatry. Jul. 1999;38(7):873-82. [pmid: 10405506].
33 Robert R, Tcheung WJ, Rosenberg L, et al. Treating thermally injured children suffering symptoms of acute stress with imipramine and fluoxetine: a randomized, double-blind study. Burns. Nov. 2008;34(7):919-28. [pmid: 18675519].
34 Ronan KR. Behaviourally-based interventions for children following volcanic eruptions: an evaluation of effectiveness. Disaster prevention and management. 1999;8(3):169-76.
35 Ruf M, Schauer M, Neuner F, et al. Narrative exposure therapy for 7- to 16-year-olds: a randomized controlled trial with traumatized refugee children. J Trauma Stress. Aug. 2010;23(4):437-45. [pmid: 20684019].
36 Sadeh A, Hen-Gal S, Tikotzky L. Young children's reactions to war-related stress: a survey and assessment of an innovative intervention. Pediatrics. Jan. 2008;121(1):46-53. [pmid: 18166556].
37 Salloum A, Overstreet S. Evaluation of individual and group grief and trauma interventions for children post disaster. J Clin Child Adolesc Psychol. Jul. 2008;37(3):495-507. [pmid: 18645741].
38 Salloum A, Overstreet S. Grief and trauma intervention for children after disaster: exploring coping skills versus trauma narration. Behav Res Ther. Mar. 2012;50(3):169-79. [pmid: 22317753].
39 Schaal S, Elbert T, Neuner F. Narrative exposure therapy versus interpersonal psychotherapy. A pilot randomized controlled trial with Rwandan genocide orphans. Psychother Psychosom. 2009;78(5):298-306. [pmid: 19628958].
40 Schauer E. Trauma Treatment for Children in War: Build-up of an evidence-based large-scale Mental Health Intervention in North-Eastern Sri Lanka. University of Konstanz. 2008.
41 Scheeringa MS, Weems CF, Cohen JA, et al. Trauma-focused cognitive-behavioral therapy for posttraumatic stress disorder in three-through six year-old children: a randomized clinical trial. J Child Psychol Psychiatry. Aug. 2011;52(8):853-60. [pmid: 21155776].
42 Schreier H, Ladakakos C, Morabito D, et al. Posttraumatic stress symptoms in children after mild to moderate pediatric trauma: a longitudinal examination of symptom prevalence, correlates, and parent-child symptom reporting. J Trauma. Feb. 2005;58(2):353-63. [pmid: 15706200].
43 Shechtman Z, Mor M. Groups for children and adolescents with trauma-related symptoms: outcomes and processes. Int J Group Psychother. Apr. 2010;60(2):221-44. [pmid: 20297882].
44 Smith P, Yule W, Perrin S, et al. Cognitive-behavioral therapy for PTSD in children and adolescents: a preliminary randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):1051-61. [pmid: 17667483].
45 Stallard P, Velleman R, Salter E, et al. A randomised controlled trial to determine the effectiveness of an early psychological intervention with children involved in road traffic accidents. J Child Psychol Psychiatry. Feb. 2006;47(2):127-34. [pmid: 16423143].
46 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. Aug. 6. 2003;290(5):603-11. [pmid: 12902363].
47 Stoddard FJ Jr., Luthra R, Sorrentino EA, et al. A randomized controlled trial of sertraline to prevent posttraumatic stress disorder in burned children. J Child Adolesc Psychopharmacol. Oct. 2011;21(5):469-77. [pmid: 22040192].
48 Thabet AA, Vostanis P, Karim K. Group crisis intervention for children during ongoing war conflict. Eur Child Adolesc Psychiatry. Aug. 2005;14(5):262-9. [pmid: 15981138].
49 Tol WA, Komproe IH, Susanty D, et al. School-based mental health intervention for children affected by political violence in Indonesia: a cluster randomized trial. JAMA. Aug. 13. 2008;300(6):655-62. [pmid: 18698064].
50 Tol WA, Komproe IH, Jordans MJ, et al. Mediators and moderators of a psychosocial intervention for children affected by political violence. J Consult Clin Psychol. Dec. 2010;78(6):818-28. [pmid: 21114342].
51 Tol WA, Komproe IH, Jordans MJD, et al. Outcomes and moderators of a preventive school-based mental health intervention for children affected by war in Sri Lanka: a cluster randomized trial. World Psychiatry. Jun. 2012;11(2):114-22. [pmid: 22654944].
52 Vijayakumar L, Kannan GK, Kumar BG, et al. Do all children need intervention after exposure to tsunami?. International Review of Psychiatry. Dec. 2006;18(6):515-22. PMID: ISI:000242763900005. [pmid: 17162691].
53 Wolmer L, Laor N, Dedeoglu C, et al. Teacher-mediated intervention after disaster: a controlled three-year follow-up of children's functioning. J Child Psychol Psychiatry. Nov. 2005;46(11):1161-8. [pmid: 16238663].
54 Wolmer L, Hamiel D, Barchas JD, et al. Teacher-Delivered Resilience-Focused Intervention in Schools With Traumatized Children Following the Second Lebanon War. J Trauma Stress. Jun. 2011;24(3):309-16. PMID: WOS:000291350300009. [pmid: 21618288].
55 Wolmer L, Hamiel D, Laor N. Preventing children's posttraumatic stress after disaster with teacher-based intervention: a controlled study. J Am Acad Child Adolesc Psychiatry. 2011;50(4):340-8. [pmid: 21421174].
56 Zehnder D, Meuli M, Landolt MA. Effectiveness of a single-session early psychological intervention for children after road traffic accidents: a randomised controlled trial. Child Adolesc Psychiatry Ment Health. 2010;4:7. [pmid: 20181120].
57 Gilboa-Schechtman E, Foa EB, Shafran N, et al. Prolonged exposure versus dynamic therapy for adolescent PTSD: a pilot randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Oct. 2010;49(10):1034-42. [pmid: 20855048].
58 Goenjian AK, Karayan I, Pynoos RS, et al. Outcome of psychotherapy among early adolescents after trauma. Am J Psychiatry. Apr. 1997;154(4):536-42. [pmid: 9090342].
59 Goenjian AK, Walling D, Steinberg AM, et al. A prospective study of posttraumatic stress and depressive reactions among treated and untreated adolescents 5 years after a catastrophic disaster. Am J Psychiatry. Dec. 2005;162(12):2302-8. [pmid: 16330594].
60 Lawrence S, De Silva M, Henley R. Sports and games for post-traumatic stress disorder (PTSD). Cochrane Database of Syst Rev. 2010;(1):CD007171. [pmid: 20091620].