# Evidence Tables

Evidence Table 1 Study characteristics

Evidence Table 2 Population characteristics

Evidence Table 3 Population baseline characteristics

Evidence Table 4 Intervention descriptions

Evidence Table 5 Benefits (KQ 1 & 2)

Evidence Table 6 Benefits (KQ1 & 2)

Evidence Table 7 Benefits (KQ1 & 2) (continued)

Evidence Table 8 Subgroup analyses

Evidence Table 9 Subgroup analyses

Evidence Table 10 Harms

Evidence Table 11 Harms

## References

1 Ahrens J, Rexford L. Cognitive processing therapy for incarcerated adolescents with PTSD. J Aggression Maltreat Trauma. 2002;6(1):201-16.
2 Berger R, Pat-Horenczyk R, Gelkopf M. School-based intervention for prevention and treatment of elementary-students' terror-related distress in Israel: a quasi-randomized controlled trial. J Trauma Stress. Aug. 2007;20(4):541-51. [pmid: 17721962].
3 Berger R, Gelkopf M. School-based intervention for the treatment of tsunami-related distress in children: a quasi-randomized controlled trial. Psychother Psychosom. 2009;78(6):364-71. [pmid: 19738402].
4 Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: secondary prevention for youth at risk of developing PTSD. J Child Psychol Psychiatry. Jun. 2011;52(6):676-85. [pmid: 20868370].
5 Catani C, Kohiladevy M, Ruf M, et al. Treating children traumatized by war and Tsunami: a comparison between exposure therapy and meditation-relaxation in North-East Sri Lanka. BMC Psychiatry. 2009;9:22. [pmid: 19439099].
6 Ford JD, Steinberg KL, Hawke J, et al. Randomized trial comparison of emotion regulation and relational psychotherapies for PTSD with girls involved in delinquency. J Clin Child Adolesc Psychol. 2012;41(1):27-37. [pmid: 22233243].
7 Gelkopf M, Berger R. A school-based, teacher-mediated prevention program (ERASE-Stress) for reducing terror-related traumatic reactions in Israeli youth: A quasi-randomized controlled trial. J Child Psychol Psychiatry. Aug. 2009;50(8):962-71. [pmid: 19207621].
8 Goenjian AK, Karayan I, Pynoos RS, et al. Outcome of psychotherapy among early adolescents after trauma. Am J Psychiatry. Apr. 1997;154(4):536-42. [pmid: 9090342].
9 Goenjian AK, Walling D, Steinberg AM, et al. A prospective study of posttraumatic stress and depressive reactions among treated and untreated adolescents 5 years after a catastrophic disaster. Am J Psychiatry. Dec. 2005;162(12):2302-8. [pmid: 16330594].
10 Jaycox LH, Langley AK, Stein BD, et al. Support for Students Exposed to Trauma: a Pilot Study. School Ment Health. Jun. 1. 2009;1(2):49-60. [pmid: 20811511].
11 Kemp M, Drummond P, McDermott B. A wait-list controlled pilot study of eye movement desensitization and reprocessing (EMDR) for children with post-traumatic stress disorder (PTSD) symptoms from motor vehicle accidents. Clin Child Psychol Psychiatry. Jan. 2010;15(1):5-25. [pmid: 19923161].
12 Layne CM, Saltzman WR, Poppleton L, et al. Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Sep. 2008;47(9):1048-62. [pmid: 18664995].
13 Nugent NR, Christopher NC, Crow JP, et al. The efficacy of early propranolol administration at reducing PTSD symptoms in pediatric injury patients: a pilot study. J Trauma Stress. Apr. 2010;23(2):282-7. [pmid: 20419738].
14 Robb AS, Cueva JE, Sporn J, et al. Sertraline treatment of children and adolescents with posttraumatic stress disorder: a double-blind, placebo-controlled trial. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):463-71. [pmid: 21186964].
15 Robert R, Blakeney PE, Villarreal C, et al. Imipramine treatment in pediatric burn patients with symptoms of acute stress disorder: a pilot study. J Am Acad Child Adolesc Psychiatry. Jul. 1999;38(7):873-82. [pmid: 10405506].
16 Robert R, Tcheung WJ, Rosenberg L, et al. Treating thermally injured children suffering symptoms of acute stress with imipramine and fluoxetine: a randomized, double-blind study. Burns. Nov. 2008;34(7):919-28. [pmid: 18675519].
17 Salloum A, Overstreet S. Evaluation of individual and group grief and trauma interventions for children post disaster. J Clin Child Adolesc Psychol. Jul. 2008;37(3):495-507. [pmid: 18645741].
18 Salloum A, Overstreet S. Grief and trauma intervention for children after disaster: exploring coping skills versus trauma narration. Behav Res Ther. Mar. 2012;50(3):169-79. [pmid: 22317753].
19 Smith P, Yule W, Perrin S, et al. Cognitive-behavioral therapy for PTSD in children and adolescents: a preliminary randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):1051-61. [pmid: 17667483].
20 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. Aug. 6. 2003;290(5):603-11. [pmid: 12902363].
21 Tol WA, Komproe IH, Susanty D, et al. School-based mental health intervention for children affected by political violence in Indonesia: a cluster randomized trial. JAMA. Aug. 13. 2008;300(6):655-62. [pmid: 18698064].
22 Tol WA, Komproe IH, Jordans MJ, et al. Mediators and moderators of a psychosocial intervention for children affected by political violence. J Consult Clin Psychol. Dec. 2010;78(6):818-28. [pmid: 21114342].
23 Tol WA, Komproe IH, Jordans MJD, et al. Outcomes and moderators of a preventive school-based mental health intervention for children affected by war in Sri Lanka: a cluster randomized trial. World Psychiatry. Jun. 2012;11(2):114-22. [pmid: 22654944].
24 Zehnder D, Meuli M, Landolt MA. Effectiveness of a single-session early psychological intervention for children after road traffic accidents: a randomised controlled trial. Child Adolesc Psychiatry Ment Health. 2010;4:7. [pmid: 20181120].
25 Stallard P, Velleman R, Salter E, et al. A randomised controlled trial to determine the effectiveness of an early psychological intervention with children involved in road traffic accidents. J Child Psychol Psychiatry. Feb. 2006;47(2):127-34. [pmid: 16423143].