# Excluded Studies

## Excluded for Wrong Publication Type

Commonwealth v. Twitchell. North East Rep Second Ser. Aug. 11. 1993;617:609-21. [pmid: 12041213].
Atypical antipsychotic agents in the treatment of schizophrenia and other psychiatric disorders. Part I: Unique patient populations. J Clin Psychiatry. May. 1998;59(5):259-65. [pmid: 9632042].
Abdulkarim AA, Tunde-Ayinmode MF. Incestuous sadism. West Afr J Med. Nov-Dec. 2010;29(6):432-3. [pmid: 21465455].
Adler-Nevo G, Manassis K. Psychosocial treatment of pediatric posttraumatic stress disorder: The neglected field of single-incident trauma. Depression and anxiety. 2005;22(4):177-89. WOS:000234394500003. [pmid: 16180209].
Alderfer MA, Noll RB. Identifying and addressing the needs of siblings of children with cancer: (commentary on Sidhu et al., page 580). Pediatr Blood Cancer. Oct. 15. 2006;47(5):537-8. [pmid: 16317731].
Allen AJ, Leonard H, Swedo SE. CURRENT KNOWLEDGE OF MEDICATIONS FOR THE TREATMENT OF CHILDHOOD ANXIETY DISORDERS. Journal of the American Academy of Child and Adolescent Psychiatry. Aug. 1995;34(8):976-86. WOS:A1995RL32000007. [pmid: 7665455].
Antai-Otong D, Richmond G. Treating a crash survivor. Advance for nurse practitioners. 2001;9(10):22. [pmid: 12400333].
Boothby N, Crawford J, Halperin J. Mozambique child soldier life outcome study: lessons learned in rehabilitation and reintegration efforts. Glob Public Health. 2006;1(1):87-107. [pmid: 19153896].
Brewer M, Melnyk BM. Effective coping/mental health interventions for critically ill adolescents: an evidence review. Pediatric nursing. 2007;33(4):361-7. 73. [pmid: 17907738].
Bronner MB, Beer R, Jozine van Zelm van Eldik M, et al. Reducing acute stress in a 16-year old using trauma-focused cognitive behaviour therapy and eye movement desensitization and reprocessing. Dev Neurorehabil. Jun. 2009;12(3):170-4. [pmid: 19466626].
Bryant RA, Sackville T, Dang ST, et al. Treating acute stress disorder: an evaluation of cognitive behavior therapy and supportive counseling techniques. Am J Psychiatry. Nov. 1999;156(11):1780-6. [pmid: 10553743].
Christie D, Wilson C. CBT in paediatric and adolescent health settings: a review of practice-based evidence. Pediatr Rehabil. Oct-Dec. 2005;8(4):241-7. [pmid: 16192099].
Cohen D, Consoli A, Bodeau N, et al. Predictors of placebo response in randomized controlled trials of psychotropic drugs for children and adolescents with internalizing disorders. J Child Adolesc Psychopharmacol. Feb. 2010;20(1):39-47. [pmid: 20166795].
Cohen J. Practice Parameter for the Assessment and Treatment of Children and Adolescents With Posttraumatic Stress Disorder. Journal of the American Academy of Child and Adolescent Psychiatry. Apr. 2010;49(4):414-30. WOS:000276153500019. [pmid: 20410735].
Cohen JA, Bernet W, Dunne JE, et al. Practice parameters for the assessment and treatment of children and adolescents with posttraumatic stress disorder. Journal of the American Academy of Child and Adolescent Psychiatry. 1998;37(10 SUPPL.):4S-26S. [pmid: 9785726].
Cohen JA, Mannarino AP, Zhitova AC, et al. Treating child abuse-related posttraumatic stress and comorbid substance abuse in adolescents. Child abuse & neglect. Dec. 2003;27(12):1345-65. WOS:000187364900005. [pmid: 14644054].
Compton SN, March JS, Brent D, et al. Cognitive-behavioral psychotherapy for anxiety and depressive disorders in children and adolescents: an evidence-based medicine review (Structured abstract). Journal of the American Academy of Child and Adolescent Psychiatry. 2004;(8):930-59. DARE-12004006517. [pmid: 15266189].
Cuijpers P, Van Straten A, Smit F. Preventing the incidence of new cases of mental disorders: a meta-analytic review. J Nerv Ment Dis. Feb. 2005;193(2):119-25. [pmid: 15684914].
Del Mar CB. Should we debrief and counsel people who have had psychological shock?. Med J Aust. Sep. 2. 2002;177(5):258-9. [pmid: 12197822].
Diseth TH, Christie HJ. Trauma-related dissociative (conversion) disorders in children and adolescents--an overview of assessment tools and treatment principles. Nord J Psychiatry. 2005;59(4):278-92. [pmid: 16195132].
Donahue SA, Lanzara CB, Felton CJ, et al. Project Liberty: New York's crisis counseling program created in the aftermath of September 11, 2001. Psychiatric Services. 2006;57(9):1253-8. [pmid: 16968752].
Donnelly CL, Amaya-Jackson L, March JS. Psychopharmacology of pediatric posttraumatic stress disorder. Journal of child and adolescent psychopharmacology. 1999;9(3):203-20. 1999-01085-007. First Author & Affiliation: Donnelly, Craig L. [pmid: 10521013].
Dreman S, Cohen E. Children of victims of terrorism revisited: integrating individual and family treatment approaches. Am J Orthopsychiatry. Apr. 1990;60(2):204-9. [pmid: 2343889].
Ellawala N. The Sumithrayo strategy for the reduction of suicide in Sri Lanka. Crisis. 1994;15(2):53-4. 6. [pmid: 7988162].
Felitti VJ. Adverse childhood experiences and adult health. Acad Pediatr. May-Jun. 2009;9(3):131-2. [pmid: 19450768].
Fellmeth Gracia LT, Nurse J, Heffernan C, et al. Educational and skills-based interventions for preventing relationship and dating violence in adolescents and young adults. Cochrane Database of Systematic Reviews. 2011;(7). CD004534.
Field A, Cottrell D. Eye movement desensitization and reprocessing as a therapeutic intervention for traumatized children and adolescents: a systematic review of the evidence for family therapists. Journal of Family Therapy. Nov. 2011;33(4):374-88. WOS:000296503200002.
Garrison EG, Roy IS, Azar V. Responding to the mental health needs of Latino children and families through school-based services. Clin Psychol Rev. Mar. 1999;19(2):199-219. [pmid: 10078420].
Gillies D, O'Brien L, Rogers P, et al. Psychological therapies for the prevention and treatment of post-traumatic stress disorder in children and adolescents. Cochrane Database of Systematic Reviews. 2007;(3).
Good C, Petersen C. SSRI and mirtazapine in PTSD. J Am Acad Child Adolesc Psychiatry. Mar. 2001;40(3):263-4. [pmid: 11288766].
Hamm MP, Osmond M, Curran J, et al. A systematic review of crisis interventions used in the emergency department: recommendations for pediatric care and research. Pediatr Emerg Care. Dec. 2010;26(12):952-62. [pmid: 21131813].
Hanson MD, Gauld M, Wathen CN, et al. Nonpharmacological interventions for acute wound care distress in pediatric patients with burn injury: a systematic review. J Burn Care Res. Sep-Oct. 2008;29(5):730-41. [pmid: 18695617].
Harmon RJ, Riggs PD. Clinical Perspectives: Clonidine for posttraumatic stress disorder in preschool children. Journal of the American Academy of Child and Adolescent Psychiatry. 1996;35(9):1247-9. [pmid: 8824068].
Hoagwood KE, Vogel JM, Levitt JM, et al. Implementing an evidence-based trauma treatment in a state system after September 11: The CATS project. Journal of the American Academy of Child and Adolescent Psychiatry. 2007;46(6):773-9. [pmid: 17513990].
Hoge CW, Pavlin JA, Milliken CS. Psychological sequelae of September 11. N Engl J Med. Aug. 8. 2002;347(6):443-5. author reply -5. [pmid: 12167689].
Huemer J, Erhart F, Steiner H. Posttraumatic stress disorder in children and adolescents: a review of psychopharmacological treatment. Child Psychiatry Hum Dev. Dec. 2010;41(6):624-40. [pmid: 20567898].
Ipser Jonathan C, Stein Dan J, Hawkridge S, et al. Pharmacotherapy for anxiety disorders in children and adolescents. Cochrane Database of Systematic Reviews. 2009;(3). CD005170.
Jankiewicz AM, Nowakowski P. Ketamine and succinylcholine for emergency intubation of pediatric patients. DICP. May. 1991;25(5):475-6. [pmid: 2068832].
Jones DP. Treatment in child sexual abuse. Child Abuse Negl. Sep. 1995;19(9):1143-4. [pmid: 8528819].
Kanas N. Trauma-focused group therapy for patients with post-traumatic stress. International journal of group psychotherapy. 1999;49(4):540-3. [pmid: 10530049].
Kar N. Psychological impact of disasters on children: review of assessment and interventions. World J Pediatr. Feb. 2009;5(1):5-11. [pmid: 19172325].
Kenardy J, Cobham V, Nixon RD, et al. Protocol for a randomised controlled trial of risk screening and early intervention comparing child- and family-focused cognitive-behavioural therapy for PTSD in children following accidental injury. BMC Psychiatry. 2010;10:92. [pmid: 21078196].
Kibby MY, Tyc VL, Mulhern RK. Effectiveness of psychological intervention for children and adolescents with chronic medical illness: a meta-analysis. Clin Psychol Rev. Jan. 1998;18(1):103-17. [pmid: 9455625].
King NJ, Tonge BJ, Mullen P, et al. Cognitive-behavioural treatment of sexually abused children: A review of research. Behavioural and Cognitive Psychotherapy. 1999;27(4):295-309.
Lamberg L. Reclaiming child soldiers' lost lives. Journal of the American Medical Association. 2004;292(5):553-4. [pmid: 15292073].
Lefevre M. Finding the key: Containing and processing traumatic sexual abuse. Arts in Psychotherapy. 2004;31(3):137-52.
Lyon GJ, Coffey B, Silva R. Postraumatic stress disorder and reactive attachment disorder: outcome in an adolescent. J Child Adolesc Psychopharmacol. Dec. 2008;18(6):641-6. [pmid: 19108670].
Macdonald GM, Higgins JP, Ramchandani P. Cognitive-behavioural interventions for children who have been sexually abused. Cochrane Database Syst Rev. 2006;(4):CD001930. [pmid: 17054148].
Magnusson D. Interactionism and the person approach in developmental psychology. Eur Child Adolesc Psychiatry. Suppl 1. 1996;5:18-22. [pmid: 9010658].
McCloskey LA, Southwick K. Psychosocial problems in refugee children exposed to war. Pediatrics. Mar. 1996;97(3):394-7. WOS:A1996TY58000019. [pmid: 8604277].
Mead N, Lester H, Chew-Graham C, et al. Effects of befriending on depressive symptoms and distress: systematic review and meta-analysis. Br J Psychiatry. Feb. 2010;196(2):96-101. [pmid: 20118451].
Morales AT. Prevention of youth gang violence and homicide with a hospital-based clinical model. Schwarz Donald F, editor. Children and violence; report of the Twenty-Third Ross Roundtable on Critical Approaches to Common Pediatric Problems. Columbus, Ohio. Ross Laboratories. 1992.
Morris J, van Ommeren M, Belfer M, et al. Children and the Sphere standard on mental and social aspects of health. Disasters. Mar. 2007;31(1):71-90. WOS:000244882900005. [pmid: 17367375].
Munoz-Solomando A, Kendall T, Whittington CJ. Cognitive behavioural therapy for children and adolescents. Curr Opin Psychiatry. Jul. 2008;21(4):332-7. [pmid: 18520736].
Nader KO, Pynoos RS. School disaster: planning and initial interventions. Journal of Social Behavior and Personality. 1993;8(5):299-320.
Nevo GA. Prolonged exposure, time-limited dynamic psychotherapy, and the dodo. J Am Acad Child Adolesc Psychiatry. May. 2011;50(5):519-20. author reply 20-1. [pmid: 21515201].
Nikulina V, Hergenrother JM, Brown EJ, et al. From efficacy to effectiveness: the trajectory of the treatment literature for children with PTSD. Expert Rev Neurother. Aug. 2008;8(8):1233-46. [pmid: 18671667].
Parker B, Turner W. Psychoanalytic/psychodynamic psychotherapy for children and adolescents who have been sexually abused. Cochrane Database of Systematic Reviews. 2009;(4). CD008162.
Pitman RK, Delahanty DL. Conceptually driven pharmacologic approaches to acute trauma. CNS Spectr. Feb. 2005;10(2):99-106. [pmid: 15685120].
Putnam FW, Hulsmann JE. Pharmacotherapy for survivors of childhood trauma. Semin Clin Neuropsychiatry. Apr. 2002;7(2):129-36. [pmid: 11953937].
Reinblatt SP, Riddle MA. The pharmacological management of childhood anxiety disorders: a review. Psychopharmacology (Berl). Mar. 2007;191(1):67-86. [pmid: 17205317].
Roberts NP, Kitchiner NJ, Kenardy J, et al. Multiple session early psychological intervention to prevent and treat post-traumatic stress disorder. Cochrane Database of Systematic Reviews. 2009;(3).
Rolfsnes ES, Idsoe T. School-based intervention programs for PTSD symptoms: a review and meta-analysis. J Trauma Stress. Apr. 2011;24(2):155-65. [pmid: 21425191].
Rosner R, Kruse J, Hagl M. A meta-analysis of interventions for bereaved children and adolescents (Structured abstract). Death Studies. 2010;(2):99-136. DARE-12010002131.
Rowe CL, Liddle HA. When the levee breaks: treating adolescents and families in the aftermath of hurricane katrina. J Marital Fam Ther. Apr. 2008;34(2):132-48. [pmid: 18412822].
Rudd MD. Psychosocial interventions for self-harm. Br J Psychiatry. Oct. 2007;191:359-60. author reply 60. [pmid: 17906253].
Ryan ND. Continuation treatment with antidepressants in child and adolescent major depression. Am J Psychiatry. Apr. 2008;165(4):411-2. [pmid: 18381908].
Saddichha S, Kumar D. Is psychosocial management effective?. Arch Gen Psychiatry. Dec. 2007;64(12):1451. author reply 2-3. [pmid: 18056554].
Slesnick N, Bartle-Haring S, Gangamma R. Predictors of substance use and family therapy outcome among physically and sexually abused runaway adolescents. J Marital Fam Ther. Jul. 2006;32(3):261-81. [pmid: 16933433].
Spirito A. Is psychotherapy helpful for adolescent suicide attempters?. Crisis. 1997;18(1):3-4. [pmid: 9141770].
Stallard P. Psychological interventions for post-traumatic reactions in children and young people: a review of randomised controlled trials. Clin Psychol Rev. Nov. 2006;26(7):895-911. [pmid: 16481081].
Steele W, Kuban C. Using drawing in short-term trauma resolution. Malchiodi CA, editor. Handbook of art therapy. 2nd ed. New York, NY US. Guilford Press. 2012:162-74.
Steeves RH, Parker B, Laughon K, et al. Adolescents' Experiences with uxoricide. Journal of the American Psychiatric Nurses Association. 2011;17(2):115-23. [pmid: 21659301].
Stevenson J. The treatment of the long-term sequelae of child abuse. Journal of Child Psychology and Psychiatry and Allied Disciplines. Jan. 1999;40(1):89-111. WOS:000078874100005.
Sullivan JM, Evans K. Integrated treatment for the survivor of childhood trauma who is chemically dependent. J Psychoactive Drugs. Oct-Dec. 1994;26(4):369-78. [pmid: 7884599].
Taylor JE, Harvey ST. Effects of psychotherapy with people who have been sexually assaulted: A meta-analysis. Aggression and Violent Behavior. Sep-Oct. 2009;14(5):273-85. WOS:000270105900001.
Triffleman EG, Pole N. Future directions in studies of trauma among ethnoracial and sexual minority samples: commentary. J Consult Clin Psychol. Aug. 2010;78(4):490-7. [pmid: 20658806].
Turner W, Macdonald GM, Dennis JA. Cognitive-behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. 2005;(2):CD003760. [pmid: 15846680].
van Wylick R, Davidson L. Teaching about child abuse with a mock trial. Med Educ. May. 2011;45(5):517-8. [pmid: 21486340].
Waters F. When treatment fails with traumatized children…why?. J Trauma Dissociation. 2005;6(1):1-8. [pmid: 16150682].
Weber S. Treatment of trauma- and abuse-related dissociative symptom disorders in children and adolescents. J Child Adolesc Psychiatr Nurs. Feb. 2009;22(1):2-6. [pmid: 19200286].
Wittmann L, Halpern J, Adams CB, et al. Prolonged exposure and psychodynamic treatment for posttraumatic stress disorder. J Am Acad Child Adolesc Psychiatry. May. 2011;50(5):521-2. author reply 2-1. [pmid: 21515203].
Yeh CC, Chou JY, Hsieh MH, et al. Aripiprazole augmentation for the treatment of an adolescent with posttraumatic stress disorder. Prog Neuropsychopharmacol Biol Psychiatry. May. 30. 2010;34(4):722-3. [pmid: 20298737].
Young AC, Kenardy JA, Cobham VE. Trauma in early childhood: a neglected population. Clinical child and family psychology review. 2011;14(3):231-50. [pmid: 21455675].

## Excluded for Wrong Study Design

Avinger KA, Jones RA. Group treatment of sexually abused adolescent girls: A review of outcome studies. American Journal of Family Therapy. 2007;35(4):315-26.
Barlow J, Johnston I, Kendrick D, et al. Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database of Systematic Reviews. 2006;(3). CD005463.
Beale IL. Scholarly literature review: Efficacy of psychological interventions for pediatric chronic illnesses. J Pediatr Psychol. Jun. 2006;31(5):437-51. [pmid: 16162841].
Beehler S, Birman D, Campbell R. The Effectiveness of Cultural Adjustment and Trauma Services (CATS): Generating Practice-Based Evidence on a Comprehensive, School-Based Mental Health Intervention for Immigrant Youth. Am J Community Psychol. 2011. Dec. 8. [pmid: 22160732].
Briere J, Elliott DM, Harris K, et al. TRAUMA SYMPTOM INVENTORY - PSYCHOMETRICS AND ASSOCIATION WITH CHILDHOOD AND ADULT VICTIMIZATION IN CLINICAL-SAMPLES. Journal of Interpersonal Violence. Dec. 1995;10(4):387-401. WOS:A1995TF97400001.
Bryant RA, Guthrie RM, Moulds ML, et al. Hypnotizability and posttraumatic stress disorder: a prospective study. Int J Clin Exp Hypn. Oct. 2003;51(4):382-9. [pmid: 14594186].
Caffaro JV. IDENTIFICATION AND TRAUMA - AN INTEGRATIVE-DEVELOPMENTAL APPROACH. Journal of Family Violence. Mar. 1995;10(1):23-40. WOS:A1995QL69500002.
Caprilli S, Anastasi F, Grotto RP, et al. Interactive music as a treatment for pain and stress in children during venipuncture: a randomized prospective study. J Dev Behav Pediatr. Oct. 2007;28(5):399-403. [pmid: 18049324].
Carlson KL, Broome M, Vessey JA. Using distraction to reduce reported pain, fear, and behavioral distress in children and adolescents: a multisite study. J Soc Pediatr Nurs. Apr-Jun. 2000;5(2):75-85. [pmid: 10879362].
Celano M, Hazzard A, Webb C, et al. Treatment of traumagenic beliefs among sexually abused girls and their mothers: an evaluation study. J Abnorm Child Psychol. Feb. 1996;24(1):1-17. [pmid: 8833025].
Cohen JA, Mannarino AP. A treatment outcome study for sexually abused preschool children: initial findings. J Am Acad Child Adolesc Psychiatry. Jan. 1996;35(1):42-50. [pmid: 8567611].
Cohen JA, Mannarino AP. A treatment study for sexually abused preschool children: outcome during a one-year follow-up. J Am Acad Child Adolesc Psychiatry. Sep. 1997;36(9):1228-35. [pmid: 9291724].
Cohen JA, Mannarino AP. Psychotherapeutic options for traumatized children. Current Opinion in Pediatrics. Oct. 2010;22(5):605-9. WOS:000281843000009. [pmid: 20814304].
Cyr C, Euser EM, Bakermans-Kranenburg MJ, et al. Attachment security and disorganization in maltreating and high-risk families: a series of meta-analyses. Dev Psychopathol. Winter. 2010;22(1):87-108. [pmid: 20102649].
Deblinger E, Steer RA, Lippmann J. Two-year follow-up study of cognitive behavioral therapy for sexually abused children suffering post-traumatic stress symptoms. Child Abuse Negl. Dec. 1999;23(12):1371-8. [pmid: 10626618].
Duggan M, Dowd N, O'Mara D, et al. Benzodiazepine premedication may attenuate the stress response in daycase anesthesia: a pilot study. Can J Anaesth. Nov. 2002;49(9):932-5. [pmid: 12419719].
Durlak JA, Wells AM. Primary prevention mental health programs for children and adolescents: a meta-analytic review. Am J Community Psychol. Apr. 1997;25(2):115-52. [pmid: 9226860].
Ellis BH, Fogler J, Hansen S, et al. Trauma systems therapy: 15-month outcomes and the importance of effecting environmental change. Psychological Trauma: Theory, Research, Practice, and Policy. 2011. 2011-18640-001. Publication Status: Online First Posting. First Author & Affiliation: Ellis, B. Heidi. Release Date: 20110822. Correction Date: 20110829. Publication Type: Journal, (0100).
Fassaert T, Dorn T, Spreeuwenberg PM, et al. Prescription of benzodiazepines in general practice in the context of a man-made disaster: a longitudinal study. Eur J Public Health. Dec. 2007;17(6):612-7. [pmid: 17412715].
Feldman ES. Implementation of the Cognitive Behavioral Intervention for Trauma in Schools (CBITS) with Spanish-speaking, immigrant middle-school students: Is effective, culturally competent treatment possible within a public school setting?. [3261445]. United States -- Wisconsin. The University of Wisconsin-Madison. 2007.
Finkelhor D, Berliner L. Research on the treatment of sexually abused children: a review and recommendations. J Am Acad Child Adolesc Psychiatry. Nov. 1995;34(11):1408-23. [pmid: 8543508].
Foertsch CE, O'Hara MW, Kealey GP, et al. A quasi-experimental, dual-center study of morphine efficacy in patients with burns. J Burn Care Rehabil. Mar-Apr. 1995;16(2 Pt 1):118-26. [pmid: 7775504].
Glover AC, Roane HS, Kadey HJ, et al. Preference for reinforcers under progressive- and fixed-ratio schedules: a comparison of single and concurrent arrangements. J Appl Behav Anal. Summer. 2008;41(2):163-76. [pmid: 18595281].
Hagenaars MA, Brewin CR, van Minnen A, et al. Intrusive images and intrusive thoughts as different phenomena: two experimental studies. Memory. Jan. 2010;18(1):76-84. [pmid: 20391178].
Haight WL, Mangelsdorf S, Black J, et al. Enhancing parent-child interaction during foster care visits: experimental assessment of an intervention. Child Welfare. Jul-Aug. 2005;84(4):459-81. [pmid: 16117259].
House AS. Increasing the usability of cognitive processing therapy for survivors of child sexual abuse. J Child Sex Abus. 2006;15(1):87-103. [pmid: 16551587].
Hussey DL, Guo S. Characteristics and trajectories of treatment foster care youth. Child Welfare. Jul-Aug. 2005;84(4):485-506. [pmid: 16117260].
Johnson R, Browne K, Hamilton-Giachritsis C. Young children in institutional care at risk of harm (Structured abstract). Trauma, Violence, and Abuse. 2006;(1):34-60. DARE-12006008182.
Jordans MJD, Tol WA, Komproe IH, et al. Systematic review of evidence and treatment approaches: Psychosocial and mental health care for children in war. Child and Adolescent Mental Health. 2009;14(1):2-14.
Kant R, Chalansani R, Chengappa KN, et al. The off-label use of clozapine in adolescents with bipolar disorder, intermittent explosive disorder, or posttraumatic stress disorder. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):57-63. [pmid: 15142392].
Kazak AE, Simms S, Barakat L, et al. Surviving cancer competently intervention program (SCCIP): a cognitive-behavioral and family therapy intervention for adolescent survivors of childhood cancer and their families. Fam Process. Summer. 1999;38(2):175-91. [pmid: 10407719].
Lanktree CB, Briere J. Outcome of therapy for sexually abused children: a repeated measures study. Child Abuse Negl. Sep. 1995;19(9):1145-55. [pmid: 8528820].
Maeda M, Kato H, Maruoka T. Adolescent vulnerability to PTSD and effects of community-based intervention: Longitudinal study among adolescent survivors of the Ehime Maru sea accident. Psychiatry Clin Neurosci. Dec. 2009;63(6):747-53. [pmid: 20021628].
March JS, Amaya-Jackson L, Murray MC, et al. Cognitive-behavioral psychotherapy for children and adolescents with posttraumatic stress disorder after a single-incident stressor. Journal of the American Academy of Child and Adolescent Psychiatry. 1998;37(6):585-93. [pmid: 9628078].
Marom T, Goldfarb A, Russo E, et al. Battery ingestion in children. Int J Pediatr Otorhinolaryngol. Aug. 2010;74(8):849-54. [pmid: 20538351].
McDonell MG, Tarantino J, Dubose AP, et al. A Pilot Evaluation of Dialectical Behavioural Therapy in Adolescent Long-Term Inpatient Care. Child and Adolescent Mental Health. 2010;15(4):193-6.
McGain B, McKinzey RK. The efficacy of group treatment in sexually abused girls. Child Abuse Negl. Sep. 1995;19(9):1157-69. [pmid: 8528821].
Murphy RA, Rosenheck RA, Berkowitz SJ, et al. Acute service delivery in a police-mental health program for children exposed to violence and trauma. Psychiatr Q. Summer. 2005;76(2):107-21. [pmid: 15884740].
Nilsson D, Wadsby M. Symboldrama, a psychotherapeutic method for adolescents with dissociative and PTSD symptoms: a pilot study. J Trauma Dissociation. 2010;11(3):308-21. [pmid: 20603765].
O'Shea B, Hodes M, Down G, et al. A School-based Mental Health Service for Refugee Children. Clinical Child Psychology & Psychiatry. 2000;5(2):189. [pmid: 5434966].
Ovaert LB, Cashel ML, Sewell KW. Structured group therapy for posttraumatic stress disorder in incarcerated male juveniles. Am J Orthopsychiatry. Jul. 2003;73(3):294-301. [pmid: 12921210].
Passarela CDM, Mendes DD, De Jesus Mari J. A systematic review to study the efficacy of cognitive behavioral therapy for sexually abused children and adolescents with posttraumatic stress disorder. Revista de Psiquiatria Clinica. 2010;37(2):63-73.
Patterson DR, Tininenko J, Ptacek JT. Pain during burn hospitalization predicts long-term outcome. J Burn Care Res. Sep-Oct. 2006;27(5):719-26. [pmid: 16998406].
Peled E, Edleson JL. Multiple perspectives on groupwork with children of battered women. Violence Vict. Winter. 1992;7(4):327-46. [pmid: 1308439].
Pine DS, Cohen JA. Trauma in children and adolescents: risk and treatment of psychiatric sequelae. Biol Psychiatry. Apr. 1. 2002;51(7):519-31. [pmid: 11950454].
Poijula S, Dyregrov A, Wahlberg KE, et al. Reactions to adolescent suicide and crisis intervention in three secondary schools. International journal of emergency mental health. 2001;3(2):97-106. [pmid: 11508571].
Prchal A, Landolt MA. Psychological interventions with siblings of pediatric cancer patients: a systematic review (Structured abstract). Psycho-Oncology. 2009;(12):1241-51. DARE-12010001588. [pmid: 19382110].
Ritschel LA. School-based group psychotherapy for at-risk adolescents. Int J Group Psychother. 2011;61(2):311-7. [pmid: 21463103].
Robert R, Meyer WJ 3rd, Villarreal C, et al. An approach to the timely treatment of acute stress disorder. J Burn Care Rehabil. May-Jun. 1999;20(3):250-8. [pmid: 10342481].
Roussos A, Goenjian AK, Steinberg AM, et al. Posttraumatic stress and depressive reactions among children and adolescents after the 1999 earthquake in Ano Liosia, Greece. Am J Psychiatry. Mar. 2005;162(3):530-7. [pmid: 15741470].
Saxe G, Stoddard F, Courtney D, et al. Relationship between acute morphine and the course of PTSD in children with burns. J Am Acad Child Adolesc Psychiatry. Aug. 2001;40(8):915-21. [pmid: 11501691].
Seedat S, Lockhat R, Kaminer D, et al. An open trial of citalopram in adolescents with post-traumatic stress disorder. Int Clin Psychopharmacol. Jan. 2001;16(1):21-5. [pmid: 11195256].
Sezibera V, Van Broeck N, Philippot P. Intervening on persistent posttraumatic stress disorder: Rumination-focused cognitive and behavioral therapy in a population of young survivors of the 1994 genocide in Rwanda. Journal of Cognitive Psychotherapy. 2009;23(2):107-13.
Silverman WK, Ortiz CD, Viswesvaran C, et al. Evidence-based psychosocial treatments for children and adolescents exposed to traumatic events (Structured abstract). Journal of Clinical Child and Adolescent Psychology. 2008;(1):156-83. DARE-12008103480. [pmid: 18444057].
Steiner H, Saxena KS, Carrion V, et al. Divalproex sodium for the treatment of PTSD and conduct disordered youth: a pilot randomized controlled clinical trial. Child Psychiatry Hum Dev. Oct. 2007;38(3):183-93. [pmid: 17570057].
Strawn JR, Keeshin BR, DelBello MP, et al. Psychopharmacologic treatment of posttraumatic stress disorder in children and adolescents: a review. J Clin Psychiatry. Jul. 2010;71(7):932-41. [pmid: 20441729].
Tcheung WJ, Robert R, Rosenberg L, et al. Early treatment of acute stress disorder in children with major burn injury. Pediatr Crit Care Med. Nov. 2005;6(6):676-81. [pmid: 16276335].
Tourigny M, Hebert M. Comparison of open versus closed group interventions for sexually abused adolescent girls. Violence Vict. 2007;22(3):334-49. [pmid: 17619638].
Turner W, Macdonald G, Dennis Jane A. Behavioural and cognitive behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database of Systematic Reviews. 2007;(1). CD003760.
Van der Oord S, Lucassen S, Van Emmerik AA, et al. Treatment of post-traumatic stress disorder in children using cognitive behavioural writing therapy. Clin Psychol Psychother. May-Jun. 2010;17(3):240-9. [pmid: 20013756].
Vance Y, Eiser C. Caring for a child with cancer--a systematic review. Pediatr Blood Cancer. Mar. 2004;42(3):249-53. [pmid: 14752862].
Weiss B, Dodge KA, Bates JE, et al. Some consequences of early harsh discipline: child aggression and a maladaptive social information processing style. Child Dev. Dec. 1992;63(6):1321-35. [pmid: 1446555].
Wheatley M, Plant J, Reader H, et al. Clozapine treatment of adolescents with posttraumatic stress disorder and psychotic symptoms. J Clin Psychopharmacol. Apr. 2004;24(2):167-73. [pmid: 15206664].
Wolff PH, Fesseha G. The orphans of Eritrea: are orphanages part of the problem or part of the solution?. Am J Psychiatry. Oct. 1998;155(10):1319-24. [pmid: 9766761].
Wolff PH, Fesseha G. The orphans of Eritrea: what are the choices?. Am J Orthopsychiatry. Oct. 2005;75(4):475-84. [pmid: 16262507].

## Excluded for Wrong Population

Ahmad A, Larsson B, Sundelin-Wahlsten V. EMDR treatment for children with PTSD: results of a randomized controlled trial. Nord J Psychiatry. 2007;61(5):349-54. [pmid: 17990196].
Ahmad A, Sundelin-Wahlsten V. Applying EMDR on children with PTSD. Eur Child Adolesc Psychiatry. Apr. 2008;17(3):127-32. [pmid: 17846813].
Ahmed S, Rahman F. Childhood burn injury and suffering of affected families. Bangladesh Med Res Counc Bull. Apr. 2009;35(1):26-7. [pmid: 19637543].
Alfven G, Lindstrom A. A new method for the treatment of recurrent abdominal pain of prolonged negative stress origin. Acta Paediatr. Jan. 2007;96(1):76-81. [pmid: 17187609].
Armelius BÅ, Andreassen Tore H. Cognitive-behavioral treatment for antisocial behavior in youth in residential treatment. Cochrane Database of Systematic Reviews. 2007;(4). CD005650.
Arnold EM, Kirk RS, Roberts AC, et al. Treatment of incarcerated, sexually-abused adolescent females: an outcome study. J Child Sex Abus. 2003;12(1):123-39. [pmid: 16221662].
Arntz A, Tiesema M, Kindt M. Treatment of PTSD: a comparison of imaginal exposure with and without imagery rescripting. J Behav Ther Exp Psychiatry. Dec. 2007;38(4):345-70. [pmid: 18005935].
Asarnow JR, Porta G, Spirito A, et al. Suicide attempts and nonsuicidal self-injury in the treatment of resistant depression in adolescents: Findings from the TORDIA study. Journal of the American Academy of Child and Adolescent Psychiatry. 2011;50(8):772-81. [pmid: 21784297].
Ayduk O, Kross E. Enhancing the pace of recovery: self-distanced analysis of negative experiences reduces blood pressure reactivity. Psychol Sci. Mar. 2008;19(3):229-31. [pmid: 18315794].
Ballenger JC. Remission rates in patients with anxiety disorders treated with paroxetine. J Clin Psychiatry. Dec. 2004;65(12):1696-707. [pmid: 15641876].
Barekatain M, Taghavi T, Salehi M, et al. The efficacy of Rational-Emotive-Behavioral versus relaxation group therapies in treatment of aggression of offspring of veterans with post traumatic stress disorder. Journal of Research in Medical Sciences. 2006;11(1):34-40.
Barrett PM. Evaluation of cognitive-behavioral group treatments for childhood anxiety disorders. Journal of Clinical Child Psychology. 1998;27(4):459-68. 1999-00482 010. First Author & Affiliation: Barrett, Paula M. [pmid: 9866083].
Barrett PM, Dadds MR, Rapee RM. Family treatment of childhood anxiety: A controlled trial. Journal of Consulting and Clinical Psychology. 1996;64(2):333-42. 1996-00433-012. First Author & Affiliation: Barrett, Paula M. [pmid: 8871418].
Barrett PM, Duffy AL, Dadds MR, et al. Cognitive–behavioral treatment of anxiety disorders in children: Long-term (6-year) follow-up. Journal of Consulting and Clinical Psychology. 2001;69(1):135-41. 2001-14541-018. First Author & Affiliation: Barrett, Paula M. [pmid: 11302272].
Barton K, Baglio CS, Braverman MT. Stress reduction in child-abusing families: global and specific measures. Psychol Rep. Aug. 1994;75(1 Pt 1):287-304. [pmid: 7984740].
Basoglu M, Salcioglu E, Livanou M, et al. Single-session behavioral treatment of earthquake-related posttraumatic stress disorder: a randomized waiting list controlled trial. J Trauma Stress. Feb. 2005;18(1):1-11. [pmid: 16281190].
Bauer M, Priebe S. Psychopathology and long-term adjustment after crises in refugees from East Germany. Int J Soc Psychiatry. Autumn. 1994;40(3):165-76. [pmid: 7822109].
Baumann N, Kaschel R, Kuhl J. Striving for unwanted goals: stress-dependent discrepancies between explicit and implicit achievement motives reduce subjective well-being and increase psychosomatic symptoms. J Pers Soc Psychol. Nov. 2005;89(5):781-99. [pmid: 16351368].
Beidel DC, Turner SM, Morris TL. Behavioral treatment of childhood social phobia. Journal of Consulting and Clinical Psychology. 2000;68(6):1072-80. 2001-17092-013. First Author & Affiliation: Beidel, Deborah C. [pmid: 11142541].
Belleville G, Guay S, Marchand A. Persistence of sleep disturbances following cognitive-behavior therapy for posttraumatic stress disorder. J Psychosom Res. Apr. 2011;70(4):318-27. [pmid: 21414451].
Bisson JI, Shepherd JP, Joy D, et al. Early cognitive-behavioural therapy for post-traumatic stress symptoms after physical injury. Randomised controlled trial. Br J Psychiatry. Jan. 2004;184:63-9. [pmid: 14702229].
Blaha J, Svobodova K, Kapounkova Z. Therapeutical aspects of using citalopram in burns. Acta Chir Plast. 1999;41(1):25-32. [pmid: 10394177].
Bolton P, Bass J, Betancourt T, et al. Interventions for depression symptoms among adolescent survivors of war and displacement in northern Uganda: a randomized controlled trial. JAMA. Aug. 1. 2007;298(5):519-27. [pmid: 17666672].
Bos K, Zeanah CH, Fox NA, et al. Psychiatric outcomes in young children with a history of institutionalization. Harv Rev Psychiatry. Jan-Feb. 2011;19(1):15-24. [pmid: 21250893].
Bouwer C, Stein DJ. Survivors of torture presenting at an anxiety disorders clinic: symptomatology and pharmacotherapy. J Nerv Ment Dis. May. 1998;186(5):316-8. [pmid: 9612450].
Braga LW, Da Paz AC, Ylvisaker M. Direct clinician-delivered versus indirect family-supported rehabilitation of children with traumatic brain injury: a randomized controlled trial. Brain Inj. Sep. 2005;19(10):819-31. [pmid: 16175842].
Brazzelli M, Griffiths Peter V. Behavioural and cognitive interventions with or without other treatments for the management of faecal incontinence in children. Cochrane Database of Systematic Reviews. 2006;(2). CD002240.
Breschan C, Platzer M, Jost R, et al. Midazolam does not reduce emergence delirium after sevoflurane anesthesia in children. Paediatr Anaesth. Apr. 2007;17(4):347-52. [pmid: 17359403].
Bryant RA, Moulds ML, Guthrie RM, et al. Imaginal exposure alone and imaginal exposure with cognitive restructuring in treatment of posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2003;71(4):706-12. [pmid: 12924676].
Bryant RA, Moulds ML, Guthrie RM, et al. The additive benefit of hypnosis and cognitive-behavioral therapy in treating acute stress disorder. J Consult Clin Psychol. Apr. 2005;73(2):334-40. [pmid: 15796641].
Bryant RA, Moulds ML, Nixon RD, et al. Hypnotherapy and cognitive behaviour therapy of acute stress disorder: a 3-year follow-up. Behav Res Ther. Sep. 2006;44(9):1331-5. [pmid: 16368074].
Bugg A, Turpin G, Mason S, et al. A randomised controlled trial of the effectiveness of writing as a self-help intervention for traumatic injury patients at risk of developing post-traumatic stress disorder. Behaviour research and therapy. 2009;(1):6-12. CN-00723191. [pmid: 19012880].
Bulinski L. Post accessive social policy in the rehabilitation of adolescents following TBI. Med Sci Monit. Jan. 2011;17(1):CR14-25. [pmid: 21169906].
Butler LD, Symons BK, Henderson SL, et al. Hypnosis reduces distress and duration of an invasive medical procedure for children. Pediatrics. Jan. 2005;115(1):e77-85. [pmid: 15629969].
Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. Jul. 2001;16(4):197-203. [pmid: 11459333].
Cartwright-Hatton S, Roberts C, Chitsabesan P, et al. Systematic review of the efficacy of cognitive behaviour therapies for childhood and adolescent anxiety disorders. Br J Clin Psychol. Nov. 2004;43(Pt 4):421-36. [pmid: 15530212].
Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. Jun. 2004;72(3):500-10. [pmid: 15279533].
Cicchetti D, Rogosch FA, Toth SL. Fostering secure attachment in infants in maltreating families through preventive interventions. Dev Psychopathol. Summer. 2006;18(3):623-49. [pmid: 17152394].
Cloitre M, Koenen KC, Cohen LR, et al. Skills training in affective and interpersonal regulation followed by exposure: a phase-based treatment for PTSD related to childhood abuse. J Consult Clin Psychol. Oct. 2002;70(5):1067-74. [pmid: 12362957].
Cloitre M, Stovall-McClough KC, Nooner K, et al. Treatment for PTSD related to childhood abuse: a randomized controlled trial. Am J Psychiatry. Aug. 2010;167(8):915-24. [pmid: 20595411].
Cobham VE, Dadds MR, Spence SH. The role of parental anxiety in the treatment of childhood anxiety. Journal of Consulting and Clinical Psychology. 1998;66(6):893-905. 1998-11580-002. First Author & Affiliation: Cobham, Vanessa E. [pmid: 9874902].
Cohen JA, Deblinger E, Mannarino AP, et al. A multisite, randomized controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):393-402. [pmid: 15187799].
Cohen JA, Mannarino AP. Factors that mediate treatment outcome of sexually abused preschool children. J Am Acad Child Adolesc Psychiatry. Oct. 1996;35(10):1402-10. [pmid: 8885595].
Cohen JA, Mannarino AP, Iyengar S. Community treatment of posttraumatic stress disorder for children exposed to intimate partner violence: a randomized controlled trial. Arch Pediatr Adolesc Med. Jan. 2011;165(1):16-21. [pmid: 21199975].
Cohen JA, Mannarino AP, Knudsen K. Treating sexually abused children: 1 year follow-up of a randomized controlled trial. Child Abuse Negl. Feb. 2005;29(2):135-45. [pmid: 15734179].
Cohen JA, Mannarino AP, Perel JM, et al. A pilot randomized controlled trial of combined trauma-focused CBT and sertraline for childhood PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Jul. 2007;46(7):811-9. [pmid: 17581445].
Connors K, Terndrup TE. Nasal versus oral midazolam for sedation of anxious children undergoing laceration repair. Ann Emerg Med. Dec. 1994;24(6):1074-9. [pmid: 7978588].
Cook JA, Heflinger CA, Hoven CW, et al. A multi-site study of Medicaid-funded managed care versus fee-for-service plans' effects on mental health service utilization of children with severe emotional disturbance. J Behav Health Serv Res. Oct-Dec. 2004;31(4):384-402. [pmid: 15602140].
Cottraux J, Note I, Yao SN, et al. Randomized controlled comparison of cognitive behavior therapy with Rogerian supportive therapy in chronic post-traumatic stress disorder: a 2-year follow-up. Psychother Psychosom. 2008;77(2):101-10. [pmid: 18230943].
Craig AR, Hancock K, Dickson H, et al. Long-term psychological outcomes in spinal cord injured persons: results of a controlled trial using cognitive behavior therapy. Arch Phys Med Rehabil. Jan. 1997;78(1):33-8. [pmid: 9014954].
Cuthbertson BH, Hull A, Strachan M, et al. Post-traumatic stress disorder after critical illness requiring general intensive care. Intensive Care Med. Mar. 2004;30(3):450-5. [pmid: 12961065].
Davidson J, Landerman LR, Clary CM. Improvement of anger at one week predicts the effects of sertraline and placebo in PTSD. J Psychiatr Res. Sep-Oct. 2004;38(5):497-502. [pmid: 15380400].
Davidson JR, Landerman LR, Farfel GM, et al. Characterizing the effects of sertraline in post-traumatic stress disorder. Psychol Med. May. 2002;32(4):661-70. [pmid: 12102380].
Davidson JR, Weisler RH, Malik ML, et al. Treatment of posttraumatic stress disorder with nefazodone. Int Clin Psychopharmacol. May. 1998;13(3):111-3. [pmid: 9690977].
De Guise E, Leblanc J, Feyz M, et al. Effect of an integrated reality orientation programme in acute care on post-traumatic amnesia in patients with traumatic brain injury. Brain Inj. Apr. 2005;19(4):263-9. [pmid: 15832872].
Deblinger E, Lippmann J, Steer R. Sexually Abused Children Suffering Posttraumatic Stress Symptoms: Initial Treatment Outcome Findings. Child Maltreatment Child Maltreatment. 1996;1(4):310-21.
Deblinger E, Mannarino AP, Cohen JA, et al. Trauma-focused cognitive behavioral therapy for children: impact of the trauma narrative and treatment length. Depress Anxiety. Jan. 2011;28(1):67-75. [pmid: 20830695].
Deblinger E, Mannarino AP, Cohen JA, et al. A follow-up study of a multisite, randomized, controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Dec. 2006;45(12):1474-84. [pmid: 17135993].
Deblinger E, Stauffer LB, Steer RA. Comparative efficacies of supportive and cognitive behavioral group therapies for young children who have been sexually abused and their nonoffending mothers. Child Maltreat. Nov. 2001;6(4):332-43. [pmid: 11675816].
DeGarmo DS, Forgatch MS. Early development of delinquency within divorced families: evaluating a randomized preventive intervention trial. Dev Sci. May. 2005;8(3):229-39. [pmid: 15819755].
Devoe ER, Dean K, Traube D, et al. The SURVIVE Community Project: A Family-Based Intervention to Reduce the Impact of Violence Exposures in Urban Youth. J Aggress Maltreat Trauma. 2005;11(4):95-116. [pmid: 21369343].
Dorrepaal E, Thomaes K, Smit JH, et al. Stabilizing group treatment for Complex Posttraumatic Stress Disorder related to childhood abuse based on psycho-education and cognitive behavioral therapy: a pilot study. Child Abuse Negl. Apr. 2010;34(4):284-8. [pmid: 20303592].
Dorrepaal E, Thomaes K, Smit JH, et al. Stabilizing Group Treatment for Complex Posttraumatic Stress Disorder Related to Child Abuse Based on Psychoeducation and Cognitive Behavioural Therapy: A Multisite Randomized Controlled Trial. Psychother Psychosom. 2012;81(4):217-25. WOS:000305099500003. [pmid: 22585094].
Drummond J, Fleming D, McDonald L, et al. Randomized controlled trial of a family problem-solving intervention. Clin Nurs Res. Feb. 2005;14(1):57-80. [pmid: 15604228].
Duffy M, Gillespie K, Clark DM. Post-traumatic stress disorder in the context of terrorism and other civil conflict in Northern Ireland: Randomised controlled trial. British Medical Journal. 2007;334(7604):1147-50. [pmid: 17495988].
Dunne RL, Kenardy J, Sterling M. A Randomized Controlled Trial of Cognitive-behavioral Therapy for the Treatment of PTSD in the Context of Chronic Whiplash. Clin J Pain. 2011. Dec. 30. [pmid: 22209798].
Ertl V, Pfeiffer A, Schauer E, et al. Community-implemented trauma therapy for former child soldiers in Northern Uganda: a randomized controlled trial. JAMA. Aug. 3. 2011;306(5):503-12. [pmid: 21813428].
Eyberg SM, Funderburk BW, Hembree-Kigin TL, et al. Parent-Child Interaction Therapy with behavior problem children: One and two year maintenance of treatment effects in the family. Child & Family Behavior Therapy. 2001;23(4):1-20. ISI:000180809800001.
Faller KC, Nelson-Gardell D. Extended evaluations in cases of child sexual abuse: how many sessions are sufficient?. J Child Sex Abus. Nov. 2010;19(6):648-68. [pmid: 21113833].
Fatovich DM, Jacobs IG. A randomized, controlled trial of oral midazolam and buffered lidocaine for suturing lacerations in children (the SLIC Trial). Ann Emerg Med. Feb. 1995;25(2):209-14. [pmid: 7832349].
Field T. Massage therapy for skin conditions in young children. Dermatol Clin. Oct. 2005;23(4):717-21. [pmid: 16112449].
Fisher PA, Gunnar MR, Dozier M, et al. Effects of therapeutic interventions for foster children on behavioral problems, caregiver attachment, and stress regulatory neural systems. Ann N Y Acad Sci. Dec. 2006;1094:215-25. [pmid: 17347353].
Fisher PA, Stoolmiller M. Intervention effects on foster parent stress: associations with child cortisol levels. Dev Psychopathol. Summer. 2008;20(3):1003-21. [pmid: 18606041].
Flannery-Schroeder EC, Kendall PC. Group and individual cognitive–behavioral treatments for youth with anxiety disorders: A randomized clinical trial. Cognitive Therapy and Research. 2000;24(3):251-78. 2000-00017-001. First Author & Affiliation: Flannery-Schroeder, Ellen C.
Foa EB, Hearst-Ikeda D, Perry KJ. Evaluation of a brief cognitive-behavioral program for the prevention of chronic PTSD in recent assault victims. J Consult Clin Psychol. Dec. 1995;63(6):948-55. [pmid: 8543717].
Foley T, Spates CR. Eye movement desensitization of public-speaking anxiety: a partial dismantling. J Behav Ther Exp Psychiatry. Dec. 1995;26(4):321-9. [pmid: 8675719].
Folkes CE. Thought field therapy and trauma recovery. Int J Emerg Ment Health. Spring. 2002;4(2):99-103. [pmid: 12166020].
Ford JD, Kidd P. Early childhood trauma and disorders of extreme stress as predictors of treatment outcome with chronic posttraumatic stress disorder. J Trauma Stress. Oct. 1998;11(4):743-61. [pmid: 9870225].
Gabel S, Swanson AJ, Shindledecker R. Aggressive children in a day treatment program: changed outcome and possible explanations. Child Abuse Negl. 1990;14(4):515-23. [pmid: 2289182].
Garland AF, Landsverk JL, Hough RL, et al. Type of maltreatment as a predictor of mental health service use for children in foster care. Child Abuse Negl. Aug. 1996;20(8):675-88. [pmid: 8866114].
Gelsomini S. Use of pivagabine in the management of hospitalization distress in children. Arzneimittelforschung. Nov. 1997;47(11A):1332-5. [pmid: 9450160].
Germain V, Marchand A, Bouchard S, et al. Assessment of the therapeutic alliance in face-to-face or videoconference treatment for posttraumatic stress disorder. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):29-35. [pmid: 20528290].
Ghai B, Grandhe RP, Kumar A, et al. Comparative evaluation of midazolam and ketamine with midazolam alone as oral premedication. Paediatr Anaesth. Jul. 2005;15(7):554-9. [pmid: 15960638].
Ghosh Ippen C, Harris WW, Van Horn P, et al. Traumatic and stressful events in early childhood: Can treatment help those at highest risk?. Child Abuse and Neglect. 2011;35(7):504-13. [pmid: 21816474].
Giannotta F, Settanni M, Kliewer W, et al. Results of an Italian school-based expressive writing intervention trial focused on peer problems. J Adolesc. Dec. 2009;32(6):1377-89. [pmid: 19647311].
Gillespie K, Duffy M, Hackmann A, et al. Community based cognitive therapy in the treatment of posttraumatic stress disorder following the Omagh bomb. Behav Res Ther. Apr. 2002;40(4):345-57. [pmid: 12002894].
Goldbeck L, Laib-Koehnemund A, Fegert JM. A randomized controlled trial of consensus-based child abuse case management. Child abuse & neglect. 2007;(9):919-33. CN-00619388. [pmid: 17870161].
Goldbeck L, Schmid K. Effectiveness of autogenic relaxation training on children and adolescents with behavioral and emotional problems. J Am Acad Child Adolesc Psychiatry. Sep. 2003;42(9):1046-54. [pmid: 12960704].
Graae F, Milner J, Rizzotto L, et al. Clonazepam in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. Mar-Apr. 1994;33(3):372-6. [pmid: 8169182].
Graham-Bermann SA, Lynch S, Banyard V, et al. Community-based intervention for children exposed to intimate partner violence: an efficacy trial. J Consult Clin Psychol. Apr. 2007;75(2):199-209. [pmid: 17469878].
Greenberg MA, Wortman CB, Stone AA. Emotional expression and physical health: revising traumatic memories or fostering self-regulation?. J Pers Soc Psychol. Sep. 1996;71(3):588-602. [pmid: 8831163].
Greenfield B, Hechtman L, Tremblay C. Short-term efficacy of interventions by a youth crisis team. Can J Psychiatry. Aug. 1995;40(6):320-4. [pmid: 7585401].
Habigzang LF, Stroeher FH, Hatzenberger R, et al. Cognitive behavioral group therapy for sexually abused girls. Rev Saude Publica. Aug. Suppl 1. 2009;43:70-8. [pmid: 19669067].
Hamama L, Hamama-Raz Y, Dagan K, et al. A preliminary study of group intervention along with basic canine training among traumatized teenagers: A 3-month longitudinal study. Children and Youth Services Review. 2011;33(10):1975-80. 2011-11576-001. First Author & Affiliation: Hamama, Liat.
Han C, Masand PS, Krulewicz S, et al. Childhood abuse and treatment response in patients with irritable bowel syndrome: a post-hoc analysis of a 12-week, randomized, double-blind, placebo-controlled trial of paroxetine controlled release. J Clin Pharm Ther. Feb. 2009;34(1):79-88. [pmid: 19125906].
Hartig T, Book A, Garvill J, et al. Environmental influences on psychological restoration. Scand J Psychol. Dec. 1996;37(4):378-93. [pmid: 8931393].
Harvey ST, Taylor JE. A meta-analysis of the effects of psychotherapy with sexually abused children and adolescents. Clin Psychol Rev. Jul. 2010;30(5):517-35. [pmid: 20417003].
Hayward C, Varady S, Albano AM, et al. Cognitive–behavioral group therapy for social phobia in female adolescents: Results of a pilot study. Journal of the American Academy of Child & Adolescent Psychiatry. 2000;39(6):721-6. 2000-15897-010. First Author & Affiliation: Hayward, Chris. [pmid: 10846306].
Hazell P, Lewin T. An evaluation of postvention following adolescent suicide. Suicide Life Threat Behav. Summer. 1993;23(2):101-9. [pmid: 8342209].
Heinrich M, Wetzstein V, Muensterer OJ, et al. Conscious sedation: Off-label use of rectal S(+)-ketamine and midazolam for wound dressing changes in paediatric heat injuries. Eur J Pediatr Surg. Aug. 2004;14(4):235-9. [pmid: 15343462].
Hensley PL, Slonimski CK, Uhlenhuth EH, et al. Escitalopram: an open-label study of bereavement-related depression and grief. Journal of affective disorders. 2009;(1-2):142-9. CN-00684797. [pmid: 18597854].
Hetrick SE, Purcell R, Garner B, et al. Combined pharmacotherapy and psychological therapies for post traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2010;(7):CD007316. [pmid: 20614457].
Hetzel-Riggin MD, Brausch AM, Montgomery BS. A meta-analytic investigation of therapy modality outcomes for sexually abused children and adolescents: An exploratory study. Child abuse & neglect. Feb. 2007;31(2):125-41. WOS:000245570600004. [pmid: 17306369].
Hobbs M, Mayou R, Harrison B, et al. A randomised controlled trial of psychological debriefing for victims of road traffic accidents. BMJ. Dec. 7. 1996;313(7070):1438-9. [pmid: 8973231].
Hoge EA, Worthington JJ, Nagurney JT, et al. Effect of acute posttrauma propranolol on PTSD outcome and physiological responses during script-driven imagery. CNS Neurosci Ther. Jan. 2012;18(1):21-7. [pmid: 22070357].
Holowaty KAM, Paivio SC. Characteristics of client-identified helpful events in emotion-focused therapy for child abuse trauma. Psychotherapy Research. 2012;22(1):56-66. WOS:000302246600005. [pmid: 22171630].
Hooft IV, Andersson K, Bergman B, et al. Beneficial effect from a cognitive training programme on children with acquired brain injuries demonstrated in a controlled study. Brain Inj. Jul. 2005;19(7):511-8. [pmid: 16134739].
Hopmeyer E, Werk A. A comparative study of family bereavement groups. Death Stud. May-Jun. 1994;18(3):243-56. [pmid: 10135136].
Horowitz LA, Putnam FW, Noll JG, et al. Factors affecting utilization of treatment services by sexually abused girls. Child Abuse Negl. Jan. 1997;21(1):35-48. [pmid: 9023021].
Huxley P, Warner R. Primary prevention of parenting dysfunction in high-risk cases. Am J Orthopsychiatry. Oct. 1993;63(4):582-8. [pmid: 8267098].
Hyun MS, Chung HI, Lee YJ. The effect of cognitive-behavioral group therapy on the self-esteem, depression, and self-efficacy of runaway adolescents in a shelter in South Korea. Appl Nurs Res. Aug. 2005;18(3):160-6. [pmid: 16106334].
Irwin HJ. CODEPENDENCE, NARCISSISM, AND CHILDHOOD TRAUMA. Journal of clinical psychology. Sep. 1995;51(5):658-65. WOS:A1995RX11000010. [pmid: 8801242].
Izzo CV, Eckenrode JJ, Smith EG, et al. Reducing the impact of uncontrollable stressful life events through a program of nurse home visitation for new parents. Prev Sci. Dec. 2005;6(4):269-74. [pmid: 16075193].
Jaberghaderi N, Greenwald R, Rubin A, et al. A comparison of CBT and EMDR for sexually-abused Iranian girls. Clinical Psychology and Psychotherapy. 2004;11(5):358-68.
Jain K, Ghai B, Saxena AK, et al. Efficacy of two oral premedicants: midazolam or a low-dose combination of midazolam-ketamine for reducing stress during intravenous cannulation in children undergoing CT imaging. Paediatr Anaesth. Apr. 2010;20(4):330-7. [pmid: 20470336].
Jones C, Skirrow P, Griffiths RD, et al. Post-traumatic stress disorder-related symptoms in relatives of patients following intensive care. Intensive Care Med. Mar. 2004;30(3):456-60. [pmid: 14767589].
Jones C, Skirrow P, Griffiths RD, et al. Rehabilitation after critical illness: a randomized, controlled trial. Crit Care Med. Oct. 2003;31(10):2456-61. [pmid: 14530751].
Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
Judge Santacroce S, Asmus K, Kadan-Lottick N, et al. Feasibility and preliminary outcomes from a pilot study of coping skills training for adolescent--young adult survivors of childhood cancer and their parents. J Pediatr Oncol Nurs. Jan-Feb. 2010;27(1):10-20. [pmid: 19687468].
Karatzias A, Power K, McGoldrick T, et al. Predicting treatment outcome on three measures for post-traumatic stress disorder. European archives of psychiatry and clinical neuroscience. 2007;(1):40-6. CN-00608812. [pmid: 16915361].
Katz C, Hershkowitz I. The effects of drawing on children's accounts of sexual abuse. Child Maltreat. May. 2010;15(2):171-9. [pmid: 19926626].
Katz LY, Cox BJ, Gunasekara S, et al. Feasibility of dialectical behavior therapy for suicidal adolescent inpatients. J Am Acad Child Adolesc Psychiatry. Mar. 2004;43(3):276-82. [pmid: 15076260].
Kazak AE, Alderfer MA, Streisand R, et al. Treatment of posttraumatic stress symptoms in adolescent survivors of childhood cancer and their families: a randomized clinical trial. J Fam Psychol. Sep. 2004;18(3):493-504. [pmid: 15382974].
Kazak AE, Simms S, Alderfer MA, et al. Feasibility and preliminary outcomes from a pilot study of a brief psychological intervention for families of children newly diagnosed with cancer. J Pediatr Psychol. Dec. 2005;30(8):644-55. [pmid: 16260434].
Keller SM, Zoellner LA, Feeny NC. Understanding factors associated with early therapeutic alliance in PTSD treatment: adherence, childhood sexual abuse history, and social support. J Consult Clin Psychol. Dec. 2010;78(6):974-9. [pmid: 20873895].
Kendall JM, Charters A, McCabe SE. Topical anaesthesia for children's lacerations: an acceptable approach?. J Accid Emerg Med. Mar. 1996;13(2):119-22. [pmid: 8653235].
Kendall PC, Flannery-Schroeder E, Panichelli-Mindel SM, et al. Therapy for youths with anxiety disorders: A second randomized clincal trial. Journal of Consulting and Clinical Psychology. 1997;65(3):366-80. 1997-06366-002. First Author & Affiliation: Kendall, Philip C. [pmid: 9170760].
Kennedy P, Duff J, Evans M, et al. Coping effectiveness training reduces depression and anxiety following traumatic spinal cord injuries. Br J Clin Psychol. Mar. 2003;42(Pt 1):41-52. [pmid: 12675978].
King NJ, Tonge BJ, Heyne D, et al. Cognitive-behavioral treatment of school-refusing children: A controlled evaluation. Journal of the American Academy of Child & Adolescent Psychiatry. 1998;37(4):395-403. 1998-01321-017. First Author & Affiliation: King, Neville J. [pmid: 9549960].
King NJ, Tonge BJ, Mullen P, et al. Treating sexually abused children with posttraumatic stress symptoms: a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. Nov. 2000;39(11):1347-55. [pmid: 11068889].
Kline WH, Turnbull A, Labruna VE, et al. Enhancing pain management in the PICU by teaching guided mental imagery: a quality-improvement project. J Pediatr Psychol. Jan-Feb. 2010;35(1):25-31. [pmid: 19386770].
Knaevelsrud C, Liedl A, Maercker A. Posttraumatic growth, optimism and openness as outcomes of a cognitive-behavioural intervention for posttraumatic stress reactions. J Health Psychol. Oct. 2010;15(7):1030-8. [pmid: 20511285].
Kowalik J, Weller J, Venter J, et al. Cognitive behavioral therapy for the treatment of pediatric posttraumatic stress disorder: a review and meta-analysis. J Behav Ther Exp Psychiatry. Sep. 2011;42(3):405-13. [pmid: 21458405].
Krakow B, Sandoval D, Schrader R, et al. Treatment of chronic nightmares in adjudicated adolescent girls in a residential facility. J Adolesc Health. Aug. 2001;29(2):94-100. [pmid: 11472867].
Kruczek T, Vitanza S. Treatment effects with an adolescent abuse survivor's group. Child Abuse Negl. May. 1999;23(5):477-85. [pmid: 10348383].
Kruse J, Joksimovic L, Cavka M, et al. Effects of trauma-focused psychotherapy upon war refugees. J Trauma Stress. Dec. 2009;22(6):585-92. [pmid: 19960519].
Lange A, van de Ven JP, Schrieken B, et al. Interapy, treatment of posttraumatic stress through the Internet: a controlled trial. J Behav Ther Exp Psychiatry. Jun. 2001;32(2):73-90. [pmid: 11764063].
Last CG, Hansen C, Franco N. Cognitive-behavioral treatment of school phobia. Journal of the American Academy of Child & Adolescent Psychiatry. 1998;37(4):404-11. 1998-01321-018. First Author & Affiliation: Last, Cynthia G. [pmid: 9549961].
Lee C, Slade P, Lygo V. The influence of psychological debriefing on emotional adaptation in women following early miscarriage: a preliminary study. Br J Med Psychol. Mar. 1996;69(Pt 1):47-58. [pmid: 8829399].
Lester K, Resick PA, Young-Xu Y, et al. Impact of race on early treatment termination and outcomes in posttraumatic stress disorder treatment. J Consult Clin Psychol. Aug. 2010;78(4):480-9. [pmid: 20658805].
Lewis CC, Simons AD, Nguyen LJ, et al. Impact of childhood trauma on treatment outcome in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. Feb. 2010;49(2):132-40. [pmid: 20215935].
Lieberman AF, Ghosh Ippen C, VANH P. Child-parent psychotherapy: 6-month follow-up of a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2006;45(8):913-8. [pmid: 16865033].
Lieberman AF, Van Horn P, Ippen CG. Toward evidence-based treatment: child-parent psychotherapy with preschoolers exposed to marital violence. J Am Acad Child Adolesc Psychiatry. Dec. 2005;44(12):1241-8. [pmid: 16292115].
Lindon J, Nourse CA. A multi-dimensional model of groupwork for adolescent girls who have been sexually abused. Child Abuse Negl. Apr. 1994;18(4):341-8. [pmid: 8187019].
Livanou M, Basoglu M, Marks IM, et al. Beliefs, sense of control and treatment outcome in post-traumatic stress disorder. Psychol Med. Jan. 2002;32(1):157-65. [pmid: 11883725].
Lu DP. Using alternating bilateral stimulation of eye movement desensitization for treatment of fearful patients. Gen Dent. May-Jun. 2010;58(3):e140-7. [pmid: 20478792].
Macmillan HL. Preventive healthcare 2000 update: prevention of child maltreatment (Structured abstract). Canadian Medical Association Journal. 2000;(11):1451-8. DARE-12000008671. [pmid: 11192650].
Manassis K, Mendlowitz SL, Scapillato D, et al. Group and individual cognitive-behavioral therapy for childhood anxiety disorders. A randomized trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2002;41(12):1423-30. 2002-11435-018. First Author & Affiliation: Manassis, Katharina. [pmid: 12447028].
Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. Apr. 1998;55(4):317-25. [pmid: 9554427].
Martenyi F, Brown EB, Zhang H, et al. Fluoxetine v. placebo in prevention of relapse in post-traumatic stress disorder. Br J Psychiatry. Oct. 2002;181:315-20. [pmid: 12356658].
Mayou RA, Ehlers A, Hobbs M. Psychological debriefing for road traffic accident victims. Three-year follow-up of a randomised controlled trial. Br J Psychiatry. Jun. 2000;176:589-93. [pmid: 10974967].
McPherson J. Does Narrative Exposure Therapy Reduce PTSD in Survivors of Mass Violence?. Research on Social Work Practice. Jan. 2012;22(1):29-42. WOS:000298610700004.
McRae AL, Brady KT, Mellman TA, et al. Comparison of nefazodone and sertraline for the treatment of posttraumatic stress disorder. Depress Anxiety. 2004;19(3):190-6. [pmid: 15129422].
Melchers P, Maluck A, Suhr L, et al. An early onset rehabilitation program for children and adolescents after traumatic brain injury (TBI): Methods and first results. Restorative Neurology and Neuroscience. 1999;14(2-3):153-60. WOS:000079579700010. [pmid: 12671259].
Mello MF, Yeh MS, Barbosa Neto J, et al. A randomized, double-blind, placebo-controlled trial to assess the efficacy of topiramate in the treatment of post-traumatic stress disorder. BMC Psychiatry. 2009;9:28. [pmid: 19480669].
Melnyk BM, Alpert-Gillis L, Feinstein NF, et al. Creating opportunities for parent empowerment: program effects on the mental health/coping outcomes of critically ill young children and their mothers. Pediatrics. Jun. 2004;113(6):e597-607. [pmid: 15173543].
Mendelson T, Greenberg MT, Dariotis JK, et al. Feasibility and preliminary outcomes of a school-based mindfulness intervention for urban youth. J Abnorm Child Psychol. Oct. 2010;38(7):985-94. [pmid: 20440550].
Mendlowitz SL, Manassis K, Bradley S, et al. Cognitive-behavioral group treatments in childhood anxiety disorders: The role of parental involvement. Journal of the American Academy of Child & Adolescent Psychiatry. 1999;38(10):1223-9. 1999-01121-010. First Author & Affiliation: Mendlowitz, Sandra L. [pmid: 10517054].
Monaco A, Cozzolino V, Cattaneo R, et al. Osteopathic manipulative treatment (OMT) effects on mandibular kinetics: kinesiographic study. Eur J Paediatr Dent. Mar. 2008;9(1):37-42. [pmid: 18380529].
Muris P, Meesters C, van Melick M. Treatment of childhood anxiety disorders; A preliminary comparison between cognitive-behavioral group therapy and a psychological placebo intervention. Journal of Behavior Therapy and Experimental Psychiatry. 2002;33(3-4):143-58. 2003-03233-003. First Author & Affiliation: Muris, Peter. [pmid: 12628633].
Najavits LM, Gallop RJ, Weiss RD. Seeking safety therapy for adolescent girls with PTSD and substance use disorder: a randomized controlled trial. J Behav Health Serv Res. Oct. 2006;33(4):453-63. [pmid: 16858633].
Naranbhai V, Abdool Karim Q, Meyer-Weitz A. Interventions to modify sexual risk behaviours for preventing HIV in homeless youth. Cochrane Database of Systematic Reviews. 2011;(1). CD007501.
Nelson BJ, Weinert CR, Bury CL, et al. Intensive care unit drug use and subsequent quality of life in acute lung injury patients. Crit Care Med. Nov. 2000;28(11):3626-30. [pmid: 11098964].
Nemeroff CB, Heim CM, Thase ME, et al. Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. Nov. 25. 2003;100(24):14293-6. [pmid: 14615578].
Nijdam MJ, Gersons BP, Reitsma JB, et al. Brief eclectic psychotherapy v. eye movement desensitisation and reprocessing therapy for post-traumatic stress disorder: randomised controlled trial. Br J Psychiatry. Mar. 2012;200(3):224-31. [pmid: 22322458].
Noorthoorn EO, Havenaar JM, de Haan HA, et al. Mental health service use and outcomes after the Enschede fireworks disaster: a naturalistic follow-up study. Psychiatr Serv. Nov. 2010;61(11):1138-43. [pmid: 21041354].
Oates RK, Bross DC. What have we learned about treating child physical abuse? A literature review of the last decade. Child Abuse Negl. Apr. 1995;19(4):463-73. [pmid: 7606524].
Paivio SC, Jarry JL, Chagigiorgis H, et al. Efficacy of two versions of emotion-focused therapy for resolving child abuse trauma. Psychother Res. May. 2010;20(3):353-66. [pmid: 20099203].
Patel D, Meakin G. Oral midazolam compared with diazepam-droperidol and trimeprazine as premedicants in children. Paediatr Anaesth. 1997;7(4):287-93. [pmid: 9243685].
Phipps S, Barrera M, Vannatta K, et al. Complementary therapies for children undergoing stem cell transplantation: report of a multisite trial. Cancer. Aug. 15. 2010;116(16):3924-33. [pmid: 20626016].
Powers MB, Halpern JM, Ferenschak MP, et al. A meta-analytic review of prolonged exposure for posttraumatic stress disorder. Clin Psychol Rev. Aug. 2010;30(6):635-41. [pmid: 20546985].
Pywell CA, Hung YJ, Nagelhout J. Oral midazolam versus meperidine, atropine, and diazepam: a comparison of premedicants in pediatric outpatients. AANA J. Apr. 1995;63(2):124-30. [pmid: 7740908].
Ramchandani P, Jones DP. Treating psychological symptoms in sexually abused children: from research findings to service provision. Br J Psychiatry. Dec. 2003;183:484-90. [pmid: 14645018].
Reams R, Friedrich W. The efficacy of time-limited play therapy with maltreated preschoolers. J Clin Psychol. Nov. 1994;50(6):889-99. [pmid: 7896925].
Renfrey G, Spates CR. Eye movement desensitization: a partial dismantling study. J Behav Ther Exp Psychiatry. Sep. 1994;25(3):231-9. [pmid: 7852605].
Resnick H, Acierno R, Holmes M, et al. Prevention of post-rape psychopathology: preliminary findings of a controlled acute rape treatment study. J Anxiety Disord. Jul-Aug. 1999;13(4):359-70. [pmid: 10504107].
Resnick H, Acierno R, Waldrop AE, et al. Randomized controlled evaluation of an early intervention to prevent post-rape psychopathology. Behav Res Ther. Oct. 2007;45(10):2432-47. [pmid: 17585872].
Rice KG, Herman MA, Petersen AC. Coping with challenge in adolescence: a conceptual model and psycho-educational intervention. J Adolesc. Sep. 1993;16(3):235-51. [pmid: 8282896].
Richards DA, Lovell K, Marks IM. Post-traumatic stress disorder: evaluation of a behavioral treatment program. J Trauma Stress. Oct. 1994;7(4):669-80. [pmid: 7820356].
Rivard JC, Bloom SL, McCorkle D, et al. Preliminary results of a study examining the implementation and effects of a trauma recovery framework for youths in residential treatment. Therapeutic Communities. 2005;26(1):79-92. 2006-08528-008. First Author & Affiliation: Rivard, Jeanne C.
Robert R, Brack A, Blakeney P, et al. A double-blind study of the analgesic efficacy of oral transmucosal fentanyl citrate and oral morphine in pediatric patients undergoing burn dressing change and tubbing. J Burn Care Rehabil. Nov-Dec. 2003;24(6):351-5. [pmid: 14610417].
Rodenburg R, Benjamin A, de Roos C, et al. Efficacy of EMDR in children: a meta-analysis. Clin Psychol Rev. Nov. 2009;29(7):599-606. [pmid: 19616353].
Roelofse JA, Van der Bijl P, Moore PA. Comparison of rectal midazolam and diazepam for premedication in pediatric dental patients. Journal of Oral and Maxillofacial Surgery. 1993;51(5):525-9. [pmid: 8478759].
Rose S, Bisson JI, Churchill R, et al. Psychological debriefing for preventing post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2008;2008(2). Article Number CD000560.
Rose S, Bisson JI, Wessely SC. Psychological debriefing for preventing post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2001;2001(3).
Ross KA, Dorris L, McMillan T. A systematic review of psychological interventions to alleviate cognitive and psychosocial problems in children with acquired brain injury. Dev Med Child Neurol. Aug. 2011;53(8):692-701. [pmid: 21518345].
Ross MJ, Berger RS. Effects of stress inoculation training on athletes' postsurgical pain and rehabilitation after orthopedic injury. J Consult Clin Psychol. Apr. 1996;64(2):406-10. [pmid: 8871425].
Ruggiero KJ, Resnick HS, Acierno R, et al. Internet-based intervention for mental health and substance use problems in disaster-affected populations: a pilot feasibility study. Behav Ther. Jun. 2006;37(2):190-205. [pmid: 16942971].
Salazar AM, Keller TE, Courtney ME. Understanding social support's role in the relationship between maltreatment and depression in youth with foster care experience. Child Maltreat. May. 2011;16(2):102-13. [pmid: 21471145].
Sanchez-Meca J, Rosa-Alcazar AI, Lopez-Soler C. The psychological treatment of sexual abuse in children and adolescents: A meta-analysis. International Journal of Clinical and Health Psychology. Jan. 2011;11(1):67-93. WOS:000285571300005.
Sandler IN, Ayers TS, Wolchik SA, et al. The family bereavement program: efficacy evaluation of a theory-based prevention program for parentally bereaved children and adolescents. J Consult Clin Psychol. Jun. 2003;71(3):587-600. [pmid: 12795581].
Sandler IN, West SG, Baca L, et al. Linking empirically based theory and evaluation: the Family Bereavement Program. Am J Community Psychol. Aug. 1992;20(4):491-521. [pmid: 1481786].
Scheck MM, Schaeffer JA, Gillette C. Brief psychological intervention with traumatized young women: the efficacy of eye movement desensitization and reprocessing. J Trauma Stress. Jan. 1998;11(1):25-44. [pmid: 9479674].
Schley C, Ryall V, Crothers L, et al. Early intervention with difficult to engage, 'high-risk' youth: evaluating an intensive outreach approach in youth mental health. Early Interv Psychiatry. Aug. 2008;2(3):195-200. [pmid: 21352153].
Scholte WF, Verduin F, Kamperman AM, et al. The Effect on Mental Health of a Large Scale Psychosocial Intervention for Survivors of Mass Violence: A Quasi-Experimental Study in Rwanda. PLoS One. Aug. 2011;6(8). WOS:000293773300003.
Schreiber S, Dolberg OT, Barkai G, et al. Primary intervention for memory structuring and meaning acquisition (PIMSMA): study of a mental health first-aid intervention in the ED with injured survivors of suicide bombing attacks. Am J Disaster Med. Nov-Dec. 2007;2(6):307-20. [pmid: 18297951].
Seedat S, Stein DJ, Ziervogel C, et al. Comparison of response to a selective serotonin reuptake inhibitor in children, adolescents, and adults with posttraumatic stress disorder. J Child Adolesc Psychopharmacol. Spring. 2002;12(1):37-46. [pmid: 12014594].
Shakibaei F, Harandi AA, Gholamrezaei A, et al. Hypnotherapy in management of pain and reexperiencing of trauma in burn patients. Int J Clin Exp Hypn. Apr. 2008;56(2):185-97. [pmid: 18307128].
Shalev AY, Ankri Y, Israeli-Shalev Y, et al. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach And Prevention study. Arch Gen Psychiatry. Feb. 2012;69(2):166-76. [pmid: 21969418].
Shane P, Diamond GS, Mensinger JL, et al. Impact of victimization on substance abuse treatment outcomes for adolescents in outpatient and residential substance abuse treatment. Am J Addict. Suppl 1. 2006;15:34-42. [pmid: 17182418].
Sheese BE, Brown EL, Graziano WG. Emotional expression in cyberspace: searching for moderators of the Pennebaker disclosure effect via e-mail. Health Psychol. Sep. 2004;23(5):457-64. [pmid: 15367065].
Shibru D, Zahnd E, Becker M, et al. Benefits of a hospital-based peer intervention program for violently injured youth. J Am Coll Surg. Nov. 2007;205(5):684-9. [pmid: 17964444].
Shooshtary MH, Panaghi L, Moghadam JA. Outcome of cognitive behavioral therapy in adolescents after natural disaster. J Adolesc Health. May. 2008;42(5):466-72. [pmid: 18407041].
Short JL, Roosa MW, Sandler IN, et al. Evaluation of a preventive intervention for a self-selected subpopulation of children. Am J Community Psychol. Apr. 1995;23(2):223-47. [pmid: 7572831].
Shortt AL, Barrett PM, Fox TL. Evaluating the FRIENDS Program: A cognitive-behavioral group treatment for anxious children and their parents. Journal of Clinical Child Psychology. 2001;30(4):525-35. 2001-11979-008. First Author & Affiliation: Shortt, Alison L. [pmid: 11708240].
Sidhu R, Passmore A, Baker D. The effectiveness of a peer support camp for siblings of children with cancer. Pediatr Blood Cancer. Oct. 15. 2006;47(5):580-8. [pmid: 16317733].
Silovsky JF, Niec L, Bard D, et al. Treatment for preschool children with interpersonal sexual behavior problems: a pilot study. J Clin Child Adolesc Psychol. Jul-Sep. 2007;36(3):378-91. [pmid: 17658982].
Slesnick N, Prestopnik JL. Ecologically based family therapy outcome with substance abusing runaway adolescents. J Adolesc. Apr. 2005;28(2):277-98. [pmid: 15878048].
Sloan DM, Marx BP, Greenberg EM. A test of written emotional disclosure as an intervention for posttraumatic stress disorder. Behav Res Ther. Apr. 2011;49(4):299-304. [pmid: 21367400].
Soberman GB, Greenwald R, Rule DL. A controlled study of eye movement desensitization and reprocessing (EMDR) for boys with conduct problems. Journal of Aggression, Maltreatment and Trauma. 2002;6(1):217-36.
Sonderegger R, Rombouts S, Ocen B, et al. Trauma rehabilitation for war-affected persons in northern Uganda: a pilot evaluation of the EMPOWER programme. Br J Clin Psychol. 2011;50(3):234-49. [pmid: 21810104].
Sparks LA, Setlik J, Luhman J. Parental holding and positioning to decrease IV distress in young children: a randomized controlled trial. J Pediatr Nurs. Dec. 2007;22(6):440-7. [pmid: 18036464].
Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: The effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. Journal of Child Psychology and Psychiatry. 2000;41(6):713-26. 2000-00865-004. First Author & Affiliation: Spence, Susan H. [pmid: 11039684].
Stahmer AC, Hurlburt M, Horwitz SM, et al. Associations between intensity of child welfare involvement and child development among young children in child welfare. Child Abuse Negl. Sep. 2009;33(9):598-611. [pmid: 19818496].
Stein DJ, Pedersen R, Rothbaum BO, et al. Onset of activity and time to response on individual CAPS-SX17 items in patients treated for post-traumatic stress disorder with venlafaxine ER: a pooled analysis. Int J Neuropsychopharmacol. Feb. 2009;12(1):23-31. [pmid: 18544181].
Stein MB, Kerridge C, Dimsdale JE, et al. Pharmacotherapy to prevent PTSD: Results from a randomized controlled proof-of-concept trial in physically injured patients. J Trauma Stress. Dec. 2007;20(6):923-32. [pmid: 18157888].
Stevenson MD, Bivins CM, O'Brien K, et al. Child life intervention during angiocatheter insertion in the pediatric emergency department. Pediatr Emerg Care. Nov. 2005;21(11):712-8. [pmid: 16280943].
Stewart ME. Adolescents in a therapeutic community: treatment implications for teen survivors of traumatic experiences. J Psychoactive Drugs. Oct-Dec. 1994;26(4):409-19. [pmid: 7884603].
St-Onge M, Mercier P, De Koninck J. Imagery rehearsal therapy for frequent nightmares in children. Behav Sleep Med. 2009;7(2):81-98. [pmid: 19330581].
Streisand R, Rodrigue JR, Houck C, et al. Brief report: parents of children undergoing bone marrow transplantation: documenting stress and piloting a psychological intervention program. J Pediatr Psychol. Jul-Aug. 2000;25(5):331-7. [pmid: 10880063].
Sullivan PM, Scanlan JM, Brookhouser PE, et al. The effects of psychotherapy on behavior problems of sexually abused deaf children. Child Abuse Negl. 1992;16(2):297-307. [pmid: 1559177].
Swenson CC, Schaeffer CM, Henggeler SW, et al. Multisystemic Therapy for Child Abuse and Neglect: a randomized effectiveness trial. J Fam Psychol. Aug. 2010;24(4):497-507. [pmid: 20731496].
Taiwo B, Flowers M, Zoltie N. Reducing children's fear when undergoing painful procedures. Arch Emerg Med. Sep. 1992;9(3):306-9. [pmid: 1449578].
Tarnanas I, Manos GC. Using virtual reality to teach special populations how to cope in crisis: the case of a virtual earthquake. Stud Health Technol Inform. 2001;81:495-501. [pmid: 11317797].
Taussig HN. Risk behaviors in maltreated youth placed in foster care: a longitudinal study of protective and vulnerability factors. Child Abuse Negl. Nov. 2002;26(11):1179-99. [pmid: 12398855].
Taylor JE, Harvey ST. A meta-analysis of the effects of psychotherapy with adults sexually abused in childhood. Clin Psychol Rev. Aug. 2010;30(6):749-67. [pmid: 20579790].
Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three PTSD treatments: exposure therapy, EMDR, and relaxation training. J Consult Clin Psychol. Apr. 2003;71(2):330-8. [pmid: 12699027].
Taylor TL, Chemtob CM. Efficacy of treatment for child and adolescent traumatic stress. Arch Pediatr Adolesc Med. Aug. 2004;158(8):786-91. [pmid: 15289252].
Tecic T, Schneider A, Althaus A, et al. Early short-term inpatient psychotherapeutic treatment versus continued outpatient psychotherapy on psychosocial outcome: a randomized controlled trial in trauma patients. J Trauma. Feb. 2011;70(2):433-41. [pmid: 21057336].
Thies-Flechtner K, Muller-Oerlinghausen B, Seibert W, et al. Effect of prophylactic treatment on suicide risk in patients with major affective disorders. Data from a randomized prospective trial. Pharmacopsychiatry. May. 1996;29(3):103-7. [pmid: 8738314].
Timmer SG, Urquiza AJ, Zebell NM, et al. Parent-child interaction therapy: application to maltreating parent-child dyads. Child Abuse Negl. Jul. 2005;29(7):825-42. [pmid: 16051355].
Toth SL, Maughan A, Manly JT, et al. The relative efficacy of two interventions in altering maltreated preschool children's representational models: implications for attachment theory. Dev Psychopathol. Fall. 2002;14(4):877-908. [pmid: 12549708].
Tourigny M, Hebert M, Daigneault I, et al. Efficacy of a group therapy for sexually abused adolescent girls. J Child Sex Abus. 2005;14(4):71-93. [pmid: 16354649].
Trask EV, Walsh K, DiLillo D. Treatment effects for common outcomes of child sexual abuse: A current meta-analysis. Aggression and Violent Behavior. Jan-Feb. 2011;16(1):6-19. WOS:000288726100002. [pmid: 21603060].
Traut A, Kaminer D, Boshoff D, et al. Treatment utilisation and trauma characteristics of child and adolescent inpatients with posttraumatic stress disorder. Curationis. Aug. 2003;26(2):44-8. [pmid: 14596133].
Trivedi MH, Wisniewski SR, Morris DW, et al. Concise Associated Symptoms Tracking scale: a brief self-report and clinician rating of symptoms associated with suicidality. J Clin Psychiatry. Jun. 2011;72(6):765-74. [pmid: 21733477].
Trowell J, Kolvin I, Weeramanthri T, et al. Psychotherapy for sexually abused girls: psychopathological outcome findings and patterns of change. Br J Psychiatry. Mar. 2002;180:234-47. [pmid: 11872516].
Tsai CC, Friedmann E, Thomas SA. The effect of animal-assisted therapy on stress responses in hospitalized children. Anthrozoös. 2010;23(3):245-58. 2010-17399-004. First Author & Affiliation: Tsai, Chia-Chun.
Tucker P, Beebe KL, Burgin C, et al. Paroxetine treatment of depression with posttraumatic stress disorder: effects on autonomic reactivity and cortisol secretion. J Clin Psychopharmacol. Apr. 2004;24(2):131-40. [pmid: 15206659].
Turner W, Macdonald GM, Dennis JA. Cognitive-behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. 2007;(1):CD003760. [pmid: 17253496].
van der Kolk BA, Spinazzola J, Blaustein ME, et al. A randomized clinical trial of eye movement desensitization and reprocessing (EMDR), fluoxetine, and pill placebo in the treatment of posttraumatic stress disorder: treatment effects and long-term maintenance. The Journal of clinical psychiatry. 2007;(1):37-46. CN-00575205. [pmid: 17284128].
Van Emmerik AAP, Kamphuis JH, Hulsbosch AM, et al. Single session debriefing after psychological trauma: A meta-analysis. Lancet. 2002;360(9335):766-71. [pmid: 12241834].
van Minnen A, Arntz A, Keijsers GP. Prolonged exposure in patients with chronic PTSD: predictors of treatment outcome and dropout. Behav Res Ther. Apr. 2002;40(4):439-57. [pmid: 12002900].
Veerkamp JS, Gruythuysen RJ, Hoogstraten J, et al. Dental treatment of fearful children using nitrous oxide. Part 4: Anxiety after two years. ASDC J Dent Child. Nov-Dec. 1993;60(4):372-6. [pmid: 8126300].
Wade SL, Michaud L, Brown TM. Putting the pieces together: preliminary efficacy of a family problem-solving intervention for children with traumatic brain injury. J Head Trauma Rehabil. Jan-Feb. 2006;21(1):57-67. [pmid: 16456392].
Walton E. Enhancing investigative decisions in child welfare: an exploratory use of intensive family preservation services. Child Welfare. May-Jun. 1997;76(3):447-61. [pmid: 9130381].
Weaver TL, Clum GA. PSYCHOLOGICAL DISTRESS ASSOCIATED WITH INTERPERSONAL VIOLENCE - A METAANALYSIS. Clinical Psychology Review. 1995;15(2):115-40. WOS:A1995QX61700003.
Wethington HR, Hahn RA, Fuqua-Whitley DS, et al. The effectiveness of interventions to reduce psychological harm from traumatic events among children and adolescents: a systematic review. Am J Prev Med. Sep. 2008;35(3):287-313. [pmid: 18692745].
Wolchik SA, Sandler IN, Millsap RE, et al. Six-year follow-up of preventive interventions for children of divorce: a randomized controlled trial. JAMA. Oct. 16. 2002;288(15):1874-81. [pmid: 12377086].
Wolchik SA, West SG, Westover S, et al. The children of divorce parenting intervention: outcome evaluation of an empirically based program. Am J Community Psychol. Jun. 1993;21(3):293-31. [pmid: 8311029].
Yanos PT, Czaja SJ, Widom CS. A prospective examination of service use by abused and neglected children followed up into adulthood. Psychiatr Serv. Aug. 2010;61(8):796-802. [pmid: 20675838].
Zhang Y, Feng B, Xie JP, et al. Clinical study on treatment of the earthquake-caused post-traumatic stress disorder by cognitive-behavior therapy and acupoint stimulation. J Tradit Chin Med. Mar. 2011;31(1):60-3. [pmid: 21563510].
Zhou Q, Sandler IN, Millsap RE, et al. Mother-child relationship quality and effective discipline as mediators of the 6-year effects of the New Beginnings Program for children from divorced families. J Consult Clin Psychol. Aug. 2008;76(4):579-94. [pmid: 18665687].
Zsigmond EK, Kovacs V, Fekete G. A new route, jet-injection for anesthetic induction in children: I. Midazolam dose-range finding studies. Int J Clin Pharmacol Ther. Oct. 1995;33(10):580-4. [pmid: 8574511].
Zucker TL, Samuelson KW, Muench F, et al. The effects of respiratory sinus arrhythmia biofeedback on heart rate variability and posttraumatic stress disorder symptoms: a pilot study. Appl Psychophysiol Biofeedback. Jun. 2009;34(2):135-43. [pmid: 19396540].
Zun LS, Downey L, Rosen J. The effectiveness of an ED-based violence prevention program. Am J Emerg Med. Jan. 2006;24(1):8-13. [pmid: 16338502].

## Excluded for Wrong or No Intervention

Graham-Bermann SA, Kulkarni MR, Kanukollu SN. Is disclosure therapeutic for children following exposure to traumatic violence?. J Interpers Violence. Mar. 2011;26(5):1056-76. [pmid: 20448228].
Loughry M, Ager A, Flouri E, et al. The impact of structured activities among Palestinian children in a time of conflict. Journal of child psychology and psychiatry, and allied disciplines. Dec. 2006;47(12):1211-8. [pmid: 17176376].
Peltonen K, Punamaki RL. Preventive interventions among children exposed to trauma of armed conflict: a literature review. Aggress Behav. Mar-Apr. 2010;36(2):95-116. [pmid: 19998393].
Qouta S, Punamaki RL, el Sarraj E. The impact of the peace treaty on psychological well-being: a follow-up study of Palestinian children. Child Abuse Negl. Oct. 1995;19(10):1197-208. [pmid: 8556434].
Salloum A, Avery L, McClain RP. Group psychotherapy for adolescent survivors of homicide victims: a pilot study. J Am Acad Child Adolesc Psychiatry. Nov. 2001;40(11):1261-7. [pmid: 11699799].
Shahar G, Cohen G, Grogan KE, et al. Terrorism-related perceived stress, adolescent depression, and social support from friends. Pediatrics. Aug. 2009;124(2):e235-40. [pmid: 19596732].
Sourander A, Ronning J, Brunstein-Klomek A, et al. Childhood bullying behavior and later psychiatric hospital and psychopharmacologic treatment: findings from the Finnish 1981 birth cohort study. Arch Gen Psychiatry. Sep. 2009;66(9):1005-12. [pmid: 19736357].
Stinson J, Wilson R, Gill N, et al. A systematic review of internet-based self-management interventions for youth with health conditions (Structured abstract). Journal of Pediatric Psychology. 2009;(5):495-510. DARE-12009107789. [pmid: 19029142].

## Excluded for Wrong or No Comparator

Aderka IM, Appelbaum-Namdar E, Shafran N, et al. Sudden Gains in Prolonged Exposure for Children and Adolescents With Posttraumatic Stress Disorder. Journal of consulting and clinical psychology. Aug. 2011;79(4):441-6. WOS:000293376900003. [pmid: 21787047].
Cox J, Davies DR, Burlingame GM, et al. Effectiveness of a trauma/grief-focused group intervention: a qualitative study with war-exposed Bosnian adolescents. Int J Group Psychother. Jul. 2007;57(3):319-45. [pmid: 17661546].
Goodkind JR, Lanoue MD, Milford J. Adaptation and implementation of cognitive behavioral intervention for trauma in schools with American Indian youth. J Clin Child Adolesc Psychol. 2010;39(6):858-72. [pmid: 21058132].
Gupta L, Zimmer C. Psychosocial intervention for war-affected children in Sierra Leone. Br J Psychiatry. Mar. 2008;192(3):212-6. [pmid: 18310582].
Hermenau K, Hecker T, Ruf M, et al. Childhood adversity, mental ill-health and aggressive behavior in an African orphanage: Changes in response to trauma-focused therapy and the implementation of a new instructional system. Child and Adolescent Psychiatry and Mental Health. 2011;5.
Kagan R, Douglas AN, Hornik J, et al. Real Life Heroes Pilot Study: Evaluation of a Treatment Model for Children with Traumatic Stress. Journal of Child & Adolescent Trauma. 2008;1(1):5-22.
Kiser LJ, Donohue A, Hodgkinson S, et al. Strengthening family coping resources: the feasibility of a multifamily group intervention for families exposed to trauma. J Trauma Stress. Dec. 2010;23(6):802-6. [pmid: 21105068].
Kramer DN, Landolt MA. Characteristics and efficacy of early psychological interventions in children and adolescents after single trauma: a meta-analysis. European journal of psychotraumatology. 2011:2.
Morsette A, van den Pol R, Schuldberg D, et al. Cognitive behavioral treatment for trauma symptoms in American Indian youth: preliminary findings and issues in evidence-based practice and reservation culture. Advances in School Mental Health Promotion. 2012/01/01. 2012;5(1):51-62.
Onyut LP, Neuner F, Schauer E, et al. Narrative Exposure Therapy as a treatment for child war survivors with posttraumatic stress disorder: two case reports and a pilot study in an African refugee settlement. BMC Psychiatry. 2005;5:7. [pmid: 15691374].
Opie ND, Goodwin T, Finke LM, et al. The effect of a bereavement group experience on bereaved children's and adolescents' affective and somatic distress. Journal of child and adolescent psychiatric and mental health nursing. 1992;5(1):20-6. [pmid: 1432583].
Oras R, de Ezpeleta SC, Ahmad A. Treatment of traumatized refugee children with Eye Movement Desensitization and Reprocessing in a psychodynamic context. Nord J Psychiatry. 2004;58(3):199-203. [pmid: 15204206].
Salloum A. Group therapy for children after homicide and violence: A pilot study. Research on Social Work Practice. May. 2008;18(3):198-211. WOS:000254983900003.
Saltzman WR, Pynoos RS, Layne CM, et al. School-based trauma and grief intervention for adolescents. The Prevention Researcher. 2003;10(2):8-11.
Saxe GN, Ellis BH, Fogler J, et al. Innovations in practice: Preliminary evidence for effective family engagement in treatment for child traumatic stress–trauma systems therapy approach to preventing dropout. Child and Adolescent Mental Health. 2012;17(1):58-61. 2011-30029-009.
Saxe GN, Ells H, Fogler J, et al. Comprehensive care for traumatized children. Psychiatric Annals. May. 2005;35(5):443-8. WOS:000229100900014.
Weiner DA, Schneider A, Lyons JS. Evidence-based treatments for trauma among culturally diverse foster care youth: Treatment retention and outcomes. Children and Youth Services Review. Nov. 2009;31(11):1199-205. ISI:000271799100008.

## Excluded for Wrong or No Outcome

Adams KN. Bereavement counseling groups with elementary school students [9607156]. United States -- Florida. University of Florida. 1994.
Blakeney P, Thomas C, Holzer C 3rd, et al. Efficacy of a short-term, intensive social skills training program for burned adolescents. J Burn Care Rehabil. Nov-Dec. 2005;26(6):546-55. [pmid: 16278574].
Carbonell DM, Parteleno-Barehmi C. Psychodrama groups for girls coping with trauma. International journal of group psychotherapy. 1999;49(3):285-306. [pmid: 10390940].
Cooley-Strickland MR, Griffin RS, Darney D, et al. Urban African American youth exposed to community violence: a school-based anxiety preventive intervention efficacy study. J Prev Interv Community. Apr. 2011;39(2):149-66. [pmid: 21480032].
Currier JM, Holland JM, Neimeyer RA. The effectiveness of bereavement interventions with children: a meta-analytic review of controlled outcome research. J Clin Child Adolesc Psychol. Apr-Jun. 2007;36(2):253-9. [pmid: 17484697].
De Vos E, Stone DA, Goetz MA, et al. Evaluation of a hospital-based youth violence intervention. Am J Prev Med. Sep-Oct. 1996;12(5 Suppl):101-8. [pmid: 8909630].
Dybdahl R. Children and mothers in war: an outcome study of a psychosocial intervention program. Child Dev. Jul-Aug. 2001;72(4):1214-30. [pmid: 11480943].
Hilliard RE. The effects of music therapy-based bereavement groups on mood and behavior of grieving children: A pilot study. Journal of Music Therapy. 2001;38(4):291-306. 2002-10829-003. First Author & Affiliation: Hilliard, Russell E. [pmid: 11796079].
Hilliard RE. The effects of orff-based music therapy and social work groups on childhood grief symptoms and behaviors. J Music Ther. Summer. 2007;44(2):123-38. [pmid: 17488174].
Housley PC. Effectiveness of grief support groups for children [9722309]. United States -- Colorado. University of Northern Colorado. 1996.
Huss SN. The effect of peer bereavement support groups on the self-esteem, depression, and problem behavior of parentally bereaved children [9729145]. United States -- Ohio. The University of Toledo. 1997.
Kataoka S, Jaycox LH, Wong M, et al. Effects on school outcomes in low-income minority youth: preliminary findings from a community-partnered study of a school-based trauma intervention. Ethn Dis. 2011;21(3 Suppl 1):S1-71-7. [pmid: 22352083].
Kumakech E, Cantor-Graae E, Maling S, et al. Peer-group support intervention improves the psychosocial well-being of AIDS orphans: cluster randomized trial. Social science & medicine (1982). 2009;(6):1038-43. CN-00682459.
Tonkins SAM, Lambert MJ. A treatment outcome study of bereavement groups for children. Child and Adolescent Social Work Journal. 1996;13(1):3-21. 64570.
Wilson DL. An outcome study of a time-limited group intervention program for bereaved children [9512796]. United States -- Washington. Washington State University. 1994.
Zebrowski CA. Bereaved African-American children at risk: Testing an intervention [9969841]. United States -- District of Columbia. The George Washington University. 2000.