# Abstract and Full-Text Forms

The following are lists of fields used in the abstract and full text review forms. Please see the Evidence Tables (Appendix D) for fields used in the data abstraction forms.

Reviewers were asked to complete the following fields for screening abstracts for inclusion:

Ref ID
Year
Title
Journal
Abstract
Exclusion Code (list of options is provided below): | 1-Wrong publication type
| 2-Wrong study design
| 3-Wrong population
| 4-Wrong or no intervention
| 5-Wrong or no comparator
| 6-Wrong or no outcome
Inclusion
If include, enter sample size.
Bkg
Reviewer 1 (Initials)
Reviewer 2 (Initials)
Comments

Reviewers were asked to consider and complete the following fields when reviewing full texts for inclusion:

Reviewer Initials
Ref ID
Author
Year
Article Title
Study/Trial Name (if applicable)
Include/Exclude Codes | INCLUDE
| Exc1: Publication type
| Exc2: Study design
| Exc3: Population
| Exc4: Wrong or no intervention
| Exc5: Wrong or no comparator
| Exc6: Wrong or no outcome
| Exc7: Sample size N<10
Study Design | RCT
| NRCT
| SysRev / M-A
| Prosp cohort
| Nested case-control
Interventions: Symptom Prevention: | Psychological | CBT
| | TF-CBT
| | CPP
| | STAIR/NST
| | TGCT
| | CBITS
| Pharmacological | Morphine
| | Clonidine
| | Other (specify in comments)
| CAM | Equine-assisted psychotherapy
| | Other (specify in comments)
| Other (e.g., Web; systems level)
Interventions: Symptom Treatment | Psychological | DBT
| | SPARCS
| | PCIT
| | EMDR
| Pharmacological | SSRIs
| | Bupropion
| | Venlafaxine
| | Mirtazapine
| | Imipramine
| | MAOIS
| | Stimulants (specify in comments)
| | Antipsychotics (specify in comments)
| | Benzodiazepines (specify in comments)
| | Other (specify in comments)
| CAM | Equine-assisted psychotherapy
| | Other (specify in comments)
| Other (e.g., Web; systems level)
KQs: Mark X in cell(s) | 1
| 2
| 3a
| 3b
| 3c
| 4
Comments
Companion or Parent Study Articles
BKG (‘X’): Use only if article is excluded