# Search Strategy

## Initial Search

We performed the initial searches on October 7, 2011.

PubMed

Search | Queries | Result
#1 | Search “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 21143
#2 | Search “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 204776
#3 | Search “Social Problems/psychology”[Mesh] | 38563
#4 | Search “Life Change Events”[Mesh] | 16956
#5 | Search “Stress, Psychological”[Mesh] | 76655
#6 | Search “Wounds and Injuries/psychology”[Mesh] | 12642
#7 | Search “Disasters”[Mesh] | 53414
#8 | Search “Child Abuse”[Mesh:NoExp] | 15267
#9 | Search “survival/psychology”[Mesh] | 365
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 | 394477
#11 | Search “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 2556949
#12 | Search #10 AND #11 | 114458
#13 | Search #12 Limits: Humans, English, Publication Date from 1990/01/01 to 2011/10/01 | 73765
#14 | Search “Psychotherapy”[Mesh] | 134281
#15 | Search “Complementary Therapies”[Mesh] | 151648
#16 | Search “Mental Health Services”[Mesh] | 65842
#17 | Search “Therapeutics/psychology”[Mesh] | 40809
#18 | Search (therapy[tiab] OR therapies[tiab]) AND (“school”[tiab] OR “classroom”[tiab]) | 4818
#19 | Search “Adaptation, Psychological”[Mesh] | 88217
#20 | Search #13 AND (#14 OR #15 OR #16 OR #17 OR #18 OR #19) | 10452
#21 | Search “Psychotropic Drugs”[Mesh] | 115148
#22 | Search “Antidepressive Agents”[Pharmacological Action] | 109847
#23 | Search “Monoamine Oxidase Inhibitors”[Pharmacological Action] | 18997
#24 | Search “Anticonvulsants”[Pharmacological Action] | 120327
#25 | Search “Adrenergic Agents”[Pharmacological Action] | 301992
#26 | Search “Antipsychotic Agents”[Pharmacological Action] | 114700
#27 | Search “Tranquilizing Agents”[Pharmacological Action] | 168833
#28 | Search “Benzodiazepines”[MeSH] | 54555
#29 | Search “Opiate Alkaloids”[Mesh] | 69666
#30 | Search “Anesthetics, Dissociative”[Pharmacological Action] | 8346
#31 | Search #13 AND (#21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30) | 1526
#32 | Search #20 OR #31 | 11742
#33 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 457269
#34 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 50439
#35 | Search “Comparative Study”[Publication Type] OR “comparative study” | 1550017
#36 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 43153
#37 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] OR “Case-Control Studies”[Mesh] | 1292585
#38 | Search #32 AND (#33 OR #34 OR #35 OR #36 OR #37) | 3835

Cochrane Database

ID | Search | Hits
#1 | “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 1215
#2 | “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 9379
#3 | “Social Problems/psychology”[Mesh] | 2
#4 | “Life Change Events”[Mesh] | 381
#5 | “Stress, Psychological”[Mesh] | 2932
#6 | “Wounds and Injuries/psychology”[Mesh] | 33
#7 | “Disasters”[Mesh] | 103
#8 | “Child Abuse”[Mesh:NoExp] | 512
#9 | “survival/psychology”[Mesh] | 4
#10 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9) | 13130
#11 | “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 119851
#12 | (#10 AND #11) | 3662
#13 | (#12), from 1990 to 2011 | 3312
#14 | “Psychotherapy”[Mesh] | 6422
#15 | “Complementary Therapies”[Mesh] | 791
#16 | “Mental Health Services”[Mesh] | 1380
#17 | “Therapeutics/psychology”[Mesh] | 1
#18 | (therapy[tiab] OR therapies[tiab]) AND (“school”[tiab] OR “classroom”[tiab]) | 28136
#19 | “Adaptation, Psychological”[Mesh] | 2611
#20 | (#13 AND ( #14 OR #15 OR #16 OR #17 OR #18 OR #19 )) | 806
#21 | “Psychotropic Drugs”[Mesh] | 658
#22 | “Antidepressive Agents”[Pharmacological Action] | 4456
#23 | “Monoamine Oxidase Inhibitors”[Pharmacological Action] | 546
#24 | “Anticonvulsants”[Pharmacological Action] | 2077
#25 | “Adrenergic Agents”[Pharmacological Action] | 142
#26 | “Antipsychotic Agents”[Pharmacological Action] | 3311
#27 | “Tranquilizing Agents”[Pharmacological Action] | 530
#28 | “Benzodiazepines”[MeSH] | 2858
#29 | “Opiate Alkaloids”[Mesh] | 3
#30 | “Anesthetics, Dissociative”[Pharmacological Action] | 255
#31 | (#13 AND ( #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 )) | 96
#32 | (#20 OR #31) | 859
#33 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 350440
#34 | “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 18058
#35 | “Comparative Study”[Publication Type] OR “comparative study” | 138001
#36 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 28267
#37 | “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] OR “Case-Control Studies”[Mesh] | 20840
#38 | (#32 AND ( #33 OR #34 OR #35 OR #36 OR #37 )) | 763
#39 | “Humans”[Mesh] in Cochrane Reviews, Other Reviews, Clinical Trials, Methods Studies, Technology Assessments and Economic Evaluations | 419685
#40 | (#38 AND #39) | 703

EMBASE

No | Query | Results
#1 | ‘posttraumatic stress disorder’/exp OR ‘acute stress disorder’/exp | 26,326
#2 | ‘psychiatric treatment’/exp | 251,511
#3 | #1 AND #2 | 5,519
#4 | #3 AND ‘human’/de AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) | 4,154
#5 | ‘adolescent’/exp OR ‘child’/exp OR ‘newborn’/exp | 2,555,988
#6 | #4 AND #5 | 673

PsycINFO, CINAHL, IPA

# | Query | Results
S9 | S8 Limiters - Published Date from: 19900101-20111031; Publication Year from: 1990-2011; English; Language: English; Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2-23 mo), Preschool Age (2-5 yrs), School Age (6-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Exclude Dissertations; English Language; Exclude MEDLINE records; Language: English; Age Groups: Infant, Newborn: birth-1 month, Infant: 1-23 months, Child, Preschool: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years, All Infant, All Child; Language: English; Articles about Human Studies Search modes - Boolean/Phrase | 259
S8 | S5 or S7 | 2523
S7 | S4 and S6 | 1646
S6 | DE “Drug Therapy” | 94763
S5 | S1 and S4 | 889
S4 | S2 or S3 | 160444
S3 | “Posttraumatic Stress Disorder” OR DE “Reactive Psychosis” OR DE “Stress Reactions” OR DE “Psychological Stress” OR DE “Acute Stress Disorder” OR DE “Emotional Trauma” | 44624
S2 | “Injuries” OR DE “Burns” OR DE “Electrical Injuries” OR DE “Head Injuries” OR DE “Spinal Cord Injuries” OR DE “Wounds” | 117260
S1 | DE “Psychotherapeutic Techniques” OR DE “Animal Assisted Therapy” OR DE “Autogenic Training” OR DE “Cotherapy” OR DE “Dream Analysis” OR DE “Ericksonian Psychotherapy” OR DE “Guided Imagery” OR DE “Mirroring” OR DE “Morita Therapy” OR DE “Motivational Interviewing” OR DE “Mutual Storytelling Technique” OR DE “Paradoxical Techniques” OR DE “Psychodrama” | 25614

Web of Science (ISI)

Set | Results | Query
# 12 | 384 | #11 AND #7 AND #6 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 11 | 214,119 | #10 OR #9 OR #8 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 10 | 5,864 | Topic=(Psychotherapeutic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 9 | 40,901 | Topic=(Psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 8 | 170,421 | Topic=(drug therapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 7 | 849,415 | Topic=(child) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 6 | 40,897 | #5 OR #4 OR #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 32,295 | TS=(PTSD) OR TS=(posttraumatic) OR TS=(“stress disorder”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 2,633 | Topic=(Emotional Trauma) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 7,579 | Topic=(traumatic event) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 5,407 | Topic=(childhood trauma) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 1 | 403 | TS=(“acute stress disorder”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On

Number of records after duplicates removed: 5,990

## Update Search

We performed update searches from July 31 – August 1, 2012.

PubMed: 31 July – 1 August 2012

Search | Queries | Result
#1 | Search “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 22765
#2 | Search “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 215530
#3 | Search “Social Problems/psychology”[Mesh] | 40603
#4 | Search “Life Change Events”[Mesh] | 17615
#5 | Search “Stress, Psychological”[Mesh] | 80968
#6 | Search “Wounds and Injuries/psychology”[Mesh] | 13381
#7 | Search “Disasters”[Mesh] | 55082
#8 | Search “Child Abuse”[Mesh:NoExp] | 15808
#9 | Search “Survival/psychology”[Mesh] | 379
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 | 413713
#11 | Search “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 2638499
#12 | Search #10 AND #11 | 119610
#13 | Search #10 AND #11 Filters: Humans | 119059
#14 | Search #10 AND #11 Filters: Humans; English | 99843
#15 | Search #10 AND #11 Filters: Publication date from 1990/01/01 to 2012/12/31; Humans; English | 78503
#16 | Search “Psychotherapy”[Mesh] | 138671
#17 | Search “Complementary Therapies”[Mesh] | 159377
#18 | Search “Mental Health Services”[Mesh] | 68208
#19 | Search “Therapeutics/psychology”[Mesh] | 43216
#20 | Search (therapy[tiab] OR therapies[tiab]) AND (“school”[tiab] OR “classroom”[tiab]) | 5073
#21 | Search “Adaptation, Psychological”[Mesh] | 92153
#22 | Search #15 AND (#16 or #17 or #18 or #19 or #20 or #21) | 11096
#23 | Search “Psychotropic Drugs”[Mesh] | 119162
#24 | Search “Antidepressive Agents”[Pharmacological Action] | 112776
#25 | Search “Monoamine Oxidase Inhibitors”[Pharmacological Action] | 19226
#26 | Search “Anticonvulsants”[Pharmacological Action] | 123086
#27 | Search “Adrenergic Agents”[Pharmacological Action] | 306352
#28 | Search “Antipsychotic Agents”[Pharmacological Action] | 116968
#29 | Search “Tranquilizing Agents”[Pharmacological Action] | 171777
#30 | Search “Benzodiazepines”[MeSH] | 55585
#31 | Search “Opiate Alkaloids”[Mesh] | 71025
#32 | Search “Anesthetics, Dissociative”[Pharmacological Action] | 8666
#33 | Search #15 AND (#23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32) | 1590
#34 | Search #22 or #33 | 12433
#35 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 482202
#36 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 57226
#37 | Search “Comparative Study”[Publication Type] OR “comparative study” | 1594025
#38 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 49862
#39 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] OR “Case-Control Studies”[Mesh] | 1377387
#40 | Search #34 AND (#35 or #36 or #37 or #38 or #39) | 4074
#41 | Search #40 AND (2011/09:2012/07[edat]) | 108

Cochrane database: 31 July 2012

ID | Search | Hits
#1 | “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 1304
#2 | “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 10124
#3 | “Social Problems/psychology”[Mesh] | 2
#4 | “Life Change Events”[Mesh] | 392
#5 | “Stress, Psychological”[Mesh] | 3096
#6 | “Wounds and Injuries/psychology”[Mesh] | 34
#7 | “Disasters”[Mesh] | 113
#8 | “Child Abuse”[Mesh:NoExp] | 540
#9 | “Survival/psychology”[Mesh] | 4
#10 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9) | 14061
#11 | “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 124150
#12 | (#10 AND #11) | 4017
#13 | (#12), from 1990 to 2012 | 3667
#14 | “Psychotherapy”[Mesh] | 6822
#15 | “Complementary Therapies”[Mesh] | 933
#16 | “Mental Health Services”[Mesh] | 1500
#17 | “Therapeutics/psychology”[Mesh] | 1
#18 | (therapy[tiab] OR therapies[tiab]) AND (“school”[tiab] OR “classroom”[tiab]) | 27752
#19 | “Adaptation, Psychological”[Mesh] | 2724
#20 | (#13 AND ( #14 OR #15 OR #16 OR #17 OR #18 OR #19 )) | 943
#21 | “Psychotropic Drugs”[Mesh] | 765
#22 | “Antidepressive Agents”[Pharmacological Action] | 4622
#23 | “Monoamine Oxidase Inhibitors”[Pharmacological Action] | 571
#24 | “Anticonvulsants”[Pharmacological Action] | 2213
#25 | “Adrenergic Agents”[Pharmacological Action] | 150
#26 | “Antipsychotic Agents”[Pharmacological Action] | 3464
#27 | “Tranquilizing Agents”[Pharmacological Action] | 532
#28 | “Benzodiazepines”[MeSH] | 3035
#29 | “Opiate Alkaloids”[Mesh] | 3
#30 | “Anesthetics, Dissociative”[Pharmacological Action] | 265
#31 | (#13 AND ( #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 )) | 145
#32 | (#20 OR #31) | 1015
#33 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 364044
#34 | “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 20632
#35 | “Comparative Study”[Publication Type] OR “comparative study” | 142717
#36 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 34190
#37 | “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] OR “Case-Control Studies”[Mesh] | 22819
#38 | (#32 AND ( #33 OR #34 OR #35 OR #36 OR #37 )) | 922
#39 | “Humans”[Mesh] in Cochrane Reviews, Other Reviews, Trials, Methods Studies, Technology Assessments and Economic Evaluations | 435462
#40 | (#38 AND #39) | 853
#41 | (#40), from 2011 to 2012 | 165

EMBASE: 1 August 2012

No. | Query | Results
#7 | #6 AND [1-9-2011]/sd NOT [1-8-2012]/sd | 39
#6 | #4 AND #5 | 709
#5 | ‘adolescent’/exp OR ‘child’/exp OR ‘newborn’/exp | 2,698,263
#4 | #3 AND ‘human’/exp AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) | 4,337
#3 | #1 AND #2 | 5,998
#2 | ‘psychiatric treatment’/exp | 262,802
#1 | ‘posttraumatic stress disorder’/exp OR ‘acute stress disorder’/exp | 29,172

PsycINFO, CINAHL, IPA: 1 August 2012

No. | Query | Results
S10 | S9 | 6
S9 | S8 | 262
S8 | S5 or S7 | 2653
S7 | S4 and S6 | 1748
S6 | DE “Drug Therapy” | 100284
S5 | S1 and S4 | 918
S4 | S2 or S3 | 171392
S3 | “Posttraumatic Stress Disorder” OR DE “Reactive Psychosis” OR DE “Stress Reactions” OR DE “Psychological Stress” OR DE “Acute Stress Disorder” OR DE “Emotional Trauma” | 47150
S2 | “Injuries” OR DE “Burns” OR DE “Electrical Injuries” OR DE “Head Injuries” OR DE “Spinal Cord Injuries” OR DE “Wounds” | 125794
S1 | DE “Psychotherapeutic Techniques” OR DE “Animal Assisted Therapy” OR DE “Autogenic Training” OR DE “Cotherapy” OR DE “Dream Analysis” OR DE “Ericksonian Psychotherapy” OR DE “Guided Imagery” OR DE “Mirroring” OR DE “Morita Therapy” OR DE “Motivational Interviewing” OR DE “Mutual Storytelling Technique” OR DE “Paradoxical Techniques” OR DE “Psychodrama” | 26508

Web of Science (ISI): 1 August 2012

Set | Results | Query
# 1 | 430 | TS=(“acute stress disorder”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 5,969 | TS=(childhood trauma) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 8,303 | TS=(traumatic event) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 2,908 | TS=(emotional trauma) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 35,170 | TS=(PTSD) OR TS=(posttraumatic) OR TS=(“stress disorder”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 6 | 44,540 | #5 OR #4 OR #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 7 | 900,200 | TS=(child) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 8 | 184,616 | TS=(drug therapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 9 | 42,555 | TS=(psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 10 | 6,136 | TS=(psychotherapeutic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 11 | 230,032 | #10 OR #9 OR #8 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 12 | 425 | #11 AND #7 AND #6 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 13 | 368 | (#12) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 14 | 56 | (#13) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011-2012 Lemmatization=On

PILOTS database: 31 July 2012

No | Queries
#2 | Search Query #2 DE=(“adolescents” or “children”) 7322 Published Works results found in PILOTS Database Date Range: Earliest to Current
#3 | Search Query #3 DE=“ptsd” 26897 Published Works results found in PILOTS Database Date Range: Earliest to Current
#4 | Search Query #4 DE=“prevention” 1482 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#5 | Search Query #5 (DE=(“adolescents” or “children”)) and(DE=“ptsd”) and(DE=“prevention”) 117 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#6 | Search Query #6 42225 Published Works results found in PILOTS Database Date Range: 1990 to 2012 Limited to:
#7 | Search Query #7 (DE=(“adolescents” or “children”)) and(DE=“ptsd”) and(DE=“prevention”) 117 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#9 | Search Query #9 (DE=(“adolescents” or “children”)) and(DE=“ptsd”) and(DE=“prevention”) 117 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:

Number of records after duplicates removed: 483

## Revised Search

We performed revised searches from July 31 – 3, 2012.

PubMed: 2 August 2012

Search | Queries | Result
#1 | Search “Stress Disorders, Traumatic”[Mesh] OR “PTSD”[tiab] OR “post-traumatic stress disorders”[tiab] OR “post-traumatic stress disorder”[tiab] OR “posttraumatic stress disorders”[tiab] OR “posttraumatic stress disorder”[tiab] | 22782
#2 | Search “Traumatizing”[tiab] OR “Traumatising”[tiab] OR “Trauma”[tiab] OR “Traumatic”[tiab] OR “Traumas”[tiab] OR “Traumatization”[tiab] OR “Traumatisation”[tiab] OR “Traumatized”[tiab] OR “Traumatised”[tiab] OR “peritraumatic”[tiab] | 215654
#3 | Search “Social Problems/psychology”[Mesh] | 40620
#4 | Search “Life Change Events”[Mesh] | 17621
#5 | Search “Stress, Psychological”[Mesh] | 81015
#6 | Search “Wounds and Injuries/psychology”[Mesh] | 13385
#7 | Search “Disasters”[Mesh] | 55094
#8 | Search “Child Abuse”[Mesh:NoExp] | 15817
#9 | Search “Survival/psychology”[Mesh] | 379
#10 | Search “acute stress disorder”[All Fields] OR “acute stress disorders”[All Fields] | 366
#11 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 | 413928
#12 | Search “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 2639285
#13 | Search #11 and #12 | 119654
#14 | Search #11 and #12 Filters: Humans | 119103
#15 | Search #11 and #12 Filters: Humans; English | 99884
#16 | Search #11 and #12 Filters: Publication date from 1990/01/01 to 2012/12/31; Humans; English | 78544
#17 | Search “Psychotherapy”[Mesh] | 138716
#18 | Search “Complementary Therapies”[Mesh] | 159479
#19 | Search “Mental Health Services”[Mesh] | 68238
#20 | Search “Therapeutics/psychology”[Mesh] | 43256
#21 | Search (therapy[tiab] OR therapies[tiab]) AND (“school”[tiab] OR “classroom”[tiab]) | 5074
#22 | Search “Adaptation, Psychological”[Mesh] | 92204
#23 | Search #17 OR #18 OR #19 OR #20 OR #21 OR #22 | 443282
#24 | Search (“trauma-focused” OR “trauma focused” OR “child-parent” OR “child parent” OR Narration[Mesh]) AND (therapy OR therapies OR therapeutic*) | 2046
#25 | Search “Cognitive Behavioral Intervention for Trauma in Schools” | 14
#26 | Search CBITS | 4
#27 | Search “Skills Training in Affective and Interpersonal Regulation” | 8
#28 | Search “Dialectical Behavior Therapy” | 191
#29 | Search SPARCS | 42
#30 | Search “Parent-Child Interaction Therapy” | 59
#31 | Search “Eye Movement Desensitization Reprocessing”[Mesh] OR “Eye Movement Desensitization Reprocessing” | 54
#32 | Search “Equine-Assisted Therapy” | 34
#33 | Search “Critical Incident Stress Debriefing” | 80
#34 | Search “Crisis Intervention”[Mesh] | 4977
#35 | Search “Child-Development Community Policing” | 5
#36 | Search #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 | 7435
#37 | Search #36 NOT #23 | 1135
#38 | Search #16 AND #37 | 61
#39 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 482524
#40 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 57327
#41 | Search “Comparative Study”[Publication Type] OR “comparative study” | 1594606
#42 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 49942
#43 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] OR “Case-Control Studies”[Mesh] | 1378353
#44 | Search #38 AND (#39 or #40 or #41 or #42) | 8

EMBASE: 3 August 2012

Search | Queries | Result
#1 | ‘posttraumatic stress disorder’/exp OR ‘acute stress disorder’/exp | 29,186
#2 | ‘psychiatric treatment’/exp | 262,882
#3 | #1 AND #2 | 6,005
#4 | #3 AND ‘human’/exp AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) | 4,337
#5 | ‘adolescent’/exp OR ‘child’/exp OR ‘newborn’/exp | 2,699,004
#6 | #4 AND #5 | 709
#7 | ‘post-traumatic stress disorders’ OR ‘post-traumatic stress disorder’/exp OR ‘posttraumatic stress disorders’ OR ‘posttraumatic stress disorder’/exp | 28,847
#8 | ‘social problem’/exp/mj | 371,779
#9 | ‘life event’/exp/mj | 6,794
#10 | ‘mental stress’/exp/mj | 25,211
#11 | ‘injury’/exp/mj | 825,967
#12 | ‘disaster’/exp/mj | 12,102
#13 | ‘child abuse’/mj | 14,597
#14 | ‘survival’/mj | 18,629
#15 | #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 1,267,521
#16 | #2 AND #15 | 30,962
#17 | ‘mental health service’/exp/mj | 24,106
#18 | ‘therapy’/exp OR therapy OR therapies AND (‘school’/exp OR school OR classroom) | 1,087,826
#19 | ‘adaptive behavior’/exp/mj | 17,979
#20 | #16 AND ‘human’/exp AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) | 17,634
#21 | ‘psychotropic agent’/exp/mj | 399,776
#22 | ‘antidepressant agent’/exp/mj | 153,461
#23 | ‘monoamine oxidase inhibitor’/exp/mj | 21,644
#24 | ‘anticonvulsive agent’/exp/mj | 132,516
#25 | ‘adrenergic agents’/exp OR ‘adrenergic agents’ | 471,979
#26 | ‘neuroleptic agent’/exp/mj | 124,623
#27 | ‘tranquilizer’/exp/mj | 187,605
#28 | ‘benzodiazepine derivative’/exp/mj | 64,069
#29 | ‘opiate’/exp/mj | 17,328
#30 | #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 | 921,633
#31 | #1 OR #15 | 1,267,897
#32 | #30 AND #31 | 61,188
#33 | #32 AND (‘human’/exp OR ‘human’) AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) | 28,002
#34 | #5 AND #33 | 3,755
#35 | #5 AND #20 | 3,534
#36 | #34 NOT #35 | 3,576
#37 | #1 AND #5 AND #30 AND ‘human’/exp AND (1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) AND (‘article’/it OR ‘review’/it) AND ([embase]/lim OR [embase classic]/lim) | 126
#38 | #37 NOT #35 | 78

Child PTSD Psycinfo, CINAHL, IPA: 3 August 2012

# | Query | Results
S33 | S32 | 11
S32 | S31 NOT (S16 OR S19) | 106
S31 | S1 and S30 | 154
S30 | S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 | 2648
S29 | (“trauma-focused” OR “trauma focused” OR “child-parent” OR “child parent” OR Narration) AND (therapy OR therapies OR therapeutic*) | 875
S28 | “Critical Incident Stress Debriefing” | 220
S27 | “Equine-Assisted Therapy” | 23
S26 | “Eye Movement Desensitization Reprocessing” | 339
S25 | “Parent-Child Interaction Therapy” | 227
S24 | SPARCS | 75
S23 | “Dialectical Behavior Therapy” | 857
S22 | “Skills Training in Affective and Interpersonal Regulation” | 5
S21 | CBITS | 16
S20 | “Cognitive Behavioral Intervention for Trauma in Schools” | 15
S19 | S17 or S18 | 9893
S18 | ((((((DE “Drugs”) OR (DE “Monoamine Oxidase Inhibitors”)) AND (DE “Anticonvulsive Drugs” OR DE “Antidepressant Drugs”)) OR (DE “Adrenergic Drugs”)) OR (DE “Tranquilizing Drugs”)) OR (DE “Benzodiazepines”)) OR “opiate alkaloid” OR “opiate alkaloids” OR “dissociative anesthetics” OR “dissociative anesthetics” AND (S2 OR S3) | 8225
S17 | DE “Drug Therapy” AND (S2 OR S3) | 1748
S16 | S1 and S15 | 1770
S15 | S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 | 261469
S14 | DE “Survivors” | 10288
S13 | DE “Child Abuse” | 27903
S12 | DE “Disasters” | 6021
S11 | DE “Wounds” OR DE “Injuries” | 8210
S10 | DE “Psychological Stress” | 6948
S9 | DE “Life Changes” | 1949
S8 | TI “social problems” OR AB “social problems” | 5679
S7 | TI ( “Traumatizing” OR “Traumatising” OR “Trauma” OR “Traumatic” OR “Traumas” OR “Traumatization” OR “Traumatisation” OR “Traumatized” OR “Traumatised” OR “peritraumatic” ) OR AB ( “Traumatizing” OR “Traumatising” OR “Trauma” OR “Traumatic” OR “Traumas” OR “Traumatization” OR “Traumatisation” OR “Traumatized” OR “Traumatised” OR “peritraumatic” ) | 94990
S6 | TI “posttraumatic stress disorder” OR AB “posttraumatic stress disorders” | 5700
S5 | TI “post-traumatic stress disorder” OR AB “post-traumatic stress disorders” | 2759
S4 | TI ptsd OR AB ptsd | 19144
S3 | “Posttraumatic Stress Disorder” OR DE “Reactive Psychosis” OR DE “Stress Reactions” OR DE “Psychological Stress” OR DE “Acute Stress Disorder” OR DE “Emotional Trauma” | 47150
S2 | “Injuries” OR DE “Burns” OR DE “Electrical Injuries” OR DE “Head Injuries” OR DE “Spinal Cord Injuries” OR DE “Wounds” | 125794
S1 | DE “Psychotherapeutic Techniques” OR DE “Animal Assisted Therapy” OR DE “Autogenic Training” OR DE “Cotherapy” OR DE “Dream Analysis” OR DE “Ericksonian Psychotherapy” OR DE “Guided Imagery” OR DE “Mirroring” OR DE “Morita Therapy” OR DE “Motivational Interviewing” OR DE “Mutual Storytelling Technique” OR DE “Paradoxical Techniques” OR DE “Psychodrama” | 26508

Number of records after duplicates removed: 97

## Handsearches

Handsearches yielded 230 additional records.

Aaron J, Zaglul H, Emery RE. Posttraumatic stress in children following acute physical injury. Journal of Pediatric Psychology. Aug. 1999;24(4):335-43. [pmid: 10431499].
Adams KN. Bereavement counseling groups with elementary school students. [9607156]. United States -- Florida. University of Florida. 1994.
Ahmad A, Sofi MA, Sundelin-Wahlsten V, et al. Posttraumatic stress disorder in children after the military operation “Anfal” in Iraqi Kurdistan. Eur Child Adolesc Psychiatry. Dec. 2000;9(4):235-43. [pmid: 11202098].
Anda RF, Felitti VJ, Bremner JD, et al. The enduring effects of abuse and related adverse experiences in childhood. A convergence of evidence from neurobiology and epidemiology. Eur Arch Psychiatry Clin Neurosci. Apr. 2006;256(3):174-86. [pmid: 16311898].
Arvidson J, Kinniburgh K, Howard K, et al. Treatment of Complex Trauma in Young Children: Developmental and Cultural Considerations in Application of the ARC Intervention Model. Journal of Child & Adolescent Trauma. 2011;4(1):34-51.
Asarnow J, Glynn S, Pynoos RS, et al. When the earth stops shaking: Earthquake sequelae among children diagnosed for pre-earthquake psychopathology. Journal of the American Academy of Child and Adolescent Psychiatry. Aug. 1999;38(8):1016-23. PMID: ISI:000081664700018. [pmid: 10434494].
Baker A, Shalhoub-Kevorkian N. Effects of political and military traumas on children: the Palestinian case. Clin Psychol Rev. Dec. 1999;19(8):935-50. [pmid: 10547711].
Barrett PM. Evaluation of cognitive-behavioral group treatments for childhood anxiety disorders. Journal of Clinical Child Psychology. 1998;27(4):459-68. PMID: 1999-00482-010. First Author & Affiliation: Barrett, Paula M. [pmid: 9866083].
Barrett PM, Dadds MR, Rapee RM. Family treatment of childhood anxiety: A controlled trial. Journal of Consulting and Clinical Psychology. 1996;64(2):333-42. PMID: 1996-00433-012. First Author & Affiliation: Barrett, Paula M. [pmid: 8871418].
Barrett PM, Duffy AL, Dadds MR, et al. Cognitive–behavioral treatment of anxiety disorders in children: Long-term (6-year) follow-up. Journal of Consulting and Clinical Psychology. 2001;69(1):135-41. PMID: 2001-14541-018. First Author & Affiliation: Barrett, Paula M. [pmid: 11302272].
Baum A, Okeefe MK, Davidson LM. Acute Stressors and Chronic Response - the Case of Traumatic Stress. Journal of Applied Social Psychology. Nov. 1990;20(20):1643-54. PMID: ISI:A1990EM00100003.
Beehler S, Birman D, Campbell R. The Effectiveness of Cultural Adjustment and Trauma Services (CATS): Generating Practice-Based Evidence on a Comprehensive, School-Based Mental Health Intervention for Immigrant Youth. Am J Community Psychol. 2011. Dec. 8. [pmid: 22160732].
Beidel DC, Turner SM, Morris TL. Behavioral treatment of childhood social phobia. Journal of Consulting and Clinical Psychology. 2000;68(6):1072-80. PMID: 2001-17092-013. First Author & Affiliation: Beidel, Deborah C. [pmid: 11142541].
Berkowitz SJ. Children exposed to community violence: the rationale for early intervention. Clin Child Fam Psychol Rev. Dec. 2003;6(4):293-302. [pmid: 14719640].
Berman H. Stories of growing up amid violence by refugee children of war and children of battered women living in Canada. Image J Nurs Sch. 1999;31(1):57-63. [pmid: 10081214].
Berman H. Health in the aftermath of violence: a critical narrative study of children of war and children of battered women. Can J Nurs Res. Dec. 1999;31(3):89-109. [pmid: 10696171].
Betancourt TS. Stressors, supports and the social ecology of displacement: psychosocial dimensions of an emergency education program for Chechen adolescents displaced in Ingushetia, Russia. Cult Med Psychiatry. Sep. 2005;29(3):309-40. [pmid: 16404689].
Birman D, Ho J, Pulley E, et al. Mental health interventions for refugee children in resettlement. White Paper II. Chicago, IL. Regugee Trauma Task Force NCTSN. 2005. http://www.nctsnet.org/nctsn_assets/pdfs/materials_for_applicants/MH_Interventions_for_Refugee_Children.pdf.
Blaustein M, Kinniburgh K. Intervening beyond the child: The intertwining nature of attachment and trauma. Briefing Paper: Attachment Theroy Into Practice. British Psychological Society, Briefing Paper. 2007;26:48-53.
Boney-McCoy S, Finkelhor D. Is youth victimization related to trauma symptoms and depression after controlling for prior symptoms and family relationships? A longitudinal, prospective study. Journal of Consulting and Clinical Psychology. Dec. 1996;64(6):1406-16. PMID: ISI:A1996VZ95300030. [pmid: 8991327].
Bratton SC, Ray D, Rhine T, et al. The efficacy of play therapy with children: A meta-analytic review of treatment outcomes. Professional Psychology-Research and Practice. Aug. 2005;36(4):376-90. PMID: ISI:000231607000005.
Brent DA, Perper JA, Moritz G, et al. Posttraumatic stress disorder in peers of adolescent suicide victims: predisposing factors and phenomenology. J Am Acad Child Adolesc Psychiatry. Feb. 1995;34(2):209-15. [pmid: 7896654].
Breslau N, Davis GC, Andreski P, et al. Traumatic events and posttraumatic stress disorder in an urban population of young adults. Arch Gen Psychiatry. Mar. 1991;48(3):216-22. [pmid: 1996917].
Brewin CR, Andrews B, Rose S, et al. Acute stress disorder and posttraumatic stress disorder in victims of violent crime. Am J Psychiatry. Mar. 1999;156(3):360-6. [pmid: 10080549].
Brown E, Goodman R, Cohen J, et al. TF-CBT for children who lost their fathers in uniform during the World Trade Center Disaster. 2004.
Brown EJ, McQuaid J, Farina L, et al. Matching Interventions to Children's Mental Health Needs: Feasibility and Acceptability of a Pilot School-Based Trauma Intervention Program. Education & Treatment of Children (West Virginia University Press). 2006:257-86. [pmid: 21817250].
Bryant B, Mayou R, Wiggs L, et al. Psychological consequences of road traffic accidents for children and their mothers. Psychol Med. Feb. 2004;34(2):335-46. [pmid: 14982139].
Brymer MJ, Steinberg AM, Watson PJ, et al. Prevention and early intervention programs for children and adolescents. Beck JG, Sloan DM, editors. The Oxford handbook of traumatic stress disorders. New York, NY US. Oxford University Press. 2012:381-92.
Carver EA. Depression and loss: The effects of a short term bereavement support group for children and families. [9951566]. United States -- California. California School of Professional Psychology - Fresno. 1999.
Catani C, Jacob N, Schauer E, et al. Family violence, war, and natural disasters: a study of the effect of extreme stress on children's mental health in Sri Lanka. Bmc Psychiatry. 2008;8:33. [pmid: 18454851].
Chalder T, Tong J, Deary V. Family cognitive behaviour therapy for chronic fatigue syndrome: an uncontrolled study. Arch Dis Child. Feb. 2002;86(2):95-7. [pmid: 11827901].
Charlton M. Dialectical behavior therapy for children with developmental disabilities. NADD Bulletin. 2006;9(5):90-3.
Chase R, Doney A, Sivayogan S, et al. Mental health initiatives as peace initiatives in Sri Lankan schoolchildren affected by armed conflict. Med Confl Surviv. Oct-Dec. 1999;15(4):379-90. discussion 91-3. [pmid: 10605388].
Cicchetti D, Lynch M. Toward an ecological/transactional model of community violence and child maltreatment: consequences for children's development. Psychiatry. Feb. 1993;56(1):96-118. [pmid: 8488217].
Cicchetti D, Rogosch FA, Toth SL. The efficacy of toddler-parent psychotherapy for fostering cognitive development in offspring of depressed mothers. J Abnorm Child Psychol. Apr. 2000;28(2):135-48. [pmid: 10834766].
Cicchetti D, Toth SL, Rogosch FA. The efficacy of toddler-parent psychotherapy to increase attachment security in offspring of depressed mothers. Attach Hum Dev. Apr. 1999;1(1):34-66. [pmid: 11707882].
Coates S, Schechter D. Preschoolers' traumatic stress post-9/11: relational and developmental perspectives. Psychiatr Clin North Am. Sep. 2004;27(3):473-89. [pmid: 15325488].
Cobham VE, Dadds MR, Spence SH. The role of parental anxiety in the treatment of childhood anxiety. Journal of Consulting and Clinical Psychology. 1998;66(6):893-905. PMID: 1998-11580-002. First Author & Affiliation: Cobham, Vanessa E. [pmid: 9874902].
Cohen JA. Pharmacologic treatment of traumatized children. Trauma, Violence, & Abuse. 2001;2(2):155-71. PMID: 2001-00500-004. First Author & Affiliation: Cohen, Judith A.
Cohen JA, Mannarino AP, Rogal S. Treatment practices for childhood posttraumatic stress disorder. Child Abuse Negl. Jan. 2001;25(1):123-35. [pmid: 11214806].
Copeland WE, Keeler G, Angold A, et al. Traumatic events and posttraumatic stress in childhood. Arch Gen Psychiatry. May. 2007;64(5):577-84. [pmid: 17485609].
Costello EJ, Erkanli A, Fairbank JA, et al. The prevalence of potentially traumatic events in childhood and adolescence. J Trauma Stress. Apr. 2002;15(2):99-112. [pmid: 12013070].
Cuffe SP, Addy CL, Garrison CZ, et al. Prevalence of PTSD in a community sample of older adolescents. J Am Acad Child Adolesc Psychiatry. Feb. 1998;37(2):147-54. [pmid: 9473910].
Currier JM, Holland JM, Neimeyer RA. The effectiveness of bereavement interventions with children: a meta-analytic review of controlled outcome research. J Clin Child Adolesc Psychol. Apr-Jun. 2007;36(2):253-9. [pmid: 17484697].
Dadds MR, Spence SH, Holland DE, et al. Prevention and early intervention for anxiety disorders: a controlled trial. J Consult Clin Psychol. Aug. 1997;65(4):627-35. [pmid: 9256564].
Davidson JR. Biological therapies for posttraumatic stress disorder: an overview. J Clin Psychiatry. 1997;58(Suppl 9):29-32. [pmid: 9329449].
de Arellano MA, Waldrop AE, Deblinger E, et al. Community outreach program for child victims of traumatic events - A community-based project for underserved populations. Behavior modification. Jan. 2005;29(1):130-55. PMID: WOS:000225680900006. [pmid: 15557481].
de Vries AP, Kassam-Adams N, Cnaan A, et al. Looking beyond the physical injury: posttraumatic stress disorder in children and parents after pediatric traffic injury. Pediatrics. Dec. 1999;104(6):1293-9. [pmid: 10585980].
Deblinger E, Lippmann J, Steer R. Sexually Abused Children Suffering Posttraumatic Stress Symptoms: Initial Treatment Outcome Findings. Child Maltreatment Child Maltreatment. 1996;1(4):310-21.
Devoe ER, Dean K, Traube D, et al. The SURVIVE Community Project: A Family-Based Intervention to Reduce the Impact of Violence Exposures in Urban Youth. J Aggress Maltreat Trauma. 2005;11(4):95-116. [pmid: 21369343].
Di Gallo A, Barton J, Parry-Jones WL. Road traffic accidents: early psychological consequences in children and adolescents. Br J Psychiatry. Apr. 1997;170:358-62. [pmid: 9246255].
Dixon A, Howie P, Starling J. Trauma exposure, posttraumatic stress, and psychiatric comorbidity in female juvenile offenders. J Am Acad Child Adolesc Psychiatry. Aug. 2005;44(8):798-806. [pmid: 16034282].
Dorsey S. Improving outcomes for youth in foster care: TF-CBT. 2012.
Duff AJ. Incorporating psychological approaches into routine paediatric venepuncture. Arch Dis Child. Oct. 2003;88(10):931-7. [pmid: 14500318].
Dulcan MK. Does community mental health treatment of children and adolescents help?. Journal of the American Academy of Child and Adolescent Psychiatry. 2000;39(2):153.
Duncan DF. Growing up under the gun: Children and adolescents coping with violent neighborhoods. The Journal of Primary Prevention. 1996;16(4):343-56. PMID: 1996-05609-001. First Author & Affiliation: Duncan, David F.
Dunne RL, Kenardy J, Sterling M. A Randomized Controlled Trial of Cognitive-behavioral Therapy for the Treatment of PTSD in the Context of Chronic Whiplash. Clin J Pain. 2011. Dec. 30. [pmid: 22209798].
Dybdahl R. A Psychosocial Support Programme for Children and Mothers in War. Clinical Child Psychology & Psychiatry. 2001;6(3):425. [pmid: 5850353].
Dyregrov A, Gjestad R, Raundalen M. Children exposed to warfare: a longitudinal study. J Trauma Stress. Feb. 2002;15(1):59-68. [pmid: 11936723].
Dyregrov A, Gupta L, Gjestad R, et al. Trauma exposure and psychological reactions to genocide among Rwandan children. J Trauma Stress. Jan. 2000;13(1):3-21. [pmid: 10761171].
Ehntholt KA, Smith PA, Yule W. School-based Cognitive-Behavioural Therapy Group Intervention for Refugee Children who have Experienced War-related Trauma. Clinical Child Psychology and Psychiatry. 2005;10(2):235-50. PMID: 2005-03937-007. First Author & Affiliation: Ehntholt, Kimberly A.
Elbedour S, Onwuegbuzie AJ, Ghannam J, et al. Post-traumatic stress disorder, depression, and anxiety among Gaza Strip adolescents in the wake of the second Uprising (Intifada). Child Abuse Negl. Jul. 2007;31(7):719-29. [pmid: 17631959].
Ellis A, Stores G, Mayou R. Psychological consequences of road traffic accidents in children. Eur Child Adolesc Psychiatry. Jun. 1998;7(2):61-8. [pmid: 9712371].
Ellis BH, Fogler J, Hansen S, et al. Trauma systems therapy: 15-month outcomes and the importance of effecting environmental change. Psychological Trauma: Theory, Research, Practice, and Policy. 2011. PMID: 2011-18640-001. Publication Status: Online First Posting. First Author & Affiliation: Ellis, B. Heidi. Release Date: 20110822. Correction Date: 20110829. Publication Type: Journal, (0100).
Eyberg SM, Funderburk BW, Hembree-Kigin TL, et al. Parent-Child Interaction Therapy with behavior problem children: One and two year maintenance of treatment effects in the family. Child & Family Behavior Therapy. 2001;23(4):1-20. PMID: ISI:000180809800001.
Famularo R, Fenton T, Augustyn M, et al. Persistence of pediatric post traumatic stress disorder after 2 years. Child Abuse Negl. Dec. 1996;20(12):1245-8. [pmid: 8985614].
Feather JS, Ronan KR. Trauma-focused cognitive behavioural therapy for abused children with posttraumatic stress disorder: A pilot study. New Zealand Journal of Psychology. Nov. 2006;35(3):132-45. PMID: ISI:000243478700005.
Feeny NC, Foa EB, Treadwell KRH, et al. Posttraumatic stress disorder in youth: A critical review of the cognitive and behavioral treatment outcome literature. Professional Psychology-Research and Practice. Oct. 2004;35(5):466-76. PMID: ISI:000224211100004.
Feldman ES. Implementation of the Cognitive Behavioral Intervention for Trauma in Schools (CBITS) with Spanish-speaking, immigrant middle-school students: Is effective, culturally competent treatment possible within a public school setting?. [3261445]. United States -- Wisconsin. The University of Wisconsin - Madison. 2007.
Flannery-Schroeder EC, Kendall PC. Group and individual cognitive–behavioral treatments for youth with anxiety disorders: A randomized clinical trial. Cognitive Therapy and Research. 2000;24(3):251-78. PMID: 2000-00017-001. First Author & Affiliation: Flannery-Schroeder, Ellen C.
Forbes D, Lewis V, Varker T, et al. Psychological first aid following trauma: implementation and evaluation framework for high-risk organizations. Psychiatry. Fall. 2011;74(3):224-39. [pmid: 21916629].
Ford JD, Russo E. Trauma-focused, present-centered, emotional self-regulation approach to integrated treatment for posttraumatic stress and addiction: trauma adaptive recovery group education and therapy (TARGET). Am J Psychother. 2006;60(4):335-55. [pmid: 17340945].
Ford JD, Russo EM, Mallon SD. Integrating treatment of posttraumatic stress disorder and substance use disorder. Journal of Counseling and Development. Fal. 2007;85(4):475-89. PMID: ISI:000250682000011.
Ford JD, Steinberg KL, Hawke J, et al. Randomized trial comparison of emotion regulation and relational psychotherapies for PTSD with girls involved in delinquency. J Clin Child Adolesc Psychol. 2012;41(1):27-37. [pmid: 22233243].
Foy DW, Madvig BT, Pynoos RS, et al. Etiologic factors in the development of posttraumatic stress disorder in children and adolescents. Journal of School Psychology. Sum. 1996;34(2):133-45. PMID: ISI:A1996UL37200003.
Gale CK, Millichamp J. Generalised anxiety disorder. Clin Evid (Online). 2011. 2011. [pmid: 22030083].
Garbarino J, Kostelny K. What Children Can Tell Us About Living in a War Zone. Osofsky JD, editor. Children in a Violent Society. United States. Erikson Institute. 1997:32-41.
Garrison EG, Roy IS, Azar V. Responding to the mental health needs of Latino children and families through school-based services. Clin Psychol Rev. Mar. 1999;19(2):199-219. [pmid: 10078420].
Gelles RJ. Poverty and Violence toward Children. American Behavioral Scientist. Jan-Feb. 1992;35(3):258-74. PMID: ISI:A1992-GX67800004.
Ghuman HS, Weist MD, Sarles RM. Providing mental health services to youth where they are : school- and community-based approaches. New York. Brunner-Routledge. 2002.
Giaconia RM, Reinherz HZ, Silverman AB, et al. Traumas and posttraumatic stress disorder in a community population of older adolescents. J Am Acad Child Adolesc Psychiatry. Oct. 1995;34(10):1369-80. [pmid: 7592275].
Gillies ML, Barton J, Di Gallo A. Follow-up of young road accident victims. J Trauma Stress. Oct. 2003;16(5):523-6. [pmid: 14584639].
Goenjian AK, Walling D, Steinberg AM, et al. Depression and PTSD symptoms among bereaved adolescents 6(1/2) years after the 1988 Spitak earthquake. J Affect Disord. Jan. 2009;112(1-3):81-4. [pmid: 18547646].
Graae F, Milner J, Rizzotto L, et al. Clonazepam in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. Mar-Apr. 1994;33(3):372-6. [pmid: 8169182].
Groves BM. Children who see too much: lessons from the child witness to violence project. Boston. Beacon Press. 2002.
Hansen S, Saxe G. Trauma systems therapy: A replication of the model, integrating cognitive behavioral play therapy into child and family treatment. Drewes AA, editor. Blending play therapy with cognitive behavioral therapy: Evidence-based and other effective treatments and techniques. Hoboken, NJ US. John Wiley & Sons Inc. 2009:139-64.
Hayward C, Varady S, Albano AM, et al. Cognitive–behavioral group therapy for social phobia in female adolescents: Results of a pilot study. Journal of the American Academy of Child & Adolescent Psychiatry. 2000;39(6):721-6. PMID: 2000-15897-010. First Author & Affiliation: Hayward, Chris. [pmid: 10846306].
Heiney SP, Goon-Johnson K, Ettinger RS, et al. The effects of group therapy on siblings of pediatric oncology patients. J Pediatr Oncol Nurs. Jul. 1990;7(3):95-100. [pmid: 2206479].
Herrmann J, Brymer MJ. Psychological First Aid following trauma: A first line response for disasters and other public health emergencies. National Association of County & City Health Officials Exchange. 2008;7:1-3.
Hilliard RE. The effects of music therapy-based bereavement groups on mood and behavior of grieving children: A pilot study. Journal of Music Therapy. 2001;38(4):291-306. PMID: 2002-10829-003. First Author & Affiliation: Hilliard, Russell E. [pmid: 11796079].
Hobfoll SE, Watson P, Bell CC, et al. Five essential elements of immediate and mid-term mass trauma intervention: empirical evidence. Psychiatry. Winter. 2007;70(4):283-315. discussion 6-69. [pmid: 18181708].
Hood KK, Eyberg SM. Outcomes of parent-child interaction therapy: mothers' reports of maintenance three to six years after treatment. J Clin Child Adolesc Psychol. Sep. 2003;32(3):419-29. [pmid: 12881030].
Horrigan JP, Barnhill LJ. The suppression of nightmares with guanfacine. J Clin Psychiatry. Aug. 1996;57(8):371. [pmid: 8752021].
Housley PC. Effectiveness of grief support groups for children. [9722309]. United States -- Colorado. University of Northern Colorado. 1996.
Hoven CW, Duarte CS, Lucas CP, et al. Psychopathology among New York city public school children 6 months after September 11. Archives of General Psychiatry. May. 2005;62(5):545-52. PMID: ISI:000228905600011. [pmid: 15867108].
Hubbard J, Realmuto GM, Northwood AK, et al. Comorbidity of psychiatric diagnoses with posttraumatic stress disorder in survivors of childhood trauma. J Am Acad Child Adolesc Psychiatry. Sep. 1995;34(9):1167-73. [pmid: 7559311].
Huss SN. The effect of peer bereavement support groups on the self-esteem, depression, and problem behavior of parentally bereaved children. [9729145]. United States -- Ohio. The University of Toledo. 1997.
Jaycox LH, Kataoka S, Stein BD, et al. Responding to the needs of the community: a stepped-care approach to implementing trauma-focused interventions in schools. Report on Emotional and Behavioral Disorders in Youth. 2005;5(4):85-92.
Jaycox LH, Langley AK, Stein BD, et al. Support for Students Exposed to Trauma: A Pilot Study. School Ment Health. Jun. 1. 2009;1(2):49-60. [pmid: 20811511].
Jaycox LH, Stein BD, Kataoka SH, et al. Violence exposure, posttraumatic stress disorder, and depressive symptoms among recent immigrant schoolchildren. J Am Acad Child Adolesc Psychiatry. Sep. 2002;41(9):1104-10. [pmid: 12218432].
Kagan R, Douglas AN, Hornik J, et al. Real Life Heroes Pilot Study: Evaluation of a Treatment Model for Children with Traumatic Stress. Journal of Child & Adolescent Trauma. 2008;1(1):5-22.
Kain ZN, Mayes LC, Wang SM, et al. Postoperative behavioral outcomes in children: Effects of sedative premedication. Anesthesiology. 1999;90(3):758-65. [pmid: 10078677].
Kar N, Bastia BK. Post-traumatic stress disorder, depression and generalised anxiety disorder in adolescents after a natural disaster: a study of comorbidity. Clin Pract Epidemiol Ment Health. 2006;2:17. [pmid: 16869979].
Kar N, Mohapatra PK, Nayak KC, et al. Post-traumatic stress disorder in children and adolescents one year after a super-cyclone in Orissa, India: exploring cross-cultural validity and vulnerability factors. Bmc Psychiatry. 2007;7:8. [pmid: 17300713].
Kataoka S, Jaycox LH, Wong M, et al. Effects on school outcomes in low-income minority youth: preliminary findings from a community-partnered study of a school-based trauma intervention. Ethn Dis. Summer. 2011;21(3 Suppl 1):S1-71-7. [pmid: 22352083].
Kataoka SH, Stein BD, Jaycox LH, et al. A school-based mental health program for traumatized Latino immigrant children. Journal of the American Academy of Child & Adolescent Psychiatry. 2003;42(3):311-8. PMID: 2003-02169-013. First Author & Affiliation: Kataoka, Sheryl H. [pmid: 12595784].
Katzman MA. Current considerations in the treatment of generalized anxiety disorder. CNS Drugs. 2009;23(2):103-20. [pmid: 19173371].
Kazak AE. Evidence-based interventions for survivors of childhood cancer and their families. Journal of Pediatric Psychology. Jan-Feb. 2005;30(1):29-39. [pmid: 15610982].
Kazak AE, Alderfer M, Rourke MT, et al. Posttraumatic stress disorder (PTSD) and posttraumatic stress symptoms (PTSS) in families of adolescent childhood cancer survivors. Journal of Pediatric Psychology. Apr-May. 2004;29(3):211-9. [pmid: 15131138].
Kazak AE, Boeving CA, Alderfer MA, et al. Posttraumatic stress symptoms during treatment in parents of children with cancer. J Clin Oncol. Oct. 20. 2005;23(30):7405-10. [pmid: 16157936].
Kenardy J, Thompson K, Le Brocque R, et al. Information-provision intervention for children and their parents following pediatric accidental injury. Eur Child Adolesc Psychiatry. Aug. 2008;17(5):316-25. [pmid: 18350366].
Kendall PC. Treating anxiety disorders in children: results of a randomized clinical trial. J Consult Clin Psychol. Feb. 1994;62(1):100-10. [pmid: 8034812].
Kendall PC, Choudhury MS. Children and adolescents in cognitive-behavioral therapy: Some past efforts and current advances, and the challenges in our future. Cognitive Therapy and Research. Feb. 2003;27(1):89-104. PMID: ISI:000181234700006.
Kendall PC, Flannery-Schroeder E, Panichelli-Mindel SM, et al. Therapy for youths with anxiety disorders: A second randomized clincal trial. Journal of Consulting and Clinical Psychology. 1997;65(3):366-80. PMID: 1997-06366-002. First Author & Affiliation: Kendall, Philip C. [pmid: 9170760].
Keppel-Benson JM, Ollendick TH, Benson MJ. Post-traumatic stress in children following motor vehicle accidents. Journal of Child Psychology & Psychiatry & Allied Disciplines. 2002;43(2):203. [pmid: 6331014].
King NJ, Tonge BJ, Heyne D, et al. Cognitive-behavioral treatment of school-refusing children: A controlled evaluation. Journal of the American Academy of Child & Adolescent Psychiatry. 1998;37(4):395-403. PMID: 1998-01321-017. First Author & Affiliation: King, Neville J. [pmid: 9549960].
Kinniburgh KJ, Blaustein M, Spinazzola J, et al. Attachment, Self-Regulation and Competency. Psychiatric Annals. 2005;35(5):424-30. PMID: 2005-05449-007. First Author & Affiliation: Kinniburgh, Kristine Jentoft.
Kiser LJ, Donohue A, Hodgkinson S, et al. Strengthening family coping resources: the feasibility of a multifamily group intervention for families exposed to trauma. J Trauma Stress. Dec. 2010;23(6):802-6. [pmid: 21105068].
Kolko DJ. Individual Cognitive Behavioral Treatment and Family Therapy for Physically Abused Children and their Offending Parents: A Comparison of Clinical Outcomes. Child Maltreatment. November. 1. 1996. 1996;1(4):322-42.
Koplewicz HS, Vogel JM, Solanto MV, et al. Child and parent response to the 1993 World Trade Center bombing. J Trauma Stress. Feb. 2002;15(1):77-85. [pmid: 11936725].
Koren D, Arnon I, Klein E. Acute stress response and posttraumatic stress disorder in traffic accident victims: a one-year prospective, follow-up study. Am J Psychiatry. Mar. 1999;156(3):367-73. [pmid: 10080550].
Korol M, Green BL, Gleser GC. Children's responses to a nuclear waste disaster: PTSD symptoms and outcome prediction. J Am Acad Child Adolesc Psychiatry. Apr. 1999;38(4):368-75. [pmid: 10199107].
Kramer DN, Landolt MA. Characteristics and efficacy of early psychological interventions in children and adolescents after single trauma: a meta-analysis. European journal of psychotraumatology. 2011:2.
Kutcher SP, Reiter S, Gardner DM, et al. The pharmacotherapy of anxiety disorders in children and adolescents. Psychiatr Clin North Am. Mar. 1992;15(1):41-67. [pmid: 1549548].
Lal MK, McClelland J, Phillips J, et al. Comparison of EMLA cream versus placebo in children receiving distraction therapy for venepuncture. Acta Paediatrica, International Journal of Paediatrics. 2001;90(2):154-9.
Last CG, Hansen C, Franco N. Cognitive-behavioral treatment of school phobia. Journal of the American Academy of Child & Adolescent Psychiatry. 1998;37(4):404-11. PMID: 1998-01321-018. First Author & Affiliation: Last, Cynthia G. [pmid: 9549961].
Layne CM, Pynoos RS, Cardenas J. Wounded adolescence: School-based group psychotherapy for adolescents who sustained or witnessed violent injury. Shafii M, Shafii SL, editors. School violence: Assessment, management, prevention. Washington, DC US. American Psychiatric Association. 2001:163-86.
Liacouras CA, Mascarenhas M, Poon C, et al. Placebo-controlled trial assessing the use of oral midazolam as a premedication to conscious sedation for pediatric endoscopy. Gastrointestinal Endoscopy. 1998;47(6):455-60. [pmid: 9647368].
Ljungman G, Kreuger A, Andreasson S, et al. Midazolam nasal spray reduces procedural anxiety in children. Pediatrics. 2000;105(1 I):73-8. [pmid: 10617707].
Loughry M, Ager A, Flouri E, et al. The impact of structured activities among Palestinian children in a time of conflict. Journal of child psychology and psychiatry, and allied disciplines. Dec. 2006;47(12):1211-8. [pmid: 17176376].
Loy MJ. A study of the effectiveness of a camp intervention for bereaved adolescents. [9923242]. United States -- Wisconsin. The University of Wisconsin - Madison. 1999.
Lyons JS, Kisiel CL, Dulcan M, et al. Crisis assessment and psychiatric hospitalization of children and adolescents in state custody. Journal of Child and Family Studies. 1997;6(3):311-20. PMID: 1997-43188-003. First Author & Affiliation: Lyons, John S.
Manassis K, Mendlowitz SL, Scapillato D, et al. Group and individual cognitive-behavioral therapy for childhood anxiety disorders. A randomized trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2002;41(12):1423-30. PMID: 2002-11435-018. First Author & Affiliation: Manassis, Katharina. [pmid: 12447028].
March JS, Amaya-Jackson L, Terry R, et al. Posttraumatic symptomatology in children and adolescents after an industrial fire. J Am Acad Child Adolesc Psychiatry. Aug. 1997;36(8):1080-8. [pmid: 9256587].
Mather FJ, Tate RL, Hannan TJ. Post-traumatic stress disorder in children following road traffic accidents: a comparison of those with and without mild traumatic brain injury. Brain Inj. Dec. 2003;17(12):1077-87. [pmid: 14555366].
McDermott BM, Cvitanovich A. Posttraumatic stress disorder and emotional problems in children following motor vehicle accidents: an extended case series. Aust N Z J Psychiatry. Jun. 2000;34(3):446-52. [pmid: 10881968].
McDermott BM, Lee EM, Judd M, et al. Posttraumatic stress disorder and general psychopathology in children and adolescents following a wildfire disaster. Can J Psychiatry. Mar. 2005;50(3):137-43. [pmid: 15830823].
McKay MM, Lynn CJ, Bannon WM. Understanding inner city child mental health need and trauma exposure: implications for preparing urban service providers. Am J Orthopsychiatry. Apr. 2005;75(2):201-10. [pmid: 15839757].
McMullen J, O'Callaghan P. Delivering and evaluating a group intervention for former child soldiers and other war-affected children: A randomized controlled trial. Division of Educational and Child Psychology Annual Professional Development Event. 2012 01/11/2012-01/13/2012. Stratford-Upon-Avon, UK.
Mehta S, Ameratunga SN. Prevalence of post-traumatic stress disorder among children and adolescents who survive road traffic crashes: A systematic review of the international literature. J Paediatr Child Health. 2011. Apr. 29. [pmid: 21535287].
Meighen KG, Hines LA, Lagges AM. Risperidone treatment of preschool children with thermal burns and acute stress disorder. J Child Adolesc Psychopharmacol. Apr. 2007;17(2):223-32. [pmid: 17489717].
Meiser-Stedman R, Smith P, Glucksman E, et al. The posttraumatic stress disorder diagnosis in preschool- and elementary school-age children exposed to motor vehicle accidents. Am J Psychiatry. Oct. 2008;165(10):1326-37. [pmid: 18676592].
Mendlowitz SL, Manassis K, Bradley S, et al. Cognitive-behavioral group treatments in childhood anxiety disorders: The role of parental involvement. Journal of the American Academy of Child & Adolescent Psychiatry. 1999;38(10):1223-9. PMID: 1999-01121-010. First Author & Affiliation: Mendlowitz, Sandra L. [pmid: 10517054].
Mirza KA, Bhadrinath BR, Goodyer IM, et al. Post-traumatic stress disorder in children and adolescents following road traffic accidents. Br J Psychiatry. May. 1998;172:443-7. [pmid: 9747409].
Montgomery E, Foldspang A. Seeking asylum in Denmark: refugee children's mental health and exposure to violence. Eur J Public Health. Jun. 2005;15(3):233-7. [pmid: 15923213].
Morgos D, Worden JW, Gupta L. Psychosocial Effects of War Experiences among Displaced Children in Southern Darfur Omega. Journal of Death & Dying. 2007;56(3):229-53. [pmid: 18300649].
Morsette A, van den Pol R, Schuldberg D, et al. Cognitive behavioral treatment for trauma symptoms in American Indian youth: preliminary findings and issues in evidence-based practice and reservation culture. Advances in School Mental Health Promotion. 2012/01/01. 2012;5(1):51-62.
Mueser KT, Taub J. Trauma and PTSD among adolescents with severe emotional disorders involved in multiple service systems. Psychiatric Services. Jun. 2008;59(6):627-34. [pmid: 18511582].
Muris P, Meesters C, van Melick M. Treatment of childhood anxiety disorders; A preliminary comparison between cognitive-behavioral group therapy and a psychological placebo intervention. Journal of Behavior Therapy and Experimental Psychiatry. 2002;33(3-4):143-58. PMID: 2003-03233-003. First Author & Affiliation: Muris, Peter. [pmid: 12628633].
Nader K, Pynoos R, Fairbanks L, et al. Children's PTSD reactions one year after a sniper attack at their school. Am J Psychiatry. Nov. 1990;147(11):1526-30. [pmid: 2221168].
Nader KO, Pynoos RS, Fairbanks LA, et al. A preliminary study of PTSD and grief among the children of Kuwait following the Gulf crisis. Br J Clin Psychol. Nov. 1993;32(Pt 4):407-16. [pmid: 8298537].
Nagao K, Okuyama M, Miyamoto S, et al. Treating early mental health and post-traumatic symptoms of children in the Hanshin-Awaji earthquake. Acta Paediatr Jpn. Dec. 1995;37(6):745-54. [pmid: 8775565].
Ngo V, Langley A, Kataoka SH, et al. Providing evidence-based practice to ethnically diverse youths: examples from the Cognitive Behavioral Intervention for Trauma in Schools (CBITS) program. Journal of the American Academy of Child and Adolescent Psychiatry. 2008;47(8):858-62. [pmid: 18645419].
Norris FH, Friedman MJ, Watson PJ. 60,000 disaster victims speak: Part II. Summary and implications of the disaster mental health research. Psychiatry. Fall. 2002;65(3):240-60. [pmid: 12405080].
Novins DK, Spicer P, Fickenscher A, et al. Pathways to care: Narratives of American Indian adolescents entering substance abuse treatment. Soc Sci Med. Jun. 2012;74(12):2037-45. [pmid: 22472275].
Ohmi H, Kojima S, Awai Y, et al. Post-traumatic stress disorder in pre-school aged children after a gas explosion. Eur J Pediatr. Dec. 2002;161(12):643-8. [pmid: 12447662].
Opie ND, Goodwin T, Finke LM, et al. The effect of a bereavement group experience on bereaved children's and adolescents' affective and somatic distress. Journal of child and adolescent psychiatric and mental health nursing. 1992;5(1):20-6. [pmid: 1432583].
O'shea B, Hodes M, Down G, et al. A School-based Mental Health Service for Refugee Children. Clinical Child Psychology & Psychiatry. 2000;5(2):189. [pmid: 5434966].
Osofsky JD, Scheeringa MS. Community and Domestic Violence Exposure: Effects on Development and Psychopathology. Cicchetti D, Toth SL, editors. Rochester Symposium on Developmental Psychopathology: Develomental Perspectives on Trauma. Rochester, NY. University of Rochester Press. 1997;8:155-80.
Parker J, Watts H, Allsopp MR. Post-traumatic stress symptoms in children and parents following a school-based fatality. Child Care Health Dev. May. 1995;21(3):183-9. [pmid: 7621557].
Perry BD, Pollard RA, Blakley TL, et al. Childhood trauma, the neurobiology of adaptation, and ‘use-dependent’ development of the brain: How ‘states’ become ‘traits.’. Infant Mental Health Journal. 1995;16(4):271-91. PMID: 1996-02338-002. First Author & Affiliation: Perry, Bruce D.
Pfefferbaum B. Posttraumatic stress disorder in children: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry. Nov. 1997;36(11):1503-11. [pmid: 9394934].
Pfefferbaum B, Call JA, Sconzo GM. Mental health services for children in the first two years after the 1995 Oklahoma City terrorist bombing. Psychiatric Services. Jul. 1999;50(7):956-8. [pmid: 10402620].
Pfefferbaum B, Nixon SJ, Krug RS, et al. Clinical needs assessment of middle and high school students following the 1995 Oklahoma City bombing. Am J Psychiatry. Jul. 1999;156(7):1069-74. [pmid: 10401454].
Pfefferbaum B, Stuber J, Galea S, et al. Panic reactions to terrorist attacks and probable posttraumatic stress disorder in adolescents. J Trauma Stress. Apr. 2006;19(2):217-28. [pmid: 16612814].
Pillar G, Malhotra A, Lavie P. Post-traumatic stress disorder and sleep-what a nightmare!. Sleep Med Rev. Apr. 2000;4(2):183-200. [pmid: 12531165].
Pine DS. Developmental psychobiology and response to threats: relevance to trauma in children and adolescents. Biol Psychiatry. May. 1. 2003;53(9):796-808. [pmid: 12725972].
Psychiatry AAoCaA. Practice parameters for the assessment and treatment of children and adolescents with posttraumatic stress disorder. J Am Acad Child Adolesc Psychiatry. Oct. 1998;37(10 Suppl):4S-26S. [pmid: 9785726].
Puffer M, Greenwald R, Elrod D. A single session EMDR study with twenty traumatised children and adolescents. Traumatology. 1997;3(2).
170 Putnam FW. Dissociation in children and adolescents: a developmental perspective. New York. Guilford Press. 1997.
Qouta S, Punamki RL, El Sarraj E. Child development and family mental health in war and military violence: The Palestinian experience. International Journal of Behavioral Development. Jul. 2008;32(4):310-21. PMID: ISI:000258114300007.
Rana M, Khanzode L, Karnik N, et al. Divalproex sodium in the treatment of pediatric psychiatric disorders. Expert Rev Neurother. Mar. 2005;5(2):165-76. [pmid: 15853487].
Robertson M, Humphreys L, Ray R. Psychological treatments for posttraumatic stress disorder: recommendations for the clinician based on a review of the literature. J Psychiatr Pract. Mar. 2004;10(2):106-18. [pmid: 15330406].
Roelofse JA, Van der Bijl P, Moore PA. Comparison of rectal midazolam and diazepam for premedication in pediatric dental patients. Journal of Oral and Maxillofacial Surgery. 1993;51(5):525-9. [pmid: 8478759].
Rogosch FA, Cicchetti D, Aber JL. The Role of Child Maltreatment in Early Deviations in Cognitive and Affective Processing Abilities and Later Peer Relationship Problems. Development and Psychopathology. Fal. 1995;7(4):591-609. PMID: ISI:A1995TF89400002.
Ronan KR. Behaviourally-based interventions for children following volcanic eruptions: an evaluation of effectiveness. Disaster prevention and management. 1999;8(3):169-76.
Ruzek JI, Brymer MJ, Jacobs AK, et al. Psychological First Aid. Journal of Mental Health Counseling. 2007;29(1):17-49. PMID: 2007-01603-003. First Author & Affiliation: Ruzek, Josef I.
Sack WH, Clarke G, Him C, et al. A 6-year follow-up study of Cambodian refugee adolescents traumatized as children. J Am Acad Child Adolesc Psychiatry. Mar. 1993;32(2):431-7. [pmid: 8444775].
Saigh PA, Yule W, Inamdar SC. Imaginal flooding of traumatized children and adolescents. Journal of School Psychology. Sum. 1996;34(2):163-83. PMID: ISI:A1996UL37200005.
Saltzman WR, Pynoos RS, Layne CM, et al. School-based trauma and grief intervention for adolescents. The Prevention Researcher. 2003;10(2):8-11.
Saltzman WR, Steinberg AM, Layne CM, et al. A developmental approach to school-based treatment of adolescents exposed to trauma and traumatic loss. Journal of Child & Adolescent Group Therapy. 2001;11(2-3):43-56. PMID: 2002-13067-001. First Author & Affiliation: Saltzman, William R.
Saxe GN, Ellis BH, Fogler J, et al. Innovations in practice: Preliminary evidence for effective family engagement in treatment for child traumatic stress–trauma systems therapy approach to preventing dropout. Child and Adolescent Mental Health. 2012;17(1):58-61. PMID: 2011-30029-009. First Author & Affiliation: Saxe, Glenn N.
Saxe GN, Ellis HB, Kaplow JB. Collaborative treatment of traumatized children and teens : the trauma systems therapy approach. New York. The Guilford Press. 2007.
Schaal S, Elbert T. Ten years after the genocide: trauma confrontation and posttraumatic stress in Rwandan adolescents. J Trauma Stress. Feb. 2006;19(1):95-105. [pmid: 16568463].
Schafer I, Barkmann C, Riedesser P, et al. Posttraumatic syndromes in children and adolescents after road traffic accidents--a prospective cohort study. Psychopathology. 2006;39(4):159-64. [pmid: 16612135].
Schauer E. Trauma Treatment for Children in War: Build-up of an Evidence-based Large-scale Mental Health Intervention in North-Eastern Sri Lanka. University of Konstanz. 2008.
Scheeringa MS, Weems CF, Cohen JA, et al. Trauma-focused cognitive-behavioral therapy for posttraumatic stress disorder in three-through six year-old children: a randomized clinical trial. J Child Psychol Psychiatry. Aug. 2011;52(8):853-60. [pmid: 21155776].
Scheeringa MS, Wright MJ, Hunt JP, et al. Factors affecting the diagnosis and prediction of PTSD symptomatology in children and adolescents. Am J Psychiatry. Apr. 2006;163(4):644-51. [pmid: 16585439].
Scheeringa MS, Zeanah CH, Myers L, et al. Predictive validity in a prospective follow-up of PTSD in preschool children. J Am Acad Child Adolesc Psychiatry. Sep. 2005;44(9):899-906. [pmid: 16113618].
Schwab-Stone ME, Ayers TS, Kasprow W, et al. No Safe Haven - a Study of Violence Exposure in an Urban-Community. Journal of the American Academy of Child and Adolescent Psychiatry. Oct. 1995;34(10):1343-52. PMID: ISI:A1995RX16500020. [pmid: 7592272].
Schwarz ED, Perry BD. The post-traumatic response in children and adolescents. Psychiatr Clin North Am. Jun. 1994;17(2):311-26. [pmid: 7937362].
Scott RW, Mughelli K, Deas D. An overview of controlled studies of anxiety disorders treatment in children and adolescents. J Natl Med Assoc. Jan. 2005;97(1):13-24. [pmid: 15719867].
Scrimin S, Axia G, Capello F, et al. Posttraumatic reactions among injured children and their caregivers 3 months after the terrorist attack in Beslan. Psychiatry Res. Mar. 30. 2006;141(3):333-6. [pmid: 16515809].
Scrimin S, Moscardino U, Capello F, et al. Trauma reminders and PTSD symptoms in children three years after a terrorist attack in Beslan. Soc Sci Med. Mar. 2011;72(5):694-700. [pmid: 21255892].
Seng JS, Graham-Bermann SA, Clark MK, et al. Posttraumatic stress disorder and physical comorbidity among female children and adolescents: results from service-use data. Pediatrics. Dec. 2005;116(6):e767-76. [pmid: 16322133].
Shalev AY, Ankri Y, Israeli-Shalev Y, et al. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach And Prevention study. Arch Gen Psychiatry. Feb. 2012;69(2):166-76. [pmid: 21969418].
Shaw JA, Applegate B, Tanner S, et al. Psychological effects of Hurricane Andrew on an elementary school population. J Am Acad Child Adolesc Psychiatry. Sep. 1995;34(9):1185-92. [pmid: 7559313].
Sherwin TS, Green SM, Khan A, et al. Does adjunctive midazolam reduce recovery agitation after ketamine sedation for pediatric procedures? A randomized, double-blind, placebo-controlled trial. Annals of Emergency Medicine. 2000;35(3):229-38. [pmid: 10692189].
Shortt AL, Barrett PM, Fox TL. Evaluating the FRIENDS Program: A cognitive-behavioral group treatment for anxious children and their parents. Journal of Clinical Child Psychology. 2001;30(4):525-35. PMID: 2001-11979-008. First Author & Affiliation: Shortt, Alison L. [pmid: 11708240].
Simeon JG, Ferguson HB, Knott V, et al. Clinical, cognitive, and neurophysiological effects of alprazolam in children and adolescents with overanxious and avoidant disorders. J Am Acad Child Adolesc Psychiatry. Jan. 1992;31(1):29-33. [pmid: 1537778].
Sinclair E, Salmon K, Bryant RA. The role of panic attacks in acute stress disorder in children. J Trauma Stress. Dec. 2007;20(6):1069-73. [pmid: 18157894].
Smith DK, Leve LD, Chamberlain P. Preventing internalizing and externalizing problems in girls in foster care as they enter middle school: impact of an intervention. Prev Sci. Sep. 2011;12(3):269-77. [pmid: 21475990].
Smith P, Perrin S, Yule W, et al. War exposure among children from Bosnia-Hercegovina: psychological adjustment in a community sample. J Trauma Stress. Apr. 2002;15(2):147-56. [pmid: 12013066].
Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: The effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. Journal of Child Psychology and Psychiatry. 2000;41(6):713-26. PMID: 2000-00865-004. First Author & Affiliation: Spence, Susan H. [pmid: 11039684].
Stallard P, Law F. Screening and psychological debriefing of adolescent survivors of life-threatening events. Br J Psychiatry. Nov. 1993;163:660-5. [pmid: 8298836].
Stallard P, Salter E, Velleman R. Posttraumatic stress disorder following road traffic accidents - a second prospective study. Eur Child Adolesc Psychiatry. Jun. 2004;13(3):172-8. [pmid: 15254845].
Stallard P, Velleman R, Langsford J, et al. Coping and psychological distress in children involved in road traffic accidents. Br J Clin Psychol. Jun. 2001;40(Pt 2):197-208. [pmid: 11446241].
Stein B, Comer D, Gardner W, et al. Prospective study of displaced children's symptoms in wartime Bosnia. Soc Psychiatry Psychiatr Epidemiol. Sep. 1999;34(9):464-9. [pmid: 10541666].
Steiner H, Garcia IG, Matthews Z. Posttraumatic stress disorder in incarcerated juvenile delinquents. J Am Acad Child Adolesc Psychiatry. Mar. 1997;36(3):357-65. [pmid: 9055516].
Sturms LM, van der Sluis CK, Stewart RE, et al. A prospective study on paediatric traffic injuries: health-related quality of life and post-traumatic stress. Clin Rehabil. May. 2005;19(3):312-22. [pmid: 15859532].
Thabet AA, Abed Y, Vostanis P. Emotional problems in Palestinian children living in a war zone: a cross-sectional study. Lancet. May. 25. 2002;359(9320):1801-4. [pmid: 12044374].
Thabet AA, Abu Tawahina A, El Sarraj E, et al. Exposure to war trauma and PTSD among parents and children in the Gaza strip. Eur Child Adolesc Psychiatry. Jun. 2008;17(4):191-9. [pmid: 18365135].
Thienkrua W, Cardozo BL, Chakkraband ML, et al. Symptoms of posttraumatic stress disorder and depression among children in tsunami-affected areas in southern Thailand. JAMA. Aug. 2. 2006;296(5):549-59. [pmid: 16882961].
Tonkins SAM, Lambert MJ. A treatment outcome study of bereavement groups for children. Child and Adolescent Social Work Journal. 1996;13(1):3-21. 64570.
Toth SL, Rogosch FA, Manly JT, et al. The efficacy of toddler-parent psychotherapy to reorganize attachment in the young offspring of mothers with major depressive disorder: a randomized preventive trial. J Consult Clin Psychol. Dec. 2006;74(6):1006-16. [pmid: 17154731].
van der Kolk BA. The body keeps the score: Memory and the evolving psychobiology of posttraumatic stress. Horowitz MJ, editor. Essential papers on posttraumatic stress disorder. New York, NY US. New York University Press. 1999:301-26.
van der Kolk BA, Pelcovitz D, Roth S, et al. Dissociation, somatization, and affect dysregulation: The complexity of adaption to trauma. The American Journal of Psychiatry. 1996;153(Suppl):83-93. PMID: 1996-00460-008. Partial author list. First Author & Affiliation: van der Kolk, Bessel A. [pmid: 8659645].
Van Etten ML, Taylor S. Comparative efficacy of treatments for post-traumatic stress disorder: A meta-analysis. Clinical Psychology & Psychotherapy. Sep. 1998;5(3):126-44. PMID: ISI:000076455300001.
Vernberg EM, Steinberg AM, Jacobs AK, et al. Innovations in disaster mental health: Psychological first aid. Professional Psychology-Research and Practice. Aug. 2008;39(4):381-8. PMID: ISI:000258613400001.
Vickers B. Cognitive behaviour therapy for adolescents with psychological disorders: A group treatment programme. Clinical Child Psychology and Psychiatry. 2002;7(2):249-62. PMID: 2002-13308-009. First Author & Affiliation: Vickers, Bea.
Vijayakumar L, Kannan GK, Kumar BG, et al. Do all children need intervention after exposure to tsunami?. International Review of Psychiatry. Dec. 2006;18(6):515-22. PMID: ISI:000242763900005. [pmid: 17162691].
Walker J. The use of oral midazolam in accident and emergency to reduce anxiety in children. Accident and emergency nursing. 1996;4(3):110-3. [pmid: 8920391].
Weiner DA, Schneider A, Lyons JS. Evidence-based treatments for trauma among culturally diverse foster care youth: Treatment retention and outcomes. Children and Youth Services Review. Nov. 2009;31(11):1199-205. PMID: ISI:000271799100008.
Willemsen H, Chowdhury U, Briscall L. Needle Phobia in Children: A Discussion of Aetiology and Treatment Options. Clinical Child Psychology & Psychiatry. 2002;7(4):609-19. [pmid: 9450529].
Wilson DL. An outcome study of a time-limited group intervention program for bereaved children. [9512796]. United States -- Washington. Washington State University. 1994.
Yule W. Post-traumatic stress disorder in child survivors of shipping disasters: the sinking of the ‘Jupiter’. Psychother Psychosom. 1992;57(4):200-5. [pmid: 1410197].
Zebrowski CA. Bereaved African-American children at risk: Testing an intervention. [9969841]. United States -- District of Columbia. The George Washington University. 2000.
Zehnder D, Meuli M, Landolt MA. Effectiveness of a single-session early psychological intervention for children after road traffic accidents: a randomised controlled trial. Child Adolesc Psychiatry Ment Health. 2010;4:7. [pmid: 20181120].
Zink KA, McCain GC. Post-traumatic stress disorder in children and adolescents with motor vehicle-related injuries. J Spec Pediatr Nurs. Jul-Sep. 2003;8(3):99-106. [pmid: 12942888].
Zwier KJ, Rao U. Buspirone Use in an Adolescent with Social Phobia and Mixed Personality-Disorder (Cluster a-Type). Journal of the American Academy of Child and Adolescent Psychiatry. Sep. 1994;33(7):1007-11. PMID: ISI:A1994PD46600011. [pmid: 7961339].