# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th Edition. Text Revision (DSM-IV-TR). Arlington, VA. American Psychiatric Association. 2000.
2 Gaynes BN, Gavin N, Meltzer-Brody S, et al. Perinatal Depression: Prevalence, Screening Accuracy, and Screening Outcomes. Evidence Report/Technology Assessment No. 119. (Prepared by RTI–University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E006-2.
3 Gaynes BN, Gavin N, Meltzer-Brody S, et al. Perinatal depression: prevalence, screening accuracy, and screening outcomes. Evid Rep Technol Assess (Summ). 2005;(119):1-8. [pmid: 15760246].
4 The Institute of Medicine. Depression in Parents, Parenting, and Children: Opportunities to Improve Identification, Treatment, and Prevention. 2009. http://books.nap.edu/openbook.php?record_id=12565. Accessed: October 9, 2012.
5 O’Connor EA, Whitlock EP, Gaynes B, et al. Screening for Depression in Adults and Older Adults in Primary Care: An Updated Systematic Review. Evidence Synthesis No. 75. AHRQ Publication No. 10-05143-EF-1. Rockville, Maryland. Agency for Healthcare Research and Quality. December. 2009. http://www.ncbi.nlm.nih.gov/books/NBK36406/. Accessed October 10, 2012. [pmid: 20722174].
6 Appleby L. Suicide during pregnancy and in the first postnatal year. BMJ. 1991;302(6769):137-40. [pmid: 1995132].
7 Lindahl V, Pearson JL, Colpe L. Prevalence of suicidality during pregnancy and the postpartum. Arch Women Ment Health. 2005;8(2):77-87. [pmid: 15883651].
8 Oates M. Perinatal psychiatric disorders: a leading cause of maternal morbidity and mortality. Br Med Bull. 2003;67:219-29. [pmid: 14711766].
9 Spinelli MG. Maternal infanticide associated with mental illness: prevention and the promise of saved lives. Am J Psychiatry. 2004;161(9):1548-57. [pmid: 15337641].
10 McLearn KT, Minkovitz CS, Strobino DM, et al. Maternal depressive symptoms at 2 to 4 months post partum and early parenting practices. Arch Pediatr Adolesc Med. 2006;160(3):279-84. [pmid: 16520447].
11 Chaudron LH, Szilagyi PG, Campbell AT, et al. Legal and ethical considerations: risks and benefits of postpartum depression screening at well-child visits. Pediatrics. 2007;119(1):123-8. [pmid: 17200279].
12 Gjerdingen DK, Yawn BP. Postpartum depression screening: importance, methods, barriers, and recommendations for practice. J Am Board Fam Med. 2007;20(3):280-8. [pmid: 17478661].
13 Ng RC, Hirata CK, Yeung W, et al. Pharmacologic treatment for postpartum depression: a systematic review. Pharmacotherapy. 2010;30(9):928-41. [pmid: 20795848].
14 Dennis CL, Hodnett E. Psychosocial and psychological interventions for treating postpartum depression. Cochrane Database Syst Rev. 2007;4:CD006116. [pmid: 17943888].
15 Hewitt C, Gilbody S, Brealey S, et al. Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis. Health Technol Assess. 2009;13(36):1-145. 7. 230. [pmid: 19624978].
16 Gunlicks ML, Weissman MM. Change in child psychopathology with improvement in parental depression: a systematic review. J Am Acad Child Adolesc Psychiatry. 2008;47(4):379-89. [pmid: 18388766].
17 Wickramaratne P, Gameroff MJ, Pilowsky DJ, et al. Children of depressed mothers 1 year after remission of maternal depression: findings from the STAR*D-Child study. Am J Psychiatry. 2011;168(6):593-602. [pmid: 21406462].
18 U. S. Preventive Services Task Force. Screening for depression in adults: U.S. preventive services task force recommendation statement. Ann Intern Med. 2009;151(11):784-92. [pmid: 19949144].
19 Barbui C, Cipriani A, Patel V, et al. Efficacy of antidepressants and benzodiazepines in minor depression: systematic review and meta-analysis. Br J Psychiatry. 2011;198(1):11-6. [pmid: 21200071].
20 American College of Obstetricians and Gynecologists, Committee on Obstetric Practice. Committee opinion no. 453: Screening for depression during and after pregnancy. Obstet Gynecol. 2010;115(2 Pt 1):394-5. [pmid: 20093921].
21 Eberhard-Gran M, Eskild A, Tambs K, et al. Depression in postpartum and non-postpartum women: prevalence and risk factors. Acta Psychiatr Scand. 2002;106(6):426-33. [pmid: 12392485].
22 Josefsson A, Angelsiöö L, Berg G, et al. Obstetric, somatic, and demographic risk factors for postpartum depressive symptoms. Obstet Gynecol. 2002;99(2):223-8. [pmid: 11814501].
23 McCoy SJ, Beal JM, Shipman SB, et al. Risk factors for postpartum depression: a retrospective investigation at 4-weeks postnatal and a review of the literature. J Am Osteopath Assoc. 2006;106(4):193-8. [pmid: 16627773].
24 Robertson E, Grace S, Wallington T, et al. Antenatal risk factors for postpartum depression: a synthesis of recent literature. Gen Hosp Psychiatry. 2004;26(4):289-95. [pmid: 15234824].
25 Vesga-Lopez O, Blanco C, Keyes K, et al. Psychiatric disorders in pregnant and postpartum women in the United States. Arch Gen Psychiatry. 2008;65(7):805-15. [pmid: 18606953].
26 Earls MF. Incorporating recognition and management of perinatal and postpartum depression into pediatric practice. Pediatrics. 2010;126(5):1032-9. [pmid: 20974776].
27 Kozhimannil KB, Adams AS, Soumerai SB, et al. New Jersey’s efforts to improve postpartum depression care did not change treatment patterns for women on Medicaid. Health Aff (Millwood). 2011;30(2):293-301. [pmid: 21289351].
28 National Institute for Health Care Management. Identifying and Treating Maternal Depression: Strategies & Considerations for Health Plans. NIHCM Foundation Issue Brief. June. 2010. http://nihcm.org/pdf/FINAL_MaternalDepression6-7.pdf. Accessed October 10, 2012.
29 Hirst KP, Moutier CY. Postpartum major depression. Am Fam Physician. 2010;82(8):926-33. [pmid: 20949886].
30 American College of Nurse Midwives, Division of Women’s Health Policy and Leadership. Position statement: depression in women. 2003. www.midwife.org/siteFiles/position/Depression_in_Women_05.pdf. Accessed August 10, 2011.
31 National Institute for Health and Clinical Excellence. Antenatal and Postnatal Mental Health: Clinical Management and Service Guidance. NICE Clinical Guideline 45. Developed by the National Collaborating Centre for Mental Health. London. National Institute for Health and Clinical Excellence. 2007. http://guidance.nice.org.uk/CG45/NICEGuidance/pdf/English. Accessed August 10, 2011.
32 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed January 3, 2012.
33 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Rockville, MD. Agency for Healthcare Research and Quality. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=558. Accessed January 3, 2012.
34 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
35 Evidence-based Practice Center Systematic Review Protocol. Project Title: Efficacy and Safety of Screening for Postpartum Depression. March. 9. 2012. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=997. Accessed June 21, 2012.
36 Austin MP, Priest SR, Sullivan EA. Antenatal psychosocial assessment for reducing perinatal mental health morbidity. Cochrane Database Syst Rev. 2008;4:CD005124. [pmid: 18843682].
37 Bennett HA, Einarson A, Taddio A, et al. Prevalence of depression during pregnancy: systematic review. Obstet Gynecol. 2004;103(4):698-709. [pmid: 15051562].
38 Boyd RC, Le HN, Somberg R. Review of screening instruments for postpartum depression. Arch Women Ment Health. 2005;8(3):141-53. [pmid: 16133785].
39 Cuijpers P, Van Straten A, Warmerdam L, et al. Characteristics of effective psychological treatments of depression: a metaregression analysis. Psychother Res. 2008;18(2):225-36. [pmid: 18815968].
40 DeBackere KJ, Hill PD, Kavanaugh KL. The parental experience of pregnancy after perinatal loss. J Obstet Gynecol Neonatal Nurs. 2008;37(5):525-37. [pmid: 18811772].
41 Downe SM, Butler E, Hinder S. Screening tools for depressed mood after childbirth in UK-based South Asian women: a systematic review. J Adv Nurs. 2007;57(6):565-83. [pmid: 17346316].
42 Gibson J, McKenzie-McHarg K, Shakespeare J, et al. A systematic review of studies validating the Edinburgh Postnatal Depression Scale in antepartum and postpartum women. Acta Psychiatr Scand. 2009;119(5):350-64. [pmid: 19298573].
43 Gjerdingen D, Katon W, Rich DE. Stepped care treatment of postpartum depression: a primary care-based management model. Womens Health Issues. 2008;18(1):44-52. [pmid: 18215764].
44 Goldbort J. Transcultural analysis of postpartum depression. MCN Am J Matern Child Nurs. 2006;31(2):121-6. [pmid: 16523038].
45 Goodman JH. Postpartum depression beyond the early postpartum period. J Obstet Gynecol Neonatal Nurs. 2004;33(4):410-20. [pmid: 15346666].
46 Halbreich U, Karkun S. Cross-cultural and social diversity of prevalence of postpartum depression and depressive symptoms. J Affect Disord. 2006;91(2–3):97-111. [pmid: 16466664].
47 Hewitt CE, Gilbody SM. Is it clinically and cost effective to screen for postnatal depression: a systematic review of controlled clinical trials and economic evidence. BJOG. 2009;116(8):1019-27. [pmid: 19438499].
48 Klainin P, Arthur DG. Postpartum depression in Asian cultures: a literature review. Int J Nurs Stud. 2009;46(10):1355-73. [pmid: 19327773].
49 Kroenke K, Spitzer RL, Williams JB, et al. The Patient Health Questionnaire Somatic, Anxiety, and Depressive Symptom Scales: a systematic review. Gen Hosp Psychiatry. 2010;32(4):345-59. [pmid: 20633738].
50 Leddy MA, Lawrence H, Schulkin J. Obstetrician-gynecologists and women’s mental health: findings of the Collaborative Ambulatory Research Network 2005–2009. Obstet Gynecol Surv. 2011;66(5):316-23. [pmid: 21794195].
51 Mann R, Gilbody S. Validity of two case finding questions to detect postnatal depression: a review of diagnostic test accuracy. J Affect Disord. 2011;133(3):388-97. [pmid: 21146230].
52 Mian AI. Depression in pregnancy and the postpartum period: balancing adverse effects of untreated illness with treatment risks. J Psychiatr Pract. 2005;11(6):389-96. [pmid: 16304507].
53 Minkovitz CS, Strobino D, Scharfstein D, et al. Maternal depressive symptoms and children’s receipt of health care in the first 3 years of life. Pediatrics. 2005;115(2):306-14. [pmid: 15687437].
54 O’Mahony J, Donnelly T. Immigrant and refugee women’s post-partum depression help-seeking experiences and access to care: a review and analysis of the literature. J Psychiatr Ment Health Nurs. 2010;17(10):917-28. [pmid: 21078007].
55 Ross LE, Campbell VL, Dennis CL, et al. Demographic characteristics of participants in studies of risk factors, prevention, and treatment of postpartum depression. Can J Psychiatry. 2006;51(11):704-10. [pmid: 17121169].
56 Shaw E, Levitt C, Wong S, et al. Systematic review of the literature on postpartum care: effectiveness of postpartum support to improve maternal parenting, mental health, quality of life, and physical health. Birth. 2006;33(3):210-20. [pmid: 16948721].
57 Wylie L, Hollins Martin CJ, Marland G, et al. The enigma of post-natal depression: an update. J Psychiatr Ment Health Nurs. 2011;18(1):48-58. [pmid: 21214684].
58 Yozwiak JA. Postpartum depression and adolescent mothers: a review of assessment and treatment approaches. J Pediatr Adolesc Gynecol. 2010;23(3):172-8. [pmid: 20496498].
59 Zubaran C, Schumacher M, Roxo MR, et al. Screening tools for postpartum depression: validity and cultural dimensions. Afr J Psychiatry (Johannesbg). 2010;13(5):357-65. [pmid: 21390406].
60 Brealey SD, Hewitt C, Green JM, et al. Screening for postnatal depression—Is it acceptable to women and healthcare professionals? A systematic review and meta-synthesis. Journal of Reproductive and Infant Psychology. 2010;28(4):328-44.
61 Hewitt CE, Gilbody SM, Mann R, et al. Instruments to identify post-natal depression: Which methods have been the most extensively validated, in what setting and in which language?. International Journal of Psychiatry in Clinical Practice. 2010;14(1):72-6.
62 Matthey S. Detection and treatment of postnatal depression (perinatal depression or anxiety). Current Opinion in Psychiatry. 2004;17(1):21-9.
63 Brealey SD, Hewitt C, Green JM, et al. Screening for postnatal depression - is it acceptable to women and healthcare professionals? A systematic review and meta-synthesis. Journal of Reproductive and Infant Psychology. 2010;28(4):328-44.
64 Farneti C, Farneti M. Review of postpartum depression: A pathology also for pediatricians?. Acta Medica Mediterranea. 2009;25(3):153-61.
65 Cuijpers P, Brannmark JG, van Straten A. Psychological treatment of postpartum depression: a meta-analysis. J Clin Psychol. 2008;64(1):103-18. [pmid: 18161036].
66 Dennis CL, Chung-Lee L. Postpartum depression help-seeking barriers and maternal treatment preferences: a qualitative systematic review. Birth. 2006;33(4):323-31. [pmid: 17150072].
67 Dennis CL, Kingston D. A systematic review of telephone support for women during pregnancy and the early postpartum period. J Obstet Gynecol Neonatal Nurs. 2008;37(3):301-14. [pmid: 18507601].
68 Eberhard-Gran M, Eskild A, Tambs K, et al. Review of validation studies of the Edinburgh Postnatal Depression Scale. Acta Psychiatr Scand. 2001;104(4):243-9. [pmid: 11722298].
69 Dennis CL, Creedy D. Psychosocial and psychological interventions for preventing postpartum depression. Cochrane Database Syst Rev. 2004;4:CD001134. [pmid: 15495008].
70 Austin MP, Lumley J. Antenatal screening for postnatal depression: a systematic review. Acta Psychiatr Scand. 2003;107(1):10-7. [pmid: 12558536].
71 Fisher J, Cabral de Mello M, Patel V, et al. Prevalence and determinants of common perinatal mental disorders in women in low- and lower-middle-income countries: a systematic review. Bull World Health Organ. 2012;90(2):139G-49G. [pmid: 22423165].
72 Wu Q, Chen HL, Xu XJ. Violence as a risk factor for postpartum depression in mothers: a meta-analysis. Arch Women Ment Health. 2012;15(2):107-14. [pmid: 22382278].
73 The World Bank. Country and lending groups. http://data.worldbank.org/about/country-classifications/country-and-lending-groups. Accessed January 3, 2012.
74 Whiting PF, Rutjes AWS, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
75 Harbord RM, Whiting P, Sterne JA, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. J Clin Epidemiol. 2008;61(11):1095-103. [pmid: 19208372].
76 Menke J. Bivariate random-effects meta-analysis of sensitivity and specificity with SAS PROC GLIMMIX. Methods Inf Med. 2010;49(1):54-62. −4. [pmid: 19936437].
77 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
78 Myers ER, Misurski DA, Swamy GK. Influence of timing of seasonal influenza vaccination on effectiveness and cost-effectiveness in pregnancy. Am J Obstet Gynecol. 2011;204(6 Suppl 1):S128-40. [pmid: 21640230].
79 Ungar WJ, editor. Economic Evaluation in Child Health. New York. Oxford University Press. 2010.
80 Myers E, Sanders GD, Ravi D, et al. Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Center Program. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I). AHRQ Publication No. 11-EHC030-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed January 3, 2012.
81 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
82 Austin MP, Colton J, Priest S, et al. The Antenatal Risk Questionnaire (ANRQ): Acceptability and use for psychosocial risk assessment in the maternity setting. Women Birth. 2011. Jul. 16. [Epub ahead of print]. Women Birth. 2011. [pmid: 21764399].
83 Austin MP, Hadzi-Pavlovic D, Priest SR, et al. Depressive and anxiety disorders in the postpartum period: how prevalent are they and can we improve their detection?. Arch Women Ment Health. 2010;13(5):395-401. [pmid: 20232218].
84 Beck CT, Gable RK. Screening performance of the postpartum depression screening scale—Spanish version. J Transcult Nurs. 2005;16(4):331-8. [pmid: 16160195].
85 Chaudron LH, Szilagyi PG, Tang W, et al. Accuracy of depression screening tools for identifying postpartum depression among urban mothers. Pediatrics. 2010;125(3):e609-17. [pmid: 20156899].
86 Clarke PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. 2008;40(1):113-25. [pmid: 18459275].
87 Csatordai S, Kozinszky Z, Devosa I, et al. Validation of the Leverton Questionnaire as a screening tool for postnatal depression in Hungary. Gen Hosp Psychiatry. 2009;31(1):56-66. [pmid: 19134511].
88 Edmondson OJ, Psychogiou L, Vlachos H, et al. Depression in fathers in the postnatal period: assessment of the Edinburgh Postnatal Depression Scale as a screening measure. J Affect Disord. 2010;125(1–3):365-8. [pmid: 20163873].
89 Felice E, Saliba J, Grech V, et al. Validation of the Maltese version of the Edinburgh Postnatal Depression Scale. Arch Women Ment Health. 2006;9(2):75-80. [pmid: 16172837].
90 Felice E, Saliba J, Grech V, et al. Prevalence rates and psychosocial characteristics associated with depression in pregnancy and postpartum in Maltese women. J Affect Disord. 2004;82(2):297-301. [pmid: 15488261].
91 Gjerdingen D, Crow S, McGovern P, et al. Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. 2009;7(1):63-70. [pmid: 19139451].
92 Gjerdingen D, McGovern P, Center B. Problems with a diagnostic depression interview in a postpartum depression trial. J Am Board Fam Med. 2011;24(2):187-93. [pmid: 21383219].
93 Hamdan A, Tamim H. Psychosocial risk and protective factors for postpartum depression in the United Arab Emirates. Arch Women Ment Health. 2011;14(2):125-33. [pmid: 21063891].
94 Howard LM, Flach C, Mehay A, et al. The prevalence of suicidal ideation identified by the Edinburgh Postnatal Depression Scale in postpartum women in primary care: findings from the RESPOND trial. BMC Pregnancy Childbirth. 2011;11:57. [pmid: 21812968].
95 Jardri R, Pelta J, Maron M, et al. Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. 2006;93(1–3):169-76. [pmid: 16644021].
96 Ji S, Long Q, Newport DJ, et al. Validity of depression rating scales during pregnancy and the postpartum period: impact of trimester and parity. J Psychiatr Res. 2011;45(2):213-9. [pmid: 20542520].
97 Navarro P, Ascaso C, Garcia-Esteve L, et al. Postnatal psychiatric morbidity: a validation study of the GHQ-12 and the EPDS as screening tools. Gen Hosp Psychiatry. 2007;29(1):1-7. [pmid: 17189737].
98 Pereira AT, Bos S, Marques M, et al. The Portuguese version of the postpartum depression screening scale. J Psychosom Obstet Gynaecol. 2010;31(2):90-100. [pmid: 20443658].
99 Mauri M, Oppo A, Borri C, et al. SUICIDALITY in the perinatal period: comparison of two self-report instruments. Results from PND-ReScU. Arch Women Ment Health. 2012;15(1):39-47. [pmid: 22215284].
100 Mann R, Adamson J, Gilbody SM. Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. 2012;184(8):E424-30. [pmid: 22451686].
101 Ekeroma AJ, Ikenasio-Thorpe B, Weeks S, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) as a screening tool for postnatal depression in Samoan and Tongan women living in New Zealand. N Z Med J. 2012;125(1355):41-9. [pmid: 22722214].
102 Akincigil A, Munch S, Niemczyk KC. Predictors of maternal depression in the first year postpartum: marital status and mediating role of relationship quality. Soc Work Health Care. 2010;49(3):227-44. [pmid: 20229395].
103 Andersson L, Sundstrom-Poromaa I, Wulff M, et al. Depression and anxiety during pregnancy and six months postpartum: a follow-up study. Acta Obstet Gynecol Scand. 2006;85(8):937-44. [pmid: 16862471].
104 Barnes J, Senior R, MacPherson K. The utility of volunteer home-visiting support to prevent maternal depression in the first year of life. Child Care Health Dev. 2009;35(6):807-16. [pmid: 19719770].
105 Beck CT, Froman RD, Bernal H. Acculturation level and postpartum depression in Hispanic mothers. MCN Am J Matern Child Nurs. 2005;30(5):299-304. [pmid: 16132006].
106 Bloch M, Rotenberg N, Koren D, et al. Risk factors associated with the development of postpartum mood disorders. J Affect Disord. 2005;88(1):9-18. [pmid: 15979150].
107 Boyce P, Hickey A. Psychosocial risk factors to major depression after childbirth. Soc Psychiatry Psychiatr Epidemiol. 2005;40(8):605-12. [pmid: 16096700].
108 Chee CY, Chong YS, Ng TP, et al. The association between maternal depression and frequent non-routine visits to the infant’s doctor—a cohort study. J Affect Disord. 2008;107(1–3):247-53. [pmid: 17869346].
109 Chee CY, Lee DT, Chong YS, et al. Confinement and other psychosocial factors in perinatal depression: a transcultural study in Singapore. J Affect Disord. 2005;89(1–3):157-66. [pmid: 16257451].
110 Garcia-Esteve L, Navarro P, Ascaso C, et al. Family caregiver role and premenstrual syndrome as associated factors for postnatal depression. Arch Women Ment Health. 2008;11(3):193-200. [pmid: 18506575].
111 Mauri M, Oppo A, Montagnani MS, et al. Beyond “postpartum depressions”: specific anxiety diagnoses during pregnancy predict different outcomes: results from PND-ReScU. J Affect Disord. 2010;127(1–3):177-84. [pmid: 20554326].
112 Turner K, Piazzini A, Franza A, et al. Epilepsy and postpartum depression. Epilepsia. 2009;50(Suppl 1):24-7. [pmid: 19125843].
113 Verkerk GJ, Denollet J, Van Heck GL, et al. Personality factors as determinants of depression in postpartum women: a prospective 1-year follow-up study. Psychosom Med. 2005;67(4):632-7. [pmid: 16046379].
114 Kersting A, Kroker K, Steinhard J, et al. Complicated grief after traumatic loss: A 14-month follow up study. Eur Arch Psychiatry Clin Neurosci. 2007;257(8):437-43. [pmid: 17629729].
115 Siu BWM, Leung SSL, Ip P, et al. Antenatal risk factors for postnatal depression: A prospective study of chinese women at maternal and child health centres. BMC Psychiatry. 2012;12(22).
116 Crotty F, Sheehan J. Prevalence and detection of postnatal depression in an Irish community sample. Ir J Psychol Med. 2004;21(4):117-21.
117 Zlotnick C, Miller IW, Pearlstein T, et al. A preventive intervention for pregnant women on public assistance at risk for postpartum depression. Am J Psychiatry. 2006;163(8):1443-5. [pmid: 16877662].
118 Leung SS, Leung C, Lam TH, et al. Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292-301. [pmid: 20884642].
119 Yawn BP, Dietrich AJ, Wollan P, et al. TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Ann Fam Med. 2012;10(4):320-9. [pmid: 22778120].
120 Morrell CJ, Slade P, Warner R, et al. Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: Pragmatic cluster randomised trial in primary care. BMJ. 2009;338(7689):276-9.
121 Glavin K, Smith L, Sorum R, et al. Redesigned community postpartum care to prevent and treat postpartum depression in women—a one-year follow-up study. J Clin Nurs. 2010;19(21–22):3051-62. [pmid: 20726926].
122 Cooper PJ, Murray L, Hooper R, et al. The development and validation of a predictive index for postpartum depression. Psychol Med. 1996;26(3):627-34. [pmid: 8733220].
123 Goodman JH, Tyer-Viola L. Detection, treatment, and referral of perinatal depression and anxiety by obstetrical providers. J Womens Health (Larchmt). 2010;19(3):477-90. [pmid: 20156110].
124 Rowan P, Greisinger A, Brehm B, et al. Outcomes from implementing systematic antepartum depression screening in obstetrics. Arch Women Ment Health. 2012;15(2):115-20. [pmid: 22382279].
125 Burton A, Patel S, Kaminsky L, et al. Depression in pregnancy: time of screening and access to psychiatric care. J Matern Fetal Neonatal Med. 2011;24(11):1321-4. [pmid: 21261444].
126 Flynn HA, O’Mahen HA, Massey L, et al. The impact of a brief obstetrics clinic-based intervention on treatment use for perinatal depression. J Womens Health (Larchmt). 2006;15(10):1195-204. [pmid: 17199460].
127 Yonkers KA, Smith MV, Lin H, et al. Depression screening of perinatal women: an evaluation of the healthy start depression initiative. Psychiatr Serv. 2009;60(3):322-8. [pmid: 19252044].
128 Martin JA, Hamilton BE, Ventura SJ, et al. Births: final data for 2009. Natl Vital Stat Rep. 2011;60(1):1-70. [pmid: 22670489].
129 Meads C, Ahmed I, Riley RD. A systematic review of breast cancer incidence risk prediction models with meta-analysis of their performance. Breast Cancer Res Treat. 2012;132(2):365-77. [pmid: 22037780].
130 American Cancer Society. American Cancer Society Guidelines for Early Breast Cancer Detection in Women without Symptoms. www.cancer.org/Cancer/BreastCancer/MoreInformation/BreastCancerEarlyDetection/breast-cancer-early-detection-acs-recs. Accessed October 16, 2012.
131 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
132 Cohen D, Coco A. Declining trends in the provision of prenatal care visits by family physicians. Ann Fam Med. 2009;7(2):128-33. [pmid: 19273867].
133 Freed GL, Dunham KM, Gebremariam A, et al. Which pediatricians are providing care to America’s children? An update on the trends and changes during the past 26 years. J Pediatr. 2010;157(1):148-52. e1. [pmid: 20227714].
134 Workowski KA, Berman S. Sexually transmitted diseases treatment guidelines, 2010. MMWR Recomm Rep. 2010;59(RR-12):1-110. [pmid: 21160459].
135 Genders TS, Meijboom WB, Meijs MF, et al. CT coronary angiography in patients suspected of having coronary artery disease: decision making from various perspectives in the face of uncertainty. Radiology. 2009;253(3):734-44. [pmid: 19864509].
136 Havrilesky LJ, Sanders GD, Kulasingam S, et al. Development of an ovarian cancer screening decision model that incorporates disease heterogeneity: implications for potential mortality reduction. Cancer. 2011;117(3):545-53. [pmid: 21254049].
137 Office of the Legislative Counsel for the use of the U.S. House of Representatives. Patient Protection and Affordable Care Act. www.healthcare.gov/law/full. Accessed July 25, 2012.
138 National Institutes of Health. Women’s Mental Health During Pregnancy and the Postpartum Period (R01 Research Project Grant). http://grants.nih.gov/grants/guide/pa-files/PA-12-216.html. Accessed July 25, 2012.
139 National Institutes of Health. Women’s Mental Health During Pregnancy and the Postpartum Period (R21 Exploratory/Developmental Research Grant). http://grants.nih.gov/grants/guide/pa-files/PA-12-215.html. Accessed July 25, 2012.
140 Myers E, McBroom AJ, Shen L, et al. Value-of-Information Analysis for Patient-Centered Outcomes Research Prioritization. Prepared by the Duke Evidence-based Practice Center for the Patient-Centered Outcomes Research Institute. March. 9. 2012. www.pcori.org/assets/Value-of-Information-Analysis-for-Patient-Centered-Outcomes-Research-Prioritization.pdf. Accessed July 3, 2012.
141 Wordsworth S, Ryan M, Skatun D, et al. Women’s preferences for cervical cancer screening: a study using a discrete choice experiment. Int J Technol Assess Health Care. 2006;22(3):344-50. [pmid: 16984063].