# Methods

The methods for this Comparative Effectiveness Review (CER) follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter referred to as the Methods Guide)32 and the “Methods Guide for Medical Test Reviews” (hereafter referred to as the Medical Test Guide).33 The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.34

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing medical professional societies/clinicians in the areas of mental health, obstetrics and gynecology, women’s health, pregnancy and perinatal epidemiology, psychiatry, maternal and fetal medicine, pediatrics, and primary care; patients and scientific experts; and payers, to help define the Key Questions (KQs). The KQs were then posted for public comment for 4 weeks from November 8 to December 6, 2011, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP) comprising clinical, content, and methodological experts to provide input in defining populations, interventions, comparisons, and outcomes, and in identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP performed analysis of any kind, nor did any of them contribute to the writing of this report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Website.35

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched PubMed^®^, Embase^®^, PsycINFO^®^, and the Cochrane Database of Systematic Reviews (CDSR), limiting the search to studies published from January 1, 2004, to July 24, 2012 (subsequent to the March 2004 search end date of the 2005 AHRQ evidence review on postpartum depression).2,3 Given the findings of the 2005 review regarding the level of evidence, we chose these dates after consultation with AHRQ, Key Informants, and the TEP in order to maximize efficiency. The primary impediment to formal data synthesis in the 2005 review was study heterogeneity. Therefore, it was unlikely that we would be able to combine literature identified in that report with newer data in any subsequent meta-analyses. This led us to conclude that qualitative comparison of our findings to those of prior reviews would be a more useful approach. Where possible, we used existing validated search filters (such as the Clinical Queries Filters in PubMed). An experienced search librarian guided all searches. Search dates and exact search strings are provided in Appendix A. We supplemented the electronic searches with a manual search of citations from a set of key primary and systematic review articles.3,12,14,15,23,24,36–72 The reference lists from these articles were hand-searched and cross-referenced against our library of database search results. Additional relevant articles not already under consideration were retrieved for screening. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We used several approaches to identify relevant grey literature; these included requests to publishers of proprietary depression screening tools (from among those listed in Table 3) for scientific information packets and searches of trial registries and conference abstracts for relevant articles from completed studies. Grey literature databases included ClinicalTrials.gov; the World Health Organization (WHO) International Clinical Trials Registry Platform (ICTRP) search portal; and ProQuest COS Conference Papers Index. Search dates and exact search terms used for these sources are provided in Appendix A. The search of ClinicalTrials.gov was also used as a mechanism to ascertain publication bias by identifying completed but unpublished studies. During peer and public review of the draft report, we updated all database searches and included any eligible studies identified either through that search or through suggestions from peer and public reviewers.

Table 3 Inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Populations | - Pregnant women and women up to 12 months postpartum; - Subgroups of potential interest include:; ○ Race/ethnicity; ○ Income; ○ Parity; ○ Cultural norms; ○ History of mood disorders; ○ Perinatal outcomes; ○ History of intimate partner violence; - Fathers or domestic partners | - Women currently undergoing treatment for depression; - Studies where the primary objective is to detect depression during pregnancy rather than to identify risk factors for postpartum depression (studies that assessed women prenatally for risk of postpartum depression were not excluded); - Studies exclusively addressing bipolar disorder, a primary psychotic disorder, or maternity blues; or studies that include these populations and do not report results for subjects not fitting these subgroups separately
Interventions | - Screening using a validated screening instrument for depression, including, [underlined: but not necessarily limited to:]; ○ Bromley Postnatal Depression Scale (BPDS); ○ Edinburgh Postnatal Depression Scale (EPDS); ○ Postpartum Depression Screening Scale (PDSS); ○ Leverton Questionnaire (LQ); ○ Center for Epidemiologic Studies Depression Scale (CES-D); ○ Hospital Anxiety and Depression Scale (HADS); ○ Patient Health Questionnaire-9 (PHQ-9); ○ Beck Depression Inventory (BDI-1A, BDI-II); ○ Zung Self-Rating Depression Scale (Zung SDS); ○ Hamilton Rating Scale for Depression (HRSD); ○ Postpartum Depression Predictors Inventory-Revised (PDPI-R); ○ General Health Questionnaire (GHQ-D); ○ Montgomery Asberg Depression Rating Scale (MADRS); ○ Generalized Contentment Scale; ○ Patient Health Questionnaire-2 (PHQ-2); ○ Primary Care Evaluation of Mental Disorders; ○ Patient Health Questionnaire (PRIME-MD PHQ) | - Validation studies, or screening conducted using a nonvalidated instrument
Comparators | - No formal protocol for screening, screening with another validated instrument, or screening with the same instrument under different conditions (e.g., different settings or different timing) | - Comparison to screening with a nonvalidated instrument
Outcomes | - Performance characteristics (KQs 1–3):; ○ Sensitivity; ○ Specificity; ○ Predictive values; - Intermediate outcomes; ○ KQs 1–3:; ■ Diagnosis of depression based on the DSM-IV-TR criteria using a validated instrument; ○ KQs 4 and 5:; ■ Receipt of appropriate diagnostic and treatment services for symptoms of depression; ■ Scores on validated measures of maternal well-being and parenting; ■ Breastfeeding (e.g., proportion initiating breastfeeding or duration of breastfeeding); ○ KQ 6:; ■ Receipt of appropriate diagnostic and treatment services for symptoms of depression; - Final outcomes (KQ 4):; ○ Scores on validated diagnostic instruments for depression; ○ Health-related quality of life, based on validated measures; ○ Maternal suicidal/infanticidal behaviors; ○ Scores on validated instruments of infant health and development; ○ Maternal health system resource utilization, including number of visits and estimates of total and attributable costs; ○ Infant health system resource utilization, including number of visits and estimates of total and attributable costs; ○ Paternal outcomes, including scores on validated mental health instruments, health-related quality of life, and health system resource utilization (measured as described above for maternal outcomes); - Adverse effects (KQ 5):; ○ Scores on validated measures of stigmatization; ○ Health-related quality of life, based on validated measures; ○ Maternal health system resource utilization, including number of visits and estimates of total and attributable costs; ○ Infant health system resource utilization, including number of visits and estimates of total and attributable costs; ○ Paternal outcomes, including scores on validated mental health instruments, health-related quality of life, and health system resource utilization (measured as described above for maternal outcomes) | - Outcomes measured predelivery; - Only outcome of interest reported is depression; outcome was measured with the screening instrument only and not confirmed with a reference standard; - Only outcome of interest reported is sensitivity/specificity, and insufficient data provided to construct a 2-by-2 table; - Article provides information only about the association between postpartum depression and other outcomes without linking screening to those outcomes
Timing | - Intervention; ○ Prenatal period; ○ Immediate postpartum period (up to 6 weeks after delivery); ○ Up to 12 months after delivery; - Followup; ○ Begins at delivery; timing of followup not limited | - Outcomes measured predelivery
Setting | - Any clinical provider setting, home; - Study locations include at least one high-income economy as defined by the World Bank.73 We restrict the study to economically developed countries—countries that have greater cultural and health care system similarities to the United States—to improve applicability of the study results to U.S. populations. | None
Study design | - Original data; - RCTs, prospective and retrospective observational studies with comparator; for test characteristics, cross-sectional studies acceptable if includes patients with diagnostic uncertainty and direct comparison of test results with an appropriate reference standard; - RCTs: All sample sizes; - Observational studies: sample size ≥100 subjects | - Editorials, nonsystematic reviews, letters, case series, case reports
Publications | - English-language only; - Peer-reviewed articles; - Relevant systematic review, meta-analysis, or methods article (to be used for background only)^a^; - Published on or after January 1, 2004 | - Non-English-language articles^b^

BDI-IA = Beck Depression Inventory-IA; BDI-II = Beck Depression Inventory-II; BPDS = Bromley Postnatal Depression Scale; CES-D = Center for Epidemiologic Studies Depression Scale; DSM-IV-TR = Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision; EPDS = Edinburgh Postnatal Depression Scale; GHQ-D = General Health Questionnaire; HADS = Hospital Anxiety and Depression Scale; HRSD = Hamilton Rating Scale for Depression; KQ = Key Question; LQ = Leverton Questionnaire; MADRS = Montgomery Asberg Depression Rating Scale; PDPI-R = Postpartum Depression Predictors Inventory-Revised; PDSS = Postpartum Depression Screening Scale; PHQ-2 = Patient Health Questionnaire-2; PHQ-9 = Patient Health Questionnaire-9; PRIME-MD PHQ = Primary Care Evaluation of Mental Disorders Patient Health Questionnaire; RCT = randomized controlled trial; Zung SDS = Zung Self-Rating Depression Scale

a Systematic reviews and meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional citations to consider in the review. Articles providing methods information only (i.e., not reporting data) were not considered among the formal set of included articles, but were used to supplement the abstractions of the studies they referenced.

b Given the high volume of literature available in English-language publications and concerns about the applicability of non-English publication studies to settings in the United States, non-English articles were excluded.

### Inclusion and Exclusion Criteria

The PICOTS (Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest) criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 3.

### Study Selection

Using the prespecified inclusion and exclusion criteria described in Table 3, two investigators independently reviewed titles and abstracts for potential relevance to the KQs. The research team included a balance of investigators with expertise relevant to the clinical content area of the report (perinatal and postpartum psychiatry, general obstetrics and gynecology, maternal/fetal medicine, general pediatrics) and/or methodological expertise in epidemiology, screening, decision modeling, and the conduct of systematic reviews. Articles included by either reviewer underwent full-text screening. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the two reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through review and discussion, or through a third-party arbitrator if needed. Articles meeting our eligibility criteria were included for data abstraction. Relevant review articles and meta-analyses were flagged for manual searching of references and cross-referencing as appropriate against the library of citations identified through electronic database searching.

For citations retrieved by searching the grey literature, the above-described procedures were modified such that a single screener initially reviewed all search results; final eligibility of citations for data abstraction was determined by duplicate screening review. All screening decisions were made and tracked in a Distiller SR database (Evidence Partners Inc., Manotick, ON, Canada).

### Data Extraction

The research team created data abstraction forms and evidence table templates for abstracting data for each KQ. Based on clinical and methodological expertise, a pair of investigators was assigned to abstract data from each eligible article. One investigator abstracted the data, and the second reviewed the article and the associated completed abstraction form to check for accuracy and completeness. Disagreements were resolved by consensus, or by obtaining a third reviewer’s opinion if consensus could not be reached. To aid in both reproducibility and standardization of data collection, researchers received data abstraction instructions directly on each form created specifically for this project within the DistillerSR database.

We designed the data abstraction forms to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (screening test performance characteristics, as well as intermediate, final, and adverse events outcomes). We gave particular attention to describing the details of the screening intervention that may be related to outcomes, including setting, provider, timing, and frequency of screening; patient characteristics (e.g., age, parity); and study design (e.g., randomized controlled trial [RCT] versus observational). In addition, we described comparators carefully, because screening, diagnostic, and treatment standards may have changed during the study period. Harms outcomes were framed to help identify adverse events (e.g., stigmatization, decreased quality of life). We also abstracted data necessary for assessing quality and applicability, as described in the Methods Guide32 and the Medical Test Guide.33 Before the data abstraction form templates were used, they were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency/reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles. Appendix B lists the elements included in the data abstraction forms.

## Quality Assessment of Individual Studies

We assessed the methodological quality, or risk of bias, of individual studies using the assessment instruments detailed in the Methods Guide32 and the Medical Test Guide.33 In this context, “bias” refers to the degree to which a study’s results are due to aspects of the study design (choice of population, allocation of treatment, uneven distribution of risk factors, etc.) rather than the specific factor (risk factor or exposure, screening test, treatment, etc.) of interest. Briefly, we assessed each study with an overall summary rating based on its adherence to well-accepted standard methodologies (e.g., the QUality Assessment for Diagnostic Accuracy Studies-2 [QUADAS-2] tool74 for studies of diagnostic accuracy). To assess quality for studies presenting information on patient-centered intermediate, final, and adverse effect outcomes, we used a strategy to (1) classify the study design, (2) apply predefined criteria for quality and critical appraisal, and (3) arrive at a summary judgment of the study’s quality. We applied criteria for each study type derived from core elements described in the Methods Guide. Criteria of interest for all studies included similarity of groups at baseline, extent to which outcomes were described, blinding of subjects and providers, blinded assessment of the outcome(s), intention-to-treat analysis, differential loss to followup between the compared groups or overall high loss to followup, and conflicts of interest. Criteria specific to RCTs included methods of randomization and allocation concealment. For observational studies, additional elements such as methods for selection of participants, measurement of interventions/exposures, addressing any design-specific issues, and controlling confounding were considered. To indicate the summary judgment of the quality of individual studies, we used the overall ratings of good, fair, or poor based on the study’s adherence to well-accepted standard methodologies (Table 4). Studies of different designs were graded within the context of their respective designs. Thus, RCTs were graded as good, fair, or poor, and observational studies were separately graded as good, fair, or poor.

Table 4 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

For studies assessing screening test performance (KQs 1, 2, and 3), we used QUADAS-2^74^ to assess quality. QUADAS-2 describes risk of bias in four key domains: patient selection, index test(s), reference standard, and flow and timing. The questions in each domain are rated in terms of risk of bias and concerns regarding applicability, with associated signaling questions to help with these bias and applicability judgments. Summary judgments for these studies were assigned as high risk of bias, low risk of bias, or unclear.

## Data Synthesis

We began our data synthesis by summarizing key features of the included studies for each KQ. To the degree that data were available, we abstracted information on study design; patient characteristics; clinical settings; interventions; screening test performance; and intermediate, final, and adverse event outcomes. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis). Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies (both in terms of study population and outcomes), and completeness of the reporting of results.

We considered meta-analysis for comparisons where at least three conceptually homogenous studies reported the same patient-centered intermediate, final, or adverse effect outcome. In such instances if a meta-analysis was appropriate, we planned to use random-effects models to synthesize the available evidence quantitatively using Comprehensive Meta-Analysis software (Version 2; Biostat, Englewood, NJ). This approach includes testing for heterogeneity using graphical displays and test statistics (Q and I^2^ statistics, recognizing that the ability of statistical methods to detect heterogeneity may be limited). For comparison purposes, we also planned to perform fixed-effect meta-analyses. Our presentation of meta-analysis results typically includes summary estimates, standard errors, and exact confidence intervals (CIs). Unfortunately, the available evidence did not support meta-analysis of patient-centered or adverse event outcomes.

Test performance was summarized using sensitivity and specificity. Test sensitivity describes the proportion of subjects with the disorder who have an abnormal test. Test specificity describes the proportion of subjects without the disorder who have a normal test.

If test performance studies were conceptually homogeneous, we planned to use random-effects bivariate meta-analysis using SAS version 9.2 (SAS Institute Inc., Cary, NC) to compute summary estimates of performance.75 A random-effects model assumes that variability is a result of sampling errors as well as the true differences between studies and provides a meta-analytic modeling approach for pooling sensitivity and specificity, while accounting for possible correlation between sensitivities and specificities of the studies included.76 We intended to evaluate statistical heterogeneity by inspecting forest plots and computing Q and I^2^ statistics. Since the Q test is underpowered, we planned to set the threshold for significant heterogeneity at p<0.10. For the I^2^ test, a suggested interpretation is to assign the terms low, moderate, and high to I^2^ values of 25 percent, 50 percent, and 75 percent, respectively.77

We anticipated that intervention effects might be heterogeneous. We hypothesized that the methodological quality of individual studies, study type, characteristics of the screening population (e.g., age, parity), and characteristics of the screening intervention (e.g., setting, provider) would be associated with the intervention effects. Where there were sufficient studies (three or more), we planned to perform subgroup analyses and/or meta-regression analyses to examine these hypotheses. Examples of such a subgroup analysis are a comparison of effectiveness estimates for RCTs vs. observational studies, or a comparison of estimates of the association between a history of intimate partner violence and postpartum depression for cohort vs. case-control studies. As with the patient-centered and adverse event outcomes, the available evidence did not support meta-analyses of test performance or subgroup data.

We also adapted an existing simulation model of pregnancy and neonatal outcomes78 to estimate the balance of benefits and harms of different screening strategies based on the literature review, using the benefits and harms listed above. Because there are numerous unresolved issues about the use of quality-adjusted life years (QALYs) in the setting of maternal–child health,79 we used the estimated likelihood of specific outcomes as the model output. Specific benefits include estimates of treated depression, false negatives, and false positives. Based on our preliminary review of the literature and discussions with the Key Informants and TEP, we expected data on harms, in particular, to be sparse. We can, however, readily estimate the number of false-positive screening test results, or total referrals for further evaluation, under different scenarios. This allows an approach which compares total tests or false-positive results as a measure of “cost” or “harm” with a measure of benefit, such as “cases of depression detected.” Such an approach has been used by modelers supporting the USPSTF in making recommendations—for example, in colorectal cancer screening, where the metric was colonoscopies per cancer death prevented, or in cervical cancer screening, where the metric was colposcopies per cancer death prevented.

The model simulates pregnancy from conception through delivery and can subsequently simulate both maternal and child outcomes. Child outcomes are conditioned on gestational age at delivery and maternal race/ethnicity; both maternal and child outcomes can also easily be conditioned on maternal exposures at any point in gestation. In this context, using this model, estimates of benefits and harms can be generated for specific screening tests, at different times during and after pregnancy, for mothers and infants (and for fathers, if data are available). For example, the model could compare estimated maternal and infant outcomes from screening with a test of sensitivity X percent and specificity Y percent at 36 weeks gestation and 6 weeks postpartum, versus screening with a test of sensitivity A percent and specificity B percent at each well-child visit. The values for sensitivity and specificity (along with CIs) were derived from the literature review. The model also incorporates variability in followup and appropriate treatment after a positive screening test result. We used probabilistic sensitivity analysis to assess overall uncertainty based on the available literature, and used a modified value-of-information approach to help prioritize future research needs.80 Because the report found almost no evidence from which to derive estimates for longer term outcomes, we focused the analysis on estimating the number of detected cases of depression, false negative and false positive results under different scenarios of test performance, and prevalence of depression.

## Strength of the Body of Evidence

We rated the strength of evidence for each KQ and outcome using the approach described in the Methods Guide32,81 and Medical Test Guide.33 In brief, the approach requires assessment of four domains: risk of bias, consistency, directness, and precision (Table 5).

Table 5 Strength of evidence—required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT vs. observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether effect sizes are generally on the same side of “no effect” and the overall range of effect sizes
Directness | Direct Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Precision | Precise Imprecise | Based primarily on the size of the CIs of effect estimates

CIs = confidence intervals; RCT = randomized controlled trial

Additional domains were used when appropriate, namely, strength of association (magnitude of effect) and publication bias. These domains were considered qualitatively, and a summary rating of high, moderate, or low strength of evidence was assigned after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make; for example, when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of insufficient was assigned. This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## Applicability

We assessed applicability across our KQs using the method described in the Methods Guide32,81 and Medical Test Guide;33 In brief, this method uses the PICOTS format as a way to organize information relevant to applicability. Items of particular interest that may contribute to heterogeneity and impact applicability include setting (e.g. country, provider), comparator, spectrum of disease (e.g., whether a screening test was used in the general population vs. in a subgroup preselected based on known or suspected risk factors), family income, race, ethnicity, parity, and partner support. Within this report we consider studies conducted in the UK separately from those conducted in the rest of Europe, primarily because the use of screening instruments administered in English enhances the applicability of UK studies to a U.S. nonimmigrant setting. We used checklists to guide the assessment of applicability (see the relevant sections of Appendix B). We used these data to evaluate the applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison to the target population, characteristics of the intervention used in comparison with care models currently in use, and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively.

## Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in a range of pertinent fields (obstetrics and gynecology, adult and child psychiatry, psychology, postpartum depression screening and treatment, maternal/fetal medicine, women’s health, epidemiology, health services research, informed decision making, and family medicine) along with individuals representing stakeholder and user communities were invited to provide external peer review of this draft report; AHRQ and an associate editor also provided comments. The draft report was posted on AHRQ’s Web site for public comment for 4 weeks, from July 31 to August 28, 2012. We have addressed reviewer comments, revising the report as appropriate, and have documented our responses in a disposition of comments report available on the AHRQ Web site. A list of peer reviewers is given in the preface of this report.