# Introduction

## Background

### Postpartum Depression

Depression is a potentially life-threatening condition with a substantial impact on quality of life. The impact of depression in postpartum women is at least as great as that for depression in other populations. Postpartum depression is defined in the “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision” (hereafter, DSM-IV-TR) as a major depressive disorder according to the diagnostic criteria listed in Table 1, with a secondary criterion of onset of symptoms within 4 weeks of delivery.1 (Note: A new set of diagnostic criteria for psychiatric illness, the “Diagnostic and Statistical Manual of Mental Disorders, 5th Edition” [DSM-5], is currently scheduled for release in May 2013). Other diagnostic standards allow the definition of onset of postpartum depression to extend beyond 4 weeks and up to 12 months after delivery, and to include a “minor depression” subcategory (2 to 4 of the symptoms listed in Table 1).

Table 1 DSM-IV-TR diagnostic criteria for major depressive disorder

Criterion | Description
A. | Five (or more) of the symptoms below have been present during the same 2-week period and represent a change from previous functioning; at least one of the symptoms is either (1) depressed mood or (2) loss of interest or pleasure. (Note: Do not include symptoms that are clearly due to a general medical condition, or mood-incongruent delusions or hallucinations.); - Depressed mood most of the day, nearly every day, as indicated by either subjective report (e.g., feels sad or empty) or observation made by others (e.g., appears tearful); - Markedly diminished interest in pleasure in all, or almost all, activities most of the day, nearly every day (as indicated by either subjective account or observation made by others); - Significant weight loss when not dieting or weight gain (e.g., change of more than 5% body weight in a month), or decrease or increase in appetite nearly every day; - Insomnia or hypersomnia nearly every day; - Psychomotor agitation or retardation nearly every day (observable by others, not merely subjective feelings of restlessness or being slowed down); - Fatigue or loss of energy nearly every day; - Feelings of worthlessness or excessive or inappropriate guilt (which may be delusional) nearly every day (not merely self-reproach or guilt about being sick); - Diminished ability to think or concentrate, or indecisiveness, nearly every day (either subjective account or as observed by others); - Recurrent thoughts of death (not just fear of dying), recurrent suicidal ideation without a specific plan, or a suicide attempt or a specific plan for committing suicide
B. | The symptoms do not meet the criteria for mixed episode (DSM-IV-TR, p.365).
C. | The symptoms cause clinically significant distress or impairment in social, occupational, or other important areas of functioning.
D. | The symptoms are not due to the direct physiological effects of a substance (e.g., a drug of abuse, medication) or a general condition (e.g., hypothyroidism).
E. | The symptoms are not better accounted for by bereavement, i.e., after the loss of a loved one, the symptoms persist for longer than 2 months or are characterized by marked functional impairment, morbid preoccupation with worthlessness, suicidal ideation, psychotic symptoms, or psychomotor retardation.

DSM-IV-TR = Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision

The most recent U.S.–based formal synthesis of the evidence, performed for the Agency for Healthcare Research and Quality (AHRQ) in 2005,^2,3^ estimated that the point prevalence (the proportion of the population with the condition at a given point in time) of major depression alone during the first postpartum year is 1.0–5.9 percent, with point prevalence for major and minor depression combined of 6.5–12.9 percent. The AHRQ evidence review found a best estimate for period prevalence (the proportion of the population with the condition at any point during a defined time period) of 21.9 percent (95% CI, 15.1 to 30.0%).3 Incidence (the rate of new cases among a population without the condition within a given time period) estimates for the first 3 postpartum months were up to 6.5 percent for major depression alone and 14.5 percent for major and minor depression, with a cumulative 12-month incidence of 30.6 percent (95% CI, 18.3 to 45.4%). Although depression in the perinatal period has attracted special interest, the available data suggest that incidence and prevalence of major depression in the postpartum period are comparable to rates observed in nonpregnant/nonpostpartum women of reproductive age. However, the prevalence of depressive symptoms not meeting diagnostic criteria for depression may be higher, particularly in the first 3 months after birth.3,4 Consistent limitations in the literature noted by the AHRQ review included small sample size (precluding subgroup analyses) and lack of generalizability.

### Adverse Outcomes Associated With Postpartum Depression

Depression in adults has a significant impact on quality of life, productivity, and social functioning,4,5 and there is no evidence that these effects are any different for women during the postpartum period. In addition to the substantial morbidity burden, there is an appreciable risk of mortality through suicide. Although the risk of suicide in women may be lower during pregnancy and the postpartum period,6 a review of maternal mortality in the United Kingdom (UK) during the 1990s found that suicide was the leading cause of maternal mortality, accounting for 29 percent of maternal deaths.7,8 In addition, postpartum depression may increase the risk of infant mortality through neglect, abuse, or homicide.9

The impact of depression on mothers alone is sufficient to justify intervention, although the available evidence suggests that the burden of disease, particularly for major depression, is similar during the postpartum period and other times not associated with pregnancy or recent childbirth. However, there is another rationale for giving special consideration to the effective prevention or treatment of depression during the postpartum period. In 2009, the Institute of Medicine (IOM) published a comprehensive review of the impact of depression in parents on both parental and child outcomes.4 In observational studies, maternal depression is consistently associated with adverse effects on maternal–infant interactions and some measures of infant development,4,10 and this evidence has been explicitly cited as part of the rationale for screening by providers who care for infants.11,12 For example, the IOM report found an increased risk of “maladaptive” utilization, including underutilization of primary and preventive services, increased use of emergency services, and increased risk of hospitalization even after adjusting for infant health status.4

### Screening for Postpartum Depression

Given the potential impact of postpartum depression on maternal and infant health, there has been considerable interest in strategies aimed at identifying women who are at risk for postpartum depression or who have postpartum depression, with the ultimate goal being the application of effective preventive or therapeutic interventions to improve outcomes for both mother and child. Key components of any particular screening strategy for postpartum depression include (1) which screening test or instrument to use, (2) when to screen, (3) who should screen, and (4) how to use the results of the screening test. However, there is considerable uncertainty about all of these components, as seen in existing recommendations.

#### Potential Benefits of Screening

There is high-quality evidence that effective treatments are available for patients who meet criteria for major depression in other settings, and the available evidence suggests that both pharmacological13 and nonpharmacological4,14 treatments can be effective in the postpartum setting. Given the availability of effective treatment, screening instruments with acceptable test characteristics, and reliable systems for ensuring that women identified through a screening program receive appropriate diagnostic and therapeutic services, screening during the postpartum period is at least as justifiable as screening during other times. And, as noted below, screening for depression receives a “B” recommendation from the U.S. Preventive Services Task Force (USPSTF) if systems for ensuring receipt of appropriate services are in place.

Because maternal depression is consistently associated with adverse effects on maternal–infant interactions and longer term development outcomes, screening would be even more important if there were direct evidence that screening and treatment of previously undiagnosed maternal depression leads to improvement in these outcomes. However, outcomes in the studies included in the two most recent systematic reviews were primarily scores on measures of depression, which are often used as endpoints in clinical trials of depression therapy. Other important outcomes—such as measures of infant health and development—have not been included,2,3,15 a deficiency noted in the IOM report.4 There is some evidence that treating depression in mothers improves some measures of child mental health and functioning,16,17 but these studies have not specifically been in the context of depression detected through screening in the postpartum period. Given the consistent association between depressive symptoms and adverse effects on maternal–infant interaction, it is possible that interventions performed in response to depressive symptoms not meeting the criteria for major depression could result in improved outcomes for the mother–infant dyad.

#### Potential Harms of Screening

In their 2009 recommendations on screening for depression in adults, the USPSTF identified “false-positive results, the inconvenience of additional diagnostic workup, the costs and adverse effects of treatment of patients who are incorrectly identified as being depressed, and potential adverse effects of labeling” as potential harms, but none of the reviewed studies provided any evidence regarding these potential harms.18 Whether any of these harms is more likely when screening for postpartum depression is unclear. However, it is possible that pregnant and postpartum women may be at increased risk of a false-positive result from screening, given that many of the signs and symptoms included in the diagnostic criteria for depression (Table 1) are common and normal responses to pregnancy, childbirth, and caring for infants. Furthermore, many studies of postpartum depression include “minor depression” as a diagnostic category. Previous reviews have concluded that there is a lack of evidence that treatment of symptoms not meeting criteria for major depression improves maternal outcomes.2,3,19 If a diagnosis of minor depression does not lead to effective treatment, then patients may be exposed to the potential side effects of therapy (particularly medical therapy) in addition to being labeled as depressed without a concomitant improvement in outcomes for themselves or their child.

Screening also requires resources. Even the use of self-administered tests requires some provider time to review and document the results, with additional time required for further evaluation of positive results, whether this evaluation takes place within the same setting as screening, or through referral. Even if screening leads to improved outcomes for depressed mothers or their infants, the resources required to screen all postpartum women and to evaluate women with positive results (including women with false positive results) can place a burden on health care delivery systems, particularly public health systems, which may already be having difficulty meeting patient needs.

#### Accuracy of Screening Instruments

In evaluating strategies that involve screening for postpartum depression, patients, providers, and policymakers must consider the tradeoffs between the likely benefits and harms of screening. Although direct evidence from appropriately designed trials is ideal, such data are often lacking (and previous reviews have found them lacking for screening for postpartum depression). In such cases, inferences must be drawn from data on how well the screening test or strategy distinguishes between patients who truly have the condition of interest and those who do not, which is usually reported as the strategy’s sensitivity (the likelihood that people with the condition will have a positive test) and specificity (the likelihood that people without the condition will have a negative test). The sensitivity and specificity of a test are characteristics that are independent of the population being tested. Higher sensitivity means fewer people with the condition are missed, while higher specificity means fewer people without the condition will be falsely identified; importantly, sensitivity and specificity are indirectly correlated—increasing sensitivity decreases specificity and vice versa. In the context of screening for postpartum depression, higher sensitivity means more women with undiagnosed and untreated depression are detected, while higher specificity means fewer nondepressed women will need further evaluation to rule out depression. One advantage of reporting test sensitivity and specificity is that, because they are inherent characteristics of the tests themselves, sensitivity and specificity estimates for a given test can be compared and pooled across different studies.

Sensitivity and specificity are not, however, directly useful clinically: the more relevant test characteristics are positive predictive value (PPV; the likelihood that a person with a positive test has the condition of interest) and negative predictive value (NPV; the likelihood that a person with a negative test does not have the condition of interest). These characteristics are functions of test sensitivity and specificity and the underlying likelihood of the condition of interest (prevalence). Because of this dependence on prevalence, the PPV and NPV of a specific test can vary across studies, depending on the population. The PPV and NPV of a test or strategy can be directly estimated from a study in a specific population or can be indirectly estimated from estimates of the test sensitivity and specificity and the population prevalence. A test with a certain sensitivity and specificity might have quite different PPV and NPV when used in different settings or at different times. Greater certainty about how PPV and NPV vary across populations, settings, and timing would help in developing specific recommendations about when, whom, and how often to screen.

One of the consistent uncertainties identified in current postpartum screening recommendations is how well currently available tests and strategies for identifying women with, or at risk for, postpartum depression perform in (1) maximizing detection of undiagnosed and untreated depression and (2) minimizing false-positive results. For example, the committee opinion on screening for depression during and after pregnancy developed by the American Congress of Obstetricians and Gynecologists20 lists seven different tests—the Edinburgh Postnatal Depression Scale (EPDS), the Postpartum Depression Screening Scale (PDSS), the Patient Health Questionnaire-9 (PHQ-9), the Beck Depression Inventory (BDI), the Beck Depression Inventory II (BDI-II), the Center for Epidemiologic Studies Depression Scale (CES-D), and the Zung Self-Rating Depression Scale (Zung SDS)—with wide ranges for the reported sensitivity and specificity, but it does not provide specific guidance on which test might be most appropriate in a particular setting.

Another issue is that sensitivity and specificity may also vary based on the definition of “disease.” For example, the 2005 AHRQ evidence review on postpartum depression2,3 found that the sensitivity of all instruments reviewed was greater for a diagnosis of major depression alone compared with a broader definition of major or minor depression. As noted above, there is greater uncertainty about the availability of effective treatments for minor depression. This may be even more important in the setting of postpartum depression—if depressive symptoms that do not meet diagnostic criteria are associated with adverse effects on the mother–infant dyad, and treatment of these symptoms leads to improved developmental outcomes, then the “optimal” sensitivity target for a screening strategy should be based on these considerations.

### Clinical and Socioeconomic Factors Affecting Risk for Postpartum Depression

Consistent risk factors for postpartum depression identified in the literature include a history of depression before pregnancy, depression or anxiety during pregnancy, experiencing stressful life events during pregnancy or the early postpartum period, and low levels of social support; maternal age, income, and parity may also affect risk.4,21–25 Because the outcomes of screening for any condition are dependent on the likelihood of that condition at the time of screening (the prior probability of disease), selective use of specific tools to screen women at higher risk for postpartum depression when one or more risk factors are present may be a viable strategy.

#### Other Factors Affecting Screening Performance

##### Timing

Many of the signs and symptoms that make up the diagnostic criteria for depression are also common physiological or emotional responses to pregnancy and caring for an infant, and their prevalence can vary depending on when the measurement is performed. The presence of similar signs/symptoms in women who have and do not have depression could affect the specificity, and thus the false-positive rate, of a given screening test. In addition, testing during the prenatal period is seeking either to identify current depression (which by definition would not be postpartum depression), or to identify women at risk for postpartum depression; the performance of a test designed to identify patients at higher risk before they develop a condition is often quite different than the performance of a test designed to detect the condition itself.

##### Setting

Setting is inevitably related to timing; however, setting may have other effects on test performance. For example, the willingness of a woman to admit to symptoms of depression might vary depending on the setting—that is, her comfort level and familiarity with a provider or her concerns about being judged as a parent. Setting may also play a crucial role in determining whether women with a positive screening test result receive appropriate diagnostic and treatment services.

##### Provider

As with setting, the provider and the nature of his/her relationship with the patient may affect the willingness of the patient to admit to symptoms of depression. The provider’s ability to appropriately administer a given screening tool may be affected by his/her training or the nature of his/her usual practice. Finally, as with setting, even if the sensitivity/specificity/predictive values of the test are unchanged, the ability of the provider to provide appropriate diagnosis and treatment to a patient with a positive test may vary based on available resources, skill and training of provider, or the context of visit.

#### Effective Management of Positive Screening Tests

Screening is often focused during pregnancy or the first 3 postpartum months in settings where care is provided to pregnant or postpartum women by providers such as obstetricians, family physicians, or nurse-midwives. All of the existing recommendations for screening emphasize the need for systems or procedures to ensure that women identified as being at risk for postpartum depression receive appropriate diagnostic services, and, if a diagnosis of depression is confirmed, appropriate treatment (Table 2). Because the risk of postpartum depression extends throughout the first 12 months after delivery, maternal depression may affect outcomes for the infant, and settings where care is provided to the infant provide an opportunity for postpartum depression screening. Clinicians who provide care for infants have proposed the possibility of including screening for maternal depression as part of routine infant care,12,26 but issues regarding scope of practice, legal liability, and appropriate referral remain challenges.11

Table 2 Guidelines/recommendations for screening for postpartum depression

Organization | Statement | Date
U.S. Preventive Services Task Force18 | No specific recommendations for postpartum depression. Grade B recommendation for screening “when staff-assisted depression care supports are in place to assure accurate diagnosis, effective treatment, and follow-up;” Grade C recommendation against screening when such supports are not in place. | December 2009
American College of Obstetricians and Gynecologists, Committee on Obstetric Practice20 | At this time there is insufficient evidence to support a firm recommendation for universal antepartum or postpartum screening. There are also insufficient data to recommend how often screening should be done. However, screening for depression has the potential to benefit a woman and her family and should be strongly considered. Medical practices should have a referral process for identified cases. Women with current depression or a history of major depression warrant particularly close monitoring and evaluation. | February 2010
American Academy of Pediatrics, Committee on Psychosocial Aspects of Child and Family Health26 | Screening can be integrated, as recommended by Bright Futures and the American Academy of Pediatrics Mental Health Task Force, into the well-child care schedule and included in the prenatal visit. This screening has proven successful in practice in several initiatives and locations and is a best practice for primary care pediatricians caring for infants and their families. Intervention and referral are optimized by collaborative relationships with community resources and/or by colocated/integrated primary care and mental health practices. | November 2010
American Academy of Family Physicians29 | No specific recommendations for postpartum depression; general recommendations for screening follow those of the U.S. Preventive Services Task Force.18 | October 2010
American College of Nurse Midwives30 | The American College of Nurse Midwives supports universal screening, treatment, and/or referral for depression in women as a part of routine primary health care. | December 2003
United Kingdom National Institute for Health and Clinical Excellence31 | At a woman’s first contact with a primary care provider, at her booking visit, and postnatally (usually at 4 to 6 weeks and 3 to 4 months), health care professionals (including midwives, obstetricians, health visitors, and general practitioners) should ask two questions to identify possible depression:; - During the past month, have you often been bothered by feeling down, depressed, or hopeless?; - During the past month, have you often been bothered by having little interest or pleasure in doing things?; A third question should be considered if the woman answers “yes” to either of the initial questions:; - Is this something you feel you need or want help with?; Health care professionals may consider the use of self-report measures such as the Edinburgh Postnatal Depression Scale (EPDS), the Hospital Anxiety and Depression Scale (HADS), or the Patient Health Questionnaire-9 (PHQ-9) as part of a subsequent assessment or for the routine monitoring of outcomes. | April 2007

EPDS=Edinburgh Postnatal Depression Scale; HADS=Hospital Anxiety and Depression Scale; PHQ-9=Patient Health Questionnaire-9

##### Current Screening Recommendations

All major organizations providing care to pregnant and postpartum women and infants recognize the risks associated with postpartum depression and the potential benefit of screening, but the strength of recommendations is variable. For example, none of the U.S.–based organizations recommend use of a specific instrument (Table 2). Factors cited by these organizations that limit the strength of recommendations include the lack of sufficient data on the most appropriate screening instrument (including culturally appropriate tools to reflect population diversity), the optimal time(s) for screening,20 issues concerning reimbursement and the scope of practice,11,20 and the need for adequate systems for ensuring appropriate care for women identified through screening.11,12,18

Despite this uncertainty, efforts have been made at the state level to require offering screening for postpartum depression, although the experience to date has not demonstrated substantial benefit.4,27,28

## Scope and Key Questions

### Scope of the Review

This Comparative Effectiveness Review (CER) was funded by AHRQ and designed to evaluate the comparative diagnostic accuracy, benefits, and harms of available screening instruments for postpartum depression. Further details are provided under “Key Questions” and “Analytic Framework,” below, and in the section on “Inclusion and Exclusion Criteria” in the Methods chapter. As specified in the Key Questions (KQs), we further considered whether the diagnostic accuracy, benefits, and harms of the screening instruments evaluated differed among specific patient subgroups of interest, defined by any of the following factors: age, race/ethnicity, parity, history of mood disorders, history of intimate partner violence, perinatal outcomes, or cultural factors. We also considered whether the performance characteristics of screening instruments were affected by the timing of screening, the setting in which screening was conducted, or the type of provider. This review does not consider questions regarding the safety and/or effectiveness of downstream options for postpartum depression treatment. Treatment options are being addressed in a separate AHRQ CER (currently in progress) that will be published as a separate report.

Despite recognition that (a) postpartum depression is common, (b) it may have serious effects on both mothers and infants, and (c) screening instruments are available, uncertainty about whether, when, and how to screen for postpartum depression remains, as seen in the various recommendations summarized in Table 2. Sources for this uncertainty include:

- Imprecision in the published sensitivity and specificity estimates for the various instruments at the time the recommendations were drafted. Incorporating additional data published subsequently should add greater precision to these estimates by increasing the overall sample size and may make any differences between specific tests more apparent.
- Uncertainty about the ability of screening strategies to consistently identify the women most likely to benefit from available treatments and followup. For example, in populations at very low risk for postpartum depression, lower specificity would result in a low negative predictive value and could result in a high absolute number of women referred for additional diagnostic evaluation.
- Lack of direct evidence of benefits from screening. For screening to be of benefit, the test has to be able to accurately distinguish between those likely to benefit from further evaluation and treatment and those at low risk for the condition of interest; women identified as being at higher risk of the condition have to be able to receive appropriate diagnostic services; and, for those definitively identified with the condition, effective treatment needs to be available. Our review focuses on the first two aspects of screening benefits; a separate evidence review of the effectiveness of treatment for perinatal depression is currently ongoing. If we assume that women identified through screening whose symptoms meet the diagnostic criteria for depression are given effective treatments, then a study that randomized women to no screening versus screening, or to screening with two different instruments, would address the question of screening benefit, especially if the treatments were standardized. Addressing the question of which treatments are most effective would require a different design.
- Issues related to management of women with a positive screening result. Although all recommendations related to screening commented on the need for appropriate systems or mechanisms for managing women with a positive screening test, there is no mention of the possible harms, such as anxiety created by a positive screening test result or the potential stigma associated with a diagnosis of depression.

By summarizing the available evidence on the accuracy and effectiveness of screening for postpartum depression, we hope to provide a resource to organizations developing recommendations to enhance patient-centered outcomes for women, their partners, and children, ideally with efficient use of clinical resources. We also identify key areas of uncertainty that limit stakeholders’ ability to adequately judge the balance of benefits and harms associated with screening, at both the individual and systemic level, and suggest areas where additional research to specifically addresses the limitations of the currently available evidence would help resolve this uncertainty.

### Key Questions

With input from our Key Informants, we constructed Key Questions (KQs) using the general approach of specifying the populations, interventions, comparators, outcomes, timeframes, and settings of interest (PICOTS; see the section on “Inclusion and Exclusion Criteria” in the Methods chapter for details). The KQs considered in this CER are:

KQ 1 This question has two parts:
  a. What are the sensitivity and specificity of currently available screening instruments for detecting postpartum depression, and how do these translate into the likelihood of false-negative and false-positive results in different populations and settings?
  b. Are there clinically relevant differences in the ability of currently available screening instruments to correctly identify specific signs or symptoms of depression (e.g., suicidal ideation)?
KQ 2 This question has two parts:
  a. Are there individual factors (age, race, parity [number of live births], history of mood disorders, history of intimate partner violence, perinatal outcomes, cultural factors) that affect the baseline risk of postpartum depression and, therefore, the subsequent positive and negative predictive values of screening instruments?
  b. Are there validated predictive models or algorithms based on such factors that would improve the performance of screening instruments?
KQ 3 Are the performance characteristics (sensitivity, specificity, predictive values) of screening instruments affected by:
  a. Timing (prenatal, peripartum, or at various times in the first postpartum year) and frequency of screening?
  b. Setting (prenatal visit, hospital/birthing center/home, postpartum maternal visit, or well-child visit)?
  c. Provider (obstetrician, midwife, pediatrician, family practitioner, other health provider)?
KQ 4 What are the comparative benefits of screening for postpartum depression when compared with no screening, or between different screening strategies (based on choice of screening instrument, timing, setting, etc.)?
KQ 5 What are the comparative harms of screening for postpartum depression when compared to with screening, or between different screening strategies (based on choice of screening instrument, timing, setting, etc.)?
KQ 6 Is the likelihood of an appropriate action (referral, diagnosis, treatment, etc.) after a positive screening result affected by timing, setting, patient characteristics, or other factors?

## Analytic Framework

Figure 1 shows the analytic framework for this project.

Figure 1 Analytic framework

KQ = Key Question

This figure depicts the KQs within the context of the PICOTS described in the Methods section of this report. In general, the figure shows that the population of interest is pregnant women and women during the first 12 months postpartum. (Fathers and domestic partners were also considered, as specified in Table 3. For clarity, those groups are not depicted here.) KQ 1 focuses on the sensitivity and specificity of currently available screening instruments for detecting postpartum depression. KQ 2 considers whether there are any individual factors (age, race, parity [number of live births], history of mood disorders, perinatal outcomes, cultural factors, and history of intimate partner violence) that affect the baseline risk of postpartum depression and therefore the subsequent positive and negative predictive values of screening instruments. KQ 3 considers whether the performance characteristics (sensitivity, specificity, and predictive values) of screening instruments are affected by the timing (prenatal, peripartum, or at various times in the first postpartum year), setting of administration (prenatal visit, hospital/birthing center/home, postpartum maternal visit, well-child visit, or other setting), or provider (obstetrician, midwife, pediatrician, family practitioner, or other health care provider). The outcome for KQs 1–3 is a definitive diagnosis of depression based on Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision (DSM-IV-TR) criteria using a validated instrument. KQ 4 considers the potential benefits of screening for postpartum depression, including improved symptoms of depression, improved quality of life, reduced maternal suicidal or infanticidal behavior, improved infant/child health and development outcomes, and appropriate health resource utilization. KQ 5 considers possible harms associated with screening, including stigmatization, decreased quality of life, and inappropriate health resource utilization. Both KQ 4 and KQ 5 consider intermediate outcomes such as receipt of appropriate diagnostic and treatment services for symptoms of depression, scores on validated measures of maternal well-being and parenting, and breastfeeding (such as proportion initiating breastfeeding or duration of breastfeeding). Paternal outcomes, including scores on validated mental health instruments, health-related quality of life, and health system resource utilization, are also considered in both KQ 4 and KQ 5. KQ 6 asks whether the likelihood of an appropriate action (defined as receipt of appropriate diagnostic and treatment services for symptoms of depression) after a positive screening result is affected by the same timing, setting, and patient characteristic variables considered in KQs 2 and 3. Note that this review does not consider questions regarding the safety and/or effectiveness of downstream options for postpartum depression treatment. Treatment options are being addressed in a separate AHRQ CER (currently in progress) that will be published as a separate report.

This figure depicts the KQs within the context of the PICOTS described in the Methods section of this report. In general, the figure shows that the population of interest is pregnant women and women during the first 12 months postpartum. (Fathers and domestic partners were also considered, as specified in Table 3. For clarity, those groups are not depicted here.) KQ 1 focuses on the sensitivity and specificity of currently available screening instruments for detecting postpartum depression. KQ 2 considers whether there are any individual factors (age, race, parity [number of live births], history of mood disorders, perinatal outcomes, cultural factors, and history of intimate partner violence) that affect the baseline risk of postpartum depression and therefore the subsequent positive and negative predictive values of screening instruments. KQ 3 considers whether the performance characteristics (sensitivity, specificity, and predictive values) of screening instruments are affected by the timing (prenatal, peripartum, or at various times in the first postpartum year), setting of administration (prenatal visit, hospital/birthing center/home, postpartum maternal visit, well-child visit, or other setting), or provider (obstetrician, midwife, pediatrician, family practitioner, or other health care provider). The outcome for KQs 1–3 is a definitive diagnosis of depression based on “Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision” (DSM-IV-TR) criteria using a validated instrument. KQ 4 considers the potential benefits of screening for postpartum depression, including improved symptoms of depression, improved quality of life, reduced maternal suicidal or infanticidal behavior, improved infant/child health and development outcomes, and appropriate health resource utilization. KQ 5 considers possible harms associated with screening, including stigmatization, decreased quality of life, and inappropriate health resource utilization. Both KQ 4 and KQ 5 consider intermediate outcomes such as receipt of appropriate diagnostic and treatment services for symptoms of depression, scores on validated measures of maternal well-being and parenting, and breastfeeding (such as proportion initiating breastfeeding or duration of breastfeeding). Paternal outcomes, including scores on validated mental health instruments, health-related quality of life, and health system resource utilization, are also considered in both KQ 4 and KQ 5. KQ 6 asks whether the likelihood of an appropriate action (defined as receipt of appropriate diagnostic and treatment services for symptoms of depression) after a positive screening result is affected by the same timing, setting, and patient characteristic variables considered in KQs 2 and 3. Note that this review does not consider questions regarding the safety and/or effectiveness of downstream options for postpartum depression treatment. Treatment options are being addressed in a separate AHRQ CER (currently in progress) that will be published as a separate report.