# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual Peer Reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Lee Cohen, M.D.
  Director, Perinatal and Reproductive Psychiatry Clinical Research Program, Massachusetts General Hospital
  Associate Professor of Psychiatry, Harvard Medical School
  Boston, MA
- Emily Feinberg, Sc.D., M.Sc., M.S.N.
  Associate Professor of Pediatrics, Boston University School of Medicine
  Boston, MA
- Patricia Fontaine, M.D., M.S.
  Associate Professor, Department of Family Medicine and Community Health
  University of Minnesota
  Minneapolis, MN
- Katherine Hartmann, M.D., Ph.D.
  Professor of Medicine and of Obstetrics and Gynecology, Vanderbilt University School of Medicine
  Deputy Director, Institute of Medicine and Public Health
  Nashville, TN
- Jane Honikman, M.S.
  Founder and Former Executive Director, Postpartum Support International
  Santa Barbara, CA
- Samantha Meltzer-Brody, M.D.
  Associate Professor and Director, Perinatal Psychiatry Program
  University of North Carolina Center for Women’s Mood Disorders
  Chapel Hill, NC
- Sarah Hudson Scholle, Dr.PH., M.P.H.
  Vice President of Research and Analysis, National Committee for Quality Assurance
  Washington, DC