# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- William H. Barth, Jr., M.D.
  Associate Professor of Obstetrics, Gynecology and Reproductive Biology, Harvard Medical School
  Chair, Committee on Obstetric Practice, American College of Obstetricians and Gynecologists
  Boston, MA
- Lisa Begg, Dr.P.H., R.N.
  Director of Research Programs, Office of Research on Women’s Health
  National Institutes of Health
  Bethesda, MD
- Wendy N. Davis, Ph.D.
  Executive Director, Postpartum Support International
  Portland, OR
- Denise M. Dougherty, Ph.D.
  Senior Advisor, Child Health and Quality Improvement
  Agency for Healthcare Research and Quality
  Rockville, MD
- Marian Earls, M.D.
  Former Medical Director, Guilford Child Health, Inc.
  Member, Committee on the Psychosocial Aspects of Child and Family Health, American Academy of Pediatrics
  Greensboro, NC
- Tina Groat, M.D., M.B.A.
  National Medical Director for Women’s Health, United Healthcare
  Edina, MN
- Karen Hench, M.S., R.N.
  Past Acting Division Director, Division of Healthy Start and Perinatal Services
  Maternal and Child Health Bureau
  Rockville, MD
- Deborah Karsnitz, D.N.P., C.N.M.
  Faculty Course Coordinator, Frontier Nursing University
  President, Kentucky State Affiliate, American College of Nurse Midwives
  Louisville, KY
- Susan G. Kornstein, M.D.
  Immediate Past President, International Association for Women’s Mental Health
  Professor of Psychiatry and Obstetrics/Gynecology, Virginia Commonwealth University
  Richmond, VA
- Virginia Moyer, M.D., M.P.H.
  Professor of Pediatrics, Baylor College of Medicine
  Chair, United States Preventive Services Task Force
  Houston, TX
- Michael O’Hara, Ph.D.
  Professor of Psychology and Starch Faculty Fellow
  University of Iowa
  Iowa City, IA
- Peter J. Schmidt, M.D.
  Chief, Section on Behavioral Endocrinology
  National Institute of Mental Health
  Bethesda, MD
- Caroline Signore, M.D., M.P.H.
  Program Scientist, Pregnancy and Perinatal Branch, Eunice Kennedy Shriver National Institute of Child Health and Human Development
  Fellow, American College of Obstetricians and Gynecologists
  Rockville, MD
- Barbara Yawn, M.D., M.Sc.
  Director of Research, Olmsted Medical Center
  Adjunct Professor, Department of Family and Community Health, University of Minnesota
  Rochester, MN
- Kimberly Ann Yonkers, M.D.
  Professor of Psychiatry and Obstetrics, Gynecology, and Reproductive Sciences, Yale School of Medicine
  New Haven, CT