# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Lisa Begg, Dr.P.H., R.N.
  Director of Research Programs, Office of Research on Women’s Health
  National Institutes of Health
  Bethesda, MD
- Wendy N. Davis, Ph.D.
  Executive Director, Postpartum Support International
  Portland, OR
- Denise M. Dougherty, Ph.D.
  Senior Advisor, Child Health and Quality Improvement
  Agency for Healthcare Research and Quality
  Rockville, MD
- Marian Earls, M.D.
  Former Medical Director, Guilford Child Health, Inc.
  Member, Committee on the Psychosocial Aspects of Child and Family Health, American Academy of Pediatrics
  Greensboro, NC
- Tina Groat, M.D., M.B.A.
  National Medical Director for Women’s Health, United Healthcare
  Edina, MN
- Karen Hench, M.S., R.N.
  Past Acting Division Director, Division of Healthy Start and Perinatal Services
  Maternal and Child Health Bureau
  Rockville, MD
- Deborah Karsnitz, D.N.P., C.N.M.
  Faculty Course Coordinator, Frontier Nursing University
  President, Kentucky State Affiliate, American College of Nurse Midwives
  Louisville, KY
- Susan G. Kornstein, M.D.
  Immediate Past President, International Association for Women’s Mental Health
  Professor of Psychiatry and Obstetrics/Gynecology, Virginia Commonwealth University
  Richmond, VA
- Caroline Signore, M.D., M.P.H.
  Program Scientist, Pregnancy and Perinatal Branch, Eunice Kennedy Shriver National Institute of Child Health and Human Development
  Fellow, American College of Obstetricians and Gynecologists
  Rockville, MD
- Barbara Yawn, M.D., M.Sc.
  Director of Research, Olmsted Medical Center
  Adjunct Professor, Department of Family and Community Health, University of Minnesota
  Rochester, MN
- Kimberly Ann Yonkers, M.D.
  Professor of Psychiatry and Obstetrics, Gynecology, and Reproductive Sciences, Yale School of Medicine
  New Haven, CT