# Acknowledgments

The authors thank Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval; Rachael Posey, M.S.L.S., for assistance with project coordination; and William Meyer, M.S.W., L.C.S.W., for assistance during the topic refinement phase.