# Conclusions

The USPSTF recommends screening for depression in adults when adequate resources are available to ensure appropriate diagnostic and therapeutic services. The current evidence for women in the postpartum period is consistent with that recommendation. The prevalence of depression is similar to that observed in other women of the same age who are not pregnant or postpartum, the sensitivity and specificity of the available screening tests are similar, and although there is no direct evidence of the variability in outcomes by setting, indirect comparisons across a small number of studies suggest that the receipt of appropriate services is much higher when screening, diagnosis, and treatment are provided by the same provider or practice, and depressive symptoms are substantially improved. The ideal characteristics of a screening test for postpartum depression, including sensitivity, specificity, timing, and frequency, have not been defined. Because the balance of benefits and harms, at both the individual level and health system level, is highly dependent on these characteristics, broad consensus on these characteristics is needed.