# Study Characteristics Table

Appendix Table E-1 Characteristics of included studies

## References to Appendix E

1 Akincigil A, Munch S, Niemczyk KC. Predictors of maternal depression in the first year postpartum: marital status and mediating role of relationship quality. Soc Work Health Care. 2010;49(3):227-44. [pmid: 20229395].
2 Andersson L, Sundstrom-Poromaa I, Wulff M, et al. Depression and anxiety during pregnancy and six months postpartum: a follow-up study. Acta Obstet Gynecol Scand. 2006;85(8):937-44. [pmid: 16862471].
3 Austin MP, Colton J, Priest S, et al. The Antenatal Risk Questionnaire (ANRQ): Acceptability and use for psychosocial risk assessment in the maternity setting. Women Birth. 2011. Jul. 16. [Epub ahead of print]. Women Birth. 2011. [pmid: 21764399].
4 Austin MP, Hadzi-Pavlovic D, Priest SR, et al. Depressive and anxiety disorders in the postpartum period: how prevalent are they and can we improve their detection?. Arch Women Ment Health. 2010;13(5):395-401. [pmid: 20232218].
5 Barnes J, Senior R, MacPherson K. The utility of volunteer home-visiting support to prevent maternal depression in the first year of life. Child Care Health Dev. 2009;35(6):807-16. [pmid: 19719770].
6 Beck CT, Froman RD, Bernal H. Acculturation level and postpartum depression in Hispanic mothers. MCN Am J Matern Child Nurs. 2005;30(5):299-304. [pmid: 16132006].
7 Beck CT, Gable RK. Screening performance of the postpartum depression screening scale—Spanish version. J Transcult Nurs. 2005;16(4):331-8. [pmid: 16160195].
8 Bloch M, Rotenberg N, Koren D, et al. Risk factors associated with the development of postpartum mood disorders. J Affect Disord. 2005;88(1):9-18. [pmid: 15979150].
9 Boyce P, Hickey A. Psychosocial risk factors to major depression after childbirth. Soc Psychiatry Psychiatr Epidemiol. 2005;40(8):605-12. [pmid: 16096700].
10 Burton A, Patel S, Kaminsky L, et al. Depression in pregnancy: time of screening and access to psychiatric care. J Matern Fetal Neonatal Med. 2011;24(11):1321-4. [pmid: 21261444].
11 Chaudron LH, Szilagyi PG, Tang W, et al. Accuracy of depression screening tools for identifying postpartum depression among urban mothers. Pediatrics. 2010;125(3):e609-17. [pmid: 20156899].
12 Chee CY, Chong YS, Ng TP, et al. The association between maternal depression and frequent non-routine visits to the infant’s doctor—a cohort study. J Affect Disord. 2008;107(1–3):247-53. [pmid: 17869346].
13 Chee CY, Lee DT, Chong YS, et al. Confinement and other psychosocial factors in perinatal depression: a transcultural study in Singapore. J Affect Disord. 2005;89(1–3):157-66. [pmid: 16257451].
14 Clarke PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. 2008;40(1):113-25. [pmid: 18459275].
15 Crotty F, Sheehan J. Prevalence and detection of postnatal depression in an Irish community sample. Ir J Psychol Med. 2004;21(4):117-21.
16 Csatordai S, Kozinszky Z, Devosa I, et al. Validation of the Leverton Questionnaire as a screening tool for postnatal depression in Hungary. Gen Hosp Psychiatry. 2009;31(1):56-66. [pmid: 19134511].
17 Edmondson OJ, Psychogiou L, Vlachos H, et al. Depression in fathers in the postnatal period: assessment of the Edinburgh Postnatal Depression Scale as a screening measure. J Affect Disord. 2010;125(1–3):365-8. [pmid: 20163873].
18 Ekeroma AJ, Ikenasio-Thorpe B, Weeks S, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) as a screening tool for postnatal depression in Samoan and Tongan women living in New Zealand. N Z Med J. 2012;125(1355):41-9. [pmid: 22722214].
19 Felice E, Saliba J, Grech V, et al. Validation of the Maltese version of the Edinburgh Postnatal Depression Scale. Arch Women Ment Health. 2006;9(2):75-80. [pmid: 16172837].
20 Felice E, Saliba J, Grech V, et al. Prevalence rates and psychosocial characteristics associated with depression in pregnancy and postpartum in Maltese women. J Affect Disord. 2004;82(2):297-301. [pmid: 15488261].
21 Flynn HA, O’Mahen HA, Massey L, et al. The impact of a brief obstetrics clinic-based intervention on treatment use for perinatal depression. J Womens Health (Larchmt). 2006;15(10):1195-204. [pmid: 17199460].
22 Garcia-Esteve L, Navarro P, Ascaso C, et al. Family caregiver role and premenstrual syndrome as associated factors for postnatal depression. Arch Women Ment Health. 2008;11(3):193-200. [pmid: 18506575].
23 Gjerdingen D, McGovern P, Center B. Problems with a diagnostic depression interview in a postpartum depression trial. J Am Board Fam Med. 2011;24(2):187-93. [pmid: 21383219].
24 Gjerdingen D, Crow S, McGovern P, et al. Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. 2009;7(1):63-70. [pmid: 19139451].
25 Glavin K, Smith L, Sorum R, et al. Redesigned community postpartum care to prevent and treat postpartum depression in women—a one-year follow-up study. J Clin Nurs. 2010;19(21–22):3051-62. [pmid: 20726926].
26 Goodman JH, Tyer-Viola L. Detection, treatment, and referral of perinatal depression and anxiety by obstetrical providers. J Womens Health (Larchmt). 2010;19(3):477-90. [pmid: 20156110].
27 Hamdan A, Tamim H. Psychosocial risk and protective factors for postpartum depression in the United Arab Emirates. Arch Women Ment Health. 2011;14(2):125-33. [pmid: 21063891].
28 Howard LM, Flach C, Mehay A, et al. The prevalence of suicidal ideation identified by the Edinburgh Postnatal Depression Scale in postpartum women in primary care: findings from the RESPOND trial. BMC Pregnancy Childbirth. 2011;11:57. [pmid: 21812968].
29 Jardri R, Pelta J, Maron M, et al. Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. 2006;93(1–3):169-76. [pmid: 16644021].
30 Ji S, Long Q, Newport DJ, et al. Validity of depression rating scales during pregnancy and the postpartum period: impact of trimester and parity. J Psychiatr Res. 2011;45(2):213-9. [pmid: 20542520].
31 Kersting A, Kroker K, Steinhard J, et al. Complicated grief after traumatic loss: A 14-month follow up study. Eur Arch Psychiatry Clin Neurosci. 2007;257(8):437-43. [pmid: 17629729].
32 Leung SS, Leung C, Lam TH, et al. Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292-301. [pmid: 20884642].
33 Mann R, Adamson J, Gilbody SM. Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. 2012;184(8):E424-30. [pmid: 22451686].
34 Mauri M, Oppo A, Montagnani MS, et al. Beyond “postpartum depressions”: specific anxiety diagnoses during pregnancy predict different outcomes: results from PND-ReScU. J Affect Disord. 2010;127(1–3):177-84. [pmid: 20554326].
35 Mauri M, Oppo A, Borri C, et al. SUICIDALITY in the perinatal period: comparison of two self-report instruments. Results from PND-ReScU. Arch Women Ment Health. 2012;15(1):39-47. [pmid: 22215284].
36 Morrell CJ, Slade P, Warner R, et al. Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: Pragmatic cluster randomised trial in primary care. BMJ. 2009;338(7689):276-9.
37 Navarro P, Ascaso C, Garcia-Esteve L, et al. Postnatal psychiatric morbidity: a validation study of the GHQ-12 and the EPDS as screening tools. Gen Hosp Psychiatry. 2007;29(1):1-7. [pmid: 17189737].
38 Pereira AT, Bos S, Marques M, et al. The Portuguese version of the postpartum depression screening scale. J Psychosom Obstet Gynaecol. 2010;31(2):90-100. [pmid: 20443658].
39 Rowan P, Greisinger A, Brehm B, et al. Outcomes from implementing systematic antepartum depression screening in obstetrics. Arch Women Ment Health. 2012;15(2):115-20. [pmid: 22382279].
40 Siu BWM, Leung SSL, Ip P, et al. Antenatal risk factors for postnatal depression: A prospective study of chinese women at maternal and child health centres. BMC Psychiatry. 2012;12(22).
41 Turner K, Piazzini A, Franza A, et al. Epilepsy and postpartum depression. Epilepsia. 2009;50(Suppl 1):24-7. [pmid: 19125843].
42 Verkerk GJ, Denollet J, Van Heck GL, et al. Personality factors as determinants of depression in postpartum women: a prospective 1-year follow-up study. Psychosom Med. 2005;67(4):632-7. [pmid: 16046379].
43 Yawn BP, Dietrich AJ, Wollan P, et al. TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Ann Fam Med. 2012;10(4):320-9. [pmid: 22778120].
44 Yonkers KA, Smith MV, Lin H, et al. Depression screening of perinatal women: an evaluation of the healthy start depression initiative. Psychiatr Serv. 2009;60(3):322-8. [pmid: 19252044].
45 Zlotnick C, Miller IW, Pearlstein T, et al. A preventive intervention for pregnant women on public assistance at risk for postpartum depression. Am J Psychiatry. 2006;163(8):1443-5. [pmid: 16877662].