# Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reason indicated in bold. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Full-Text Unavailable

Buist AE, Bilszta J. Perinatal mental illness: Identifying and managing women at risk. Med Today. 2011;12(1):64-8.

## Not a Full Publication (Abstract Only), or Not Original Peer-Reviewed Data

ABM clinical protocol #18: Use of antidepressants in nursing mothers. Breastfeeding Medicine. 2008;3(1):44-52. [pmid: 18333769].
Committee opinion no. 453: Screening for depression during and after pregnancy. Obstet Gynecol. 2010;115(2 Pt 1):394-5. [pmid: 20093921].
Depression in pregnant women and mothers: How children are affected. Paediatrics and Child Health. 2004;9(8):584-586. 599. 601. [pmid: 19680491].
Maternal depression and child development. Paediatrics and Child Health. 2004;9(8):575-583. 589. 598. [pmid: 19680490].
Postpartum depression. Am Fam Physician. 2010;82(8):939-40. [pmid: 20949887].
Psychosocial risk factors: Perinatal screening and intervention. Obstetrics and Gynecology. 2006;108(2):469-477. [pmid: 16880322].
Screening for depression during and after pregnancy. Obstetrics and Gynecology. 2010;115(2 PART 1):394-395. [pmid: 20093921].
Adams C, Coyle B, Hanley J, et al. Perinatal mental health. Community Pract. 2006;79(12):385-7. [pmid: 17256281].
Adolfsson A. Meta-analysis to obtain a scale of psychological reaction after perinatal loss: focus on miscarriage. Psychol Res Behav Manag. 2011;4:29-39. [pmid: 22114533].
Ahmad Z, Ishag S, Palamarachuk T, et al. Are we asking the right questions to screen for perinatal mental health?. BJOG: An International Journal of Obstetrics and Gynaecology. 2012;119(SUPPL 1):119-120.
Ahmed AS, Khoosal D. Assessment and management of depression. Foundation Years. 2009;5(1):2-6.
Akbari SAA, Nouraei S, Bahry M, et al. Relation between maternity anxiety during pregnancy and postpartum depression. BJOG: An International Journal of Obstetrics and Gynaecology. 2012;119(SUPPL 1):120.
Ambrosini A, Donzelli G, Stanghellini G. Early perinatal diagnosis of mothers at risk of developing post-partum depression - a concise guide for obstetricians, midwives, neonatologists and paediatricians. J Matern Fetal Neonatal Med. 2011. Nov. 9. [Epub ahead of print]. [pmid: 21919554].
Ammerman RT, Putnam FW, Stevens J, et al. Sample retention in a clinical trial with depressed mothers in home visitation. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S59.
Austin MP. Antenatal screening and early intervention for ‘perinatal’ distress, depression and anxiety: Where to from here?. Archives of Women’s Mental Health. 2004;7(1):1-6.
Banti S, Borri C, Ramacciotti D, et al. The role of early screening in perinatal depression: Preliminary data for the PND-Rescu (registered trademark) II. European Psychiatry. 2012;27(1).
Beckwith J, Zhang H, Green S, et al. Stress, anxiety and mood in pregnant women. Psychosomatic Medicine. 2011;73(3):A4.
Bener A. Comparative study of postpartum depression and its predictors in Qatar. European Psychiatry. 2012;27(1):2012-03.
Bener A. Depressive, anxiety and stress disorders in the postpartum period: How prevalent are they and can we improve their detection? A major public health problem. European Psychiatry. 2012;27(1):2012-03.
Benni L, Innocenti A, Giardinelli L. Depression and anxiety in perinatal period: Prevalence and risk factors in an italian sample. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S9-S10.
Berard A, Karam F, Sheehy O, et al. Relapse of depression in pregnant users and discontinued users of antidepressants: Results from the OTIS Antidepressants Study. Journal of Population Therapeutics and Clinical Pharmacology. 2011;18(2):e186-e187.
Berard A, Karam F, Sheehy O, et al. Relapse of depressive and anxiety symptoms, and quality-of-life in pregnant users and discontinued users of antidepressants: Results from the OTIS Antidepressants Study. Journal of Population Therapeutics and Clinical Pharmacology. 2011;18(2):e285-e286.
Berman D, Campbell E, Lopez J, et al. Maternal depression and impaired fetal growth. American Journal of Obstetrics and Gynecology. 2012;206(1):S359.
Bina R. Enhancing treatment utilization for postpartum depression. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S10.
Bishop KK. Utilization of the Stetler model: evaluating the scientific evidence on screening for postpartum depression risk factors in a primary care setting. Ky Nurse. 2007;55(1):7. [pmid: 17348601].
Bloch M, Meiboom H, Lorberblat M, et al. Treatment of postpartum depression with psychotherapy and add-on sertraline: A double-blind, randomised, placebo-controlled study. European Neuropsychopharmacology. 2011;21(SUPPL 3):S359-S360.
Bogen D. Electronic reminder systems increase screening for postpartum depression. Journal of Pediatrics. 2009;155(5):758-759. [pmid: 19840622].
Bond S. Edinburgh Postnatal Depression Scale More Efficient Than Others When Screening for Postpartum Depression. Journal of Midwifery and Women’s Health. 2008;53(5):473-474.
Born L, Zinga D, Steiner M. Challenges in Identifying and Diagnosing Postpartum Disorders. Primary Psychiatry. 2004;11(3):29-36.
Bortner JL, Sapotichne BF, Stepp SD, et al. Examining the overlap between borderline personality disorder symptoms and postpartum depression in adolescent mothers. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S61.
Buist A, Udechuku A. Maternal depression: Postnatal or perinatal?. Medicine Today. 2007;8(11):38-46.
Buttner M, Kopelman RC, Stuart SP. Seeking care for perinatal depression: What do women really worry about. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S12-S13.
Buttner MM, Stuart S, O’Hara MW. Moving beyond the EPDS: The association between postpartum depressive symptoms and premenstrual dysphoric disorder. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S62.
Cantwell R, Cox JL. Psychiatric disorders in pregnancy and the puerperium. Current Obstetrics and Gynaecology. 2006;16(1):14-20.
Cantwell R, Smith S. Prediction and prevention of perinatal mental illness. Psychiatry. 2006;5(1):15-21.
Cantwell R, Smith S. Prediction and prevention of perinatal mental illness. Psychiatry. 2009;8(1):21-27.
Caramlau I, Barlow J, Sembi S, et al. Mums 4 Mums: structured telephone peer-support for women experiencing postnatal depression. Pilot and exploratory RCT of its clinical and cost effectiveness. Trials. 2011;12:88. [pmid: 21439042].
Carvalho Bos S, MacEdo A, Marques M, et al. Is positive affect in late pregnancy protective of postpartum depression?. Archives of Disease in Childhood: Fetal and Neonatal Edition. 2010;95(SUPPL 1):Fa34.
Chaudron LH, Cerulli C, Chin N. Exploring the nexus between intimate partner violence, depression and breastfeeding. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S13-S14.
Chaudron LH, Szilagyi PG, Tang W, et al. The accuracy of the PHQ-9 and CES-D for postpartum depression in an urban pediatric clinic. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S13.
Chen H. Addressing maternal mental health needs in Singapore. Psychiatr Serv. 2011;62(1):102. [pmid: 21209310].
Chessick C, Schwartz E, McDonald J, et al. Sensitivity and specificity of the Mood Disorder Questionnaire in the perinatal population. Bipolar Disorders. 2011;13(SUPPL 1):35.
Chiappini S, D’Oria L, Righino E, et al. Psychosocial risk factors for postpartum depression: A descriptive sample of pregnants. European Psychiatry. 2012;27(1):2012-03.
Chin L, Stock A, Jordan B, et al. Postnatal depression within the paediatric emergency department. Archives of Disease in Childhood. 2011;96(SUPPL 1):A86-A87.
Conde A, Figueiredo B, Bifulco A. Father’s attachment style and psychological adjustment during pregnancy and the postpartum period. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S15.
Costantino ML. Post-birth screening in Pittsburgh, PA: Results from an NIMH-funded study. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S16-S17.
Da Costa D, Ireland K, Banack H, et al. Factors associated with abnormal birthweight among full-term infants. Reproductive Sciences. 2011;18(3):85A.
Darwin Z, McGowan L, Edozien L. Depression case finding in antenatal care: Is routine use of the Whooley questions making a difference?. Journal of Reproductive and Infant Psychology. 2011;29(3):e4.
Dennis CL, Dukhovny D, Hodnett E, et al. Prospective economic evaluation of a peer support intervention for prevention of postpartum depression among high risk women. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S17.
Deole N, Darwin L, Grammatopoulos D, et al. Polymorphic variation in the glucocorticoid receptor gene: Association with susceptibility to postnatal depression. Reproductive Sciences. 2011;18(3):104A.
DeRosa N, Logsdon MC. A comparison of screening instruments for depression in postpartum adolescents. J Child Adolesc Psychiatr Nurs. 2006;19(1):13-20. [pmid: 16464212].
Dhami NK, Peterson KL, Mocnik BA. Program development and outcome evaluation of a hospital-based intensive outpatient treatment program for perinatal psychiatric disorders. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S57.
Dorheim S, Bondevik GT, Eberhard-Gran M, et al. Sleep and depression among postnatal women - A population based questionnaire study supplemented by sleep diary and actigraphy. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S17-S18.
Douglas P, Hill P. Managing infants who cry excessively in the first few months of life. BMJ. 2011;343(7836):1265-1269. [pmid: 22174332].
Driscoll JW. Postpartum depression: the state of the science. J Perinat Neonatal Nurs. 2006;20(1):40-2. [pmid: 16508460].
Earls MF. Clinical report—Incorporating recognition and management of perinatal and postpartum depression into pediatric practice. Pediatrics. 2010;126(5):1033-1039.
Eaton CL, Savola-Levin KJ. One year design and implementation of an integrated system for screening, diagnosis, and treatment of perinatal depression at a large HMO. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S64-S65.
Ekeroma A, Ikenasio-Thorpe B, Weeks S, et al. Validation of the edinburgh postnatal depression scale (EPDS) as a screening tool for postnatal depression (PND) in samoan and tongan women. Journal of Paediatrics and Child Health. 2011;47(SUPPL 1):21.
Elton C. The melancholy of motherhood. Time. 2009;174(2):55-6. [pmid: 19655648].
Engeldinger J, O’Hara MW, King S, et al. Maternal stress during pregnancy: Impact on maternal and child outcomes over 16 months. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S103.
Everard CM, Carroll GO, Khashan A, et al. Prospective cohort study to examine the association between maternal anxiety and depression and subsequent pregnancy outcomes. Archives of Disease in Childhood: Fetal and Neonatal Edition. 2010;95(SUPPL 1):Fa35-36.
Everard CM, O’Carrol G, Khashan A, et al. Prospective cohort study to examine the association between maternal anxiety and depression and subsequent pregnancy outcomes. Reproductive Sciences. 2010;17(3):309A.
Everest T, Nutt B. Mental health and pregnancy. The link between prenatal and postpartum depression. Adv Nurse Pract. 2007;15(7):61-4. [pmid: 19998999].
Feher Z, Palfy A, Szabo E, et al. Determinants of depressive symptoms in women screened for gestational diabetes 3 years after delivery. Diabetologia. 2011;54(SUPPL 1):S474.
Fernandezy Garcia E, Joseph J, Hinton L, et al. Targeted depression education increases mothers’ mental healthcare seeking. Clinical and Translational Science. 2012;5(2):155.
Feucht C. Treatment of depression during pregnancy. U.S. Pharmacist. 2007;32(9):34-44.
Field T, Hernandez-Reif M, Diego M. Intrusive and withdrawn depressed mothers and their infants. Developmental Review. 2006;26(1):15-30.
Fisher J, Haseler S, Chatham E, et al. Implementing the national perinatal depression initiative screening recommendations: Women’s hospitals Australasia (WHA) members’ experiences. Journal of Paediatrics and Child Health. 2012;48(SUPPL 1):120.
Fisher J, Rowe H, Wynter K. What were we thinking! An innovative psycho-educational program to prevent common postpartum mental disorders in women. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S20.
Fisher SD, O’Hara MW, Kopelman R, et al. The influence of parental mood and marital adjustment on child behavior. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S65.
Flanagan T, Mosen S, White H, et al. Computerized skills-based psychotherapy for postpartum depression versus treatment as usual. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S65-S66.
Flynn HA, O’Mahen HA, Himle J, et al. Understanding and overcoming challenges to engaging and retaining low income depressed women into treatment in the context of obstetrical care. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S66.
Flynn HA, Sexton M, Vazquez D, et al. The trajectory of perinatal depression, psychosocial and neuroedocrine measures and the impact of treatment on maternal and infant outcomes. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S21.
Fox EM. Perinatal depression: A health plan awareness initiative. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S66-S67.
Freda MC. The state of the science: maternal-child health research. Am J Nurs. 2005;105(1):52. [pmid: 15659996].
Freeman MP. Screening and treatment for women with mood disorders associated with reproductive events. J Clin Psychiatry. 2007;68(12):1946. [pmid: 18162027].
Gaynes BN, Gavin N, Meltzer-Brody S, et al. Perinatal depression: prevalence, screening accuracy, and screening outcomes. Evid Rep Technol Assess (Summ). 2005;(119):1-8. [pmid: 15760246].
Glover V. The long lasting effects of perinatal stress, anxiety and depression on the child. Journal of Psychosomatic Research. 2012;72(6):482.
Goeser AL. Postpartum depression. U.S. Pharmacist. 2008;33:11.
Goldbort JG. Collaborative initiatives for postpartum depression. AWHONN Lifelines. 2005;9(5):377-81. [pmid: 16359076].
Goncnullalves MP, Teixeira F, Monteiro A, et al. Postnatal depression in mothers and fathers: Correlation with psychosocial and hormonal variables. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S24.
Gourounti K, Anagnostopoulos F, Paparisteidis N, et al. The impact of psychological stress on pregnancy outcome among women undergoing in-vitro fertilization. Human Reproduction. 2011;26(SUPPL 1):i79.
Goyal D, Shen J, Wong E, et al. Clinically identified postpartum depression in asian american mothers. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S25.
Greene JA, Fried EL, Harney K. Differences in referral for services and mental health care utilization in postpartum depression: A comparison by racial/ethnic group and language of care. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S25-S26.
Haga SM, Kalkvik H, Slinning K, et al. Postpartum depressive symptoms and life satisfaction: The role of self-efficacy and social support. Archives of Women’s Mental Health. 2011;14(suppl 1):S69.
Harcha HL. Detection of postpartum depression at well-child visits. Ky Nurse. 2006;54(2):15. [pmid: 16646541].
Haworth K. Incidence and severity of postpartum depression among military beneficiaries: A performance improvement project. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S69-S70.
Haynes C. The issues associated with postpartum major depression. Midwifery Today Int Midwife. 2007;(83):44-5. 68. 9. [pmid: 17927125].
Helbig A, Kaasen A, Malt UF, et al. Does maternal psychological distress in second trimester of pregnancy affect feto-placental volume blood flow in third trimester?. Placenta. 2011;32(9):A98.
Henshaw CA, Foreman DM, Cox JL. Longitudinal follow up of postpartum blues and depression: Long term morbidity in women and children. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S27.
Herguner S, Cicekcnulli E, Annagur A, et al. Postpartum depression in mothers of infants with very low birth weight. European Psychiatry. 2012;27(1):2012-03.
Horowitz JA, Murphy CA, Gregory KE, et al. Best practices: community-based postpartum depression screening: results from the CARE study. Psychiatr Serv. 2009;60(11):1432-4. [pmid: 19880456].
Howard L, Chew-Graham CA, Tylee A, et al. The RESPOND trial: A randomized evaluation of antidepressants and support for women with postnatal depression. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S30.
Howard L, Flach C, Heron J, et al. Antenatal domestic violence, psychiatric morbidity and subsequent child behaviour. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S29-S30.
Howard LM, Flach C, Leese M, et al. Antenatal domestic violence, maternal mental health and subsequent child behaviour. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S99-S100.
Howard M, Battle C, Creech S, et al. Ten years later: Changes in clinical and demographic profile of perinatal women seeking day hospital treatment. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S30-S31.
Howell EA, Balbierz A, Jason W, et al. Mothers avoiding depression through empowerment intervention trial (made it). Journal of General Internal Medicine. 2011;26(SUPPL 1):S222-S223.
Hromi-Fiedler A, Bermudez-Millan A, Chapman D, et al. Food insecurity is a risk factor for elevated levels of depression symptoms among low-income pregnant Latinas. FASEB Journal. 2010;24.
Imaz ML, Gelabert E, Garcia Esteve L, et al. Smoking during pregnancy and postnatal period and postpartum depression. European Psychiatry. 2012;27(1):2012-03.
Imaz ML, Gelabert E, Navarro P, et al. Pregnancy-related substance use as a risk factor for postpartum depression and poor neonatal adaptation. European Neuropsychopharmacology. 2011;21(SUPPL 3):S574.
Isaac C, Schlife J. More than the blues: perinatal depression. Nebr Nurse. 2007;40(3):8-13. quiz 14-5, 23. [pmid: 17915611].
Isser NK, Schwartz LL. Engendered homicide. Journal of Psychiatry and Law. 2008;36(4):577-607.
Jomeen J, Martin CR. Prediction of depression in late pregnancy. Value in Health. 2010;13(3):A186.
Junge-Hoffmeister J, Bittner A, Richter J, et al. Preventing peripartal psychosomatic symptoms in pregnant women - Is there an impact on pregnancy and birth complications or neonatal outcomes. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S32.
Karlsson H. Prenatal psychiatry: Findings from three birth cohorts. European Child and Adolescent Psychiatry. 2011;20(SUPPL 1):S42.
Keleher V, Nyunt SZ, Broekman B, et al. Prevalence and risk factors for antenatal depression in pregnant women attending National University Hospital, Singapore. European Psychiatry. 2012;27(1):2012-03.
Kim HG, Cutts DB, Lupo VR, et al. Screening for postpartum depression among low-income mothers using an interactive voice response system. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S33.
Kuehn BM. Report promotes depression screening for mothers during pediatric visits. JAMA. 2011;305(1):26-7. [pmid: 21205958].
Le Donne M, Settineri S, Benvenga S. Early pospartum (PP) alexithymia (AT) and depression(D): Relationship with serumtsh, thyroid hormones (TH) and thyroid autoantibodies (TAB). Thyroid. 2011;21(SUPPL 1):A47.
Legato MJ. The skewed sex distribution in affective disorders--a diagnostic, social, or biological problem?. Prog Brain Res. 2010;186:159-66. [pmid: 21094891].
Leung SSL. The Child Health Programme for Hong Kong. Hong Kong Journal of Paediatrics. 2008;13(4):275-278.
Lieberman KL, Le HN, Perry DF. Correlates of maternal interactive behavior in latina immigrant mothers of 1-year old infants. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S72-S73.
Liepman MR, Kothari CL, Tareen RS, et al. Community-wide intervention reduces post partum depression through promotion of perinatal screening and treatment. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S34.
Liepman MR, Kothari CL, Tareen RS, et al. It’s not a secret anymore: Perinatal women’s disclosure of intimate partner abuse. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S34.
Lincoln JH, Berlin M, Romm J. Obstetrical care providers knowledge, attitudes, and practices related to postpartum depression at Oregon Health & Science University. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S73.
Lydsdottir LB, Olafsdottir H, Thome M, et al. Screening for antenatal depression in an Icelandic cohort study: What are we really identifying?. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S99.
Maccio EM, Pangburn JA. The case for investigating postpartum depression in lesbians and bisexual women. Women’s Health Issues. 2011;21(3):187-190. [pmid: 21521621].
Marin Morales D, Carmona Monge FJ, Toro Molina S, et al. Anxiety in early postpartum and postnatal depression at three months after delivery. Journal of Maternal-Fetal and Neonatal Medicine. 2012;25(SUPPL 2):71.
Maron M, Jardri R, Delion P, et al. Pain in the early postpartum and postnatal depression screening: Symptom or confounding factor. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S35.
Massoudi P, Wickberg B, Hwang P. Postnatal distress in fathers and mothers - Prevalence and correlates in a swedish sample. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S36.
Matthey S. Assessing for psychosocial morbidity in pregnant women. Canadian Medical Association Journal. 2005;173(3):267-269. [pmid: 16076822].
McCarthy FP, Khashan AS, Moss-Morris R, et al. A prospective cohort study to investigate the association between hyperemesis gravidarum and altered cognitive, behavioural and emotional health in pregnancy. Reproductive Sciences. 2010;17(3):289A.
McDonald S, Wall J, Forbes K, et al. Prenatal screening for suboptimal mental health in the postpartum period. American Journal of Epidemiology. 2011;173(SUPPL 11):S151.
McDowell WK. Detecting women at risk for postpartum mood disorders. Nursing. 2008;38(3):57-8. [pmid: 18418187].
McErlean RA, Dadds MR, Austin MP. A randomised controlled trial on intranasal oxytocin as an adjunct to interaction coaching to improve maternal bonding in women with mild postpartum depression. Biological Psychiatry. 2011;69(9):134S.
McQueen K, Montgomery P, Lappan-Gracon S, et al. Evidence-based recommendations for depressive symptoms in postpartum women. J Obstet Gynecol Neonatal Nurs. 2008;37(2):127-36. [pmid: 18336436].
Meijer JL, Bockting CL, Beijers C, et al. PRegnancy Outcomes after a Maternity Intervention for Stressful EmotionS (PROMISES): study protocol for a randomised controlled trial. Trials. 2011;12:157. [pmid: 21689394].
Meltzer-Brody S, Grewen K, Stuebe A, et al. Neuroendocrine pathophysiology in postpartum depression and lactation failure. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S37.
Meltzer-Brody S, Zerwas S, Leserman J, et al. Eating disorders in women with perinatal depression. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S36.
Meltzer-Brody S. Understanding and treating mood disorders across the reproductive years. Sexuality, Reproduction and Menopause. 2010;8(4):12-18.
Meltzer-Brody SE. Phenotyping, prevalence, and genetic signature of postpartum depression in the nesda GWAS study. Biological Psychiatry. 2012;71(8 SUPPL 1):12S.
Milgrom J, Mendelsohn J, Gemmill AW. Does postnatal depression screening work? Throwing out the bathwater, keeping the baby. J Affect Disord. 2011;132(3):301-10. [pmid: 20952072].
Miller ES, Chu C, Gossett DR. Postpartum obsessive compulsive disorder: Its prevalence, risk factors, and clinical course. Reproductive Sciences. 2011;18(3):378A-379A.
Mitchell AJ, Coyne J. Screening for postnatal depression: barriers to success. BJOG. 2009;116(1):11-4. [pmid: 19016688].
Mohamed A, Arya Sameera VM, George A. Determinants of obesity in women during first five years postpartum. Australasian Medical Journal. 2010;3(3):222-223.
Monteiro AG, Areias ME, Goncnullalves MP, et al. Impact of parental depression over cognitive and psychomotor development of babies during the first year of life. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S76.
Moore D, Ayers S. A review of postnatal mental health websites: Help for healthcare professionals and patients. Archives of Women’s Mental Health. 2011;14(6):443-452.
Morrell J, Slade P, Walters S. The health of postnatal women’s partners up to 18 months postnatally: A longitudinal survey alongside a randomised controlled trial. Journal of Reproductive and Infant Psychology. 2011;29(3):e12-e13.
Mounts KO. Screening for maternal depression in the neonatal ICU. Clin Perinatol. 2009;36(1):137-52. [pmid: 19161871].
Mozurkewich E, Chilimigras J, Klemens C, et al. The mothers, Omega-3 and mental health study. BMC Pregnancy Childbirth. 2011;11:46. [pmid: 21696635].
Musters C, McDonald E, Jones I. Management of postnatal depression. BMJ. 2008;337:a736. [pmid: 18689433].
Ngai FW, Chan WCS. The effect of a childbirth psychoeducation program on postnatal depression. Asian Journal of Psychiatry. 2011;4(SUPPL 1):S69-S70.
Norwitz ER, Bellanger K, Funai EF, et al. Post-Traumatic stress disorder (PTSD) and panic disorder are independent risk factors for preterm birth, but not low birth weight or small-for-gestational age: The Yale ‘Pink & Blue’ Prospective cohort study. Reproductive Sciences. 2010;17(3):352A.
Nylen KJ, O’Hara MW, Engeldinger J. Perceived social support interacts with prenatal depression to predict birth outcomes. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S40-S41.
Nylen KJ, Segre LS, O’Hara MW. Public health implications of postpartum depression. Psychiatric Annals. 2005;35(7):599-609.
Ochiai H. Early detection of families needing support and actions for parenting: The infant health program of mie medical association. Japan Medical Association Journal. 2011;54(3):175-179.
Oettel M. 2nd Meeting of the Egon & Ann Diczfalusy Foundation “Prevention in Women’s Health” September 30 – October 1, 2008, Szeged, Hungary. Journal fur Reproduktionsmedizin und Endokrinologie. 2010;7(1):45-49.
Ogasawara K, Hudgins J, Sutherland D, et al. Association of serotonin transporter gene polymorphism and postpartum depression. Reproductive Sciences. 2011;18(3):87A.
O’Hara M, Gorman LL. Can Postpartum Depression Be Predicted?. Primary Psychiatry. 2004;11(3):42-47.
O’Hara MW, Nylen K, Schiller C, et al. Maternal psychopathology and stress: Fetal, infant, and toddler outcomes. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S114.
Olsen E. Preventing postpartum depression: AWeb-based intervention. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S77.
Oudi M, Sazvar S, Alizadeh L, et al. Prenatal attachment in pregnancy conceived by assisted reproduction(ART) compared to the natural. Human Reproduction. 2011;26(SUPPL 1):i337-i338.
Pajulo M, Karlsson H, Karlsson L, et al. Baby’s mind in mind: Prenatal parental capacity to mentalise about the baby. Data from the FinnBrain birth cohort study. European Child and Adolescent Psychiatry. 2011;20(SUPPL 1):S41.
Palmer AA. Development of a support program to address the mental health needs of women along the continuum of perinatal care. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S78.
Patino M, Gaskins A, Meyer KB, et al. The influence of grandmothers on postpartum health of mother and infant. American Journal of Physical Anthropology. 2012;147(SUPPL 54):234.
Paulden M, Palmer S, Hewitt C, et al. Screening for postnatal depression in primary care: cost effectiveness analysis. BMJ. 2009;339:b5203. [pmid: 20028779].
Pearlstein T, Howard M, Salisbury A, et al. Postpartum depression. Am J Obstet Gynecol. 2009;200(4):357-64. [pmid: 19318144].
Pereira AT, Bos S, Marques M, et al. Development and validation of the portuguese short version of the postpartum depression screening scale to screen for antenatal depression. European Psychiatry. 2012;27(1):2012-03.
Perfetti J, Clark R, Fillmore CM. Postpartum depression: identification, screening, and treatment. WMJ. 2004;103(6):56-63. [pmid: 15622821].
Piejko E. The postpartum visit--why wait 6 weeks?. Aust Fam Physician. 2006;35(9):674-8. [pmid: 16969434].
Pogany A, Petersen M. What are the best screening instruments for PPD?. JAAPA. 2007;20(7):34-6. 38. [pmid: 17695096].
Pritchard MA, Colditz PB, Cartwright D, et al. Six-week postpartum depression predicts parenting profiles in mothers of preterm children. Journal of Paediatrics and Child Health. 2012;48(SUPPL 1):120.
Quigley J, Howland K, Myer M. Evaluating the edinburgh postnatal depression scale. A case study from Kingston Maternal and Child Health Service in South Melbourne, Victoria, Australia. Aust Nurs J. 2006;13(8):23-6. [pmid: 16544685].
Rabenda-Lacka KM. The prevalence and risk factors of postpartum depression in Poland. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S44.
Rankin J, Martin CR. Does trial participation impact on the psychometric properties of self-report depression in postnatal women?. Value in Health. 2010;13(3):A181-A182.
Redshaw M, Martin C. Changing times and continuing issues. Journal of Reproductive and Infant Psychology. 2009;27(1):1-3.
Redshaw M, Martin CR. Psychometric properties of the Oxford worries about labour scale (OWLS). Value in Health. 2010;13(3):A185.
Ricciardulli S, Banti S, Borri C, et al. Risk factors of depression and anxiety during pregnancy: Maternal antenatal attachment. European Psychiatry. 2012;27(1):2012-03.
Robertson Blackmore E, Moynihan J, Rubinow DR, et al. Trauma but not depression is associated with pro-inflammatory cytokines in pregnancy. Archives of Women’s Mental Health. 2011;14:S45.
Robinson RV, Lampman C. Rates and correlates of postpartum depression in Alaska. Alaska Med. 2009;51:42-3. [pmid: 19998713].
Rubertsson C, Borjesson K, Berglund A, et al. The Swedish validation of edinburgh postnatal depression scale- EPDS during pregnancy. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S46.
Rychnovsky JD, Brady MA. Choosing a postpartum depression screening instrument for your pediatric practice. J Pediatr Health Care. 2008;22(1):64-7. [pmid: 18174093].
Saldanha D, Rathi N. Evaluation of risk factors in postpartum depression. Asian Journal of Psychiatry. 2011;4:S56.
Salisbury AL. Examination of fetal neurobehavior at the time of exposure to maternal depression and antidepressant use. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S47-S48.
Salisbury AL. Influences of maternal mood, SRI treatment, anxiety, and sleep on fetal and infant neurobehavior. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S48.
Salmela-Aro K, Rouhe H, Erja H, et al. Intervention promoting positive motherhood among nulliparous pregnant women with an intense fear of childbirth. European Child and Adolescent Psychiatry. 2011;20(SUPPL 1):S49.
Segre LS, Brock RL, O’Hara MW, et al. Disseminating perinatal depression screening as a public health initiative: S train-the-trainer approach. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S48-S49.
Sharkey KM, Pearlstein TB. Role of circadian rhythm disruption in postpartum depression - A pilot study. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S80-S81.
Shivakumar G, Brandon AR, Johnson NL, et al. Screening to treatment: Obstacles and predictors in perinatal depression (STOP-PPD). Archives of Women’s Mental Health. 2011;14(SUPPL 1):S81.
Silver R, Adams M, Straub H, et al. Antenatal depressive symptoms increase the likelihood of preterm birth. American Journal of Obstetrics and Gynecology. 2012;206(1):S235.
Singer T, Kofinas J, Huang J, et al. Should invitro fertilization treatment be considered arisk factor for post partum depression?. Fertility and Sterility. 2012;97(3 SUPPL 1):S29.
Sit D. Seasonality of depression risk and suicidal symptoms in the postpartum period. Neuropsychopharmacology. 2010;35(SUPPL 1):S378.
Sit DKY, Wisner KL, Seltman H. Seasonal effects on EPDS positivity and suicidal symptoms in women. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S81.
Spinelli MG, Endicott J. Controlled clinical trial of antepartum interpersonal psychotherapy versus parenting education program at 3 NYC sites. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S49.
Srkalovic Imsiragic A, Begic D, Kolumbic Lakos A, et al. Impact of social support and previosly undiagnosed pospartal depression on pospartum complications and postpartum psychiatric disorders development. European Psychiatry. 2012;27(1):2012-03.
Stramrood C, Wessel I, Doornbos B, et al. Long-term psychological effects of preeclampsia and PPROM. Reproductive Sciences. 2010;17(3):204A-205A.
Stramrood CAI, Van Geenen M, Doornbos B, et al. Fathers with PTSD and depression in pregnancies complicated by preeclampsia or PPROM. Pregnancy Hypertension. 2011;1(3–4):293.
Stramrood CAI, Van Geenen M, Doornbos B, et al. PTSD and depression in partners of women with PE or PPROM. Reproductive Sciences. 2010;17(3):205A.
Strawbridge EM, Howard M, Nolan P, et al. Increasing post-partum depression detection in Rhode Island: targeting pediatric providers. Med Health R I. 2008;91(8):255-7. [pmid: 18754266].
Sword W, Bai YQ, Thabane L, et al. Predictors of postpartum depression over the first year following childbirth. Journal of Paediatrics and Child Health. 2012;48(SUPPL 1):62.
Tandon SD, Mendelson T, Perry D, et al. Preventing perinatal depression among low-income home visiting clients. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S51-S52.
Tansy J, Tulic M, D’Vaz N, et al. Prenatal maternal stress and infant allergy: An exploratory study. Internal Medicine Journal. 2011;41(SUPPL 4):20.
Tareen A, Kothari C, Charoth RM, et al. Smoking in perinatal women is associated with intimate partner victimization, housing challenges and history of mental illness. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S52.
Tareen RS, Liepman MR, Charoth RM, et al. Impact of psychiatric care on perinatal mood disorders. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S52-S53.
Teixeira F, Goncnullalves MP, Monteiro A, et al. Incidence and prevalence of depression in women and men, during pregnancy and after childbirth: Comparing the likelihood to be depressed in subsamples of previously severely depressed and without history of depression. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S53.
Trivedi N, LaCoursiere Y, Aguayo J, et al. The impact of depressed mood on glycemic control and pregnancy outcomes in women with diabetes. Reproductive Sciences. 2010;17(3):208A.
Turella E, Donolato A, Ciulli B, et al. Postpartum depression: From a screening project to a regular support program among a maternity population. Psychiatrische Praxis. 2011;38(1):2011-06.
Vilela A. Depressed mothers, depressed children?. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S134-S135.
Wang DX, Ding T, Qu Y, et al. The effects of epidural labor analgesia on the incidence of postpartum depression. European Journal of Anaesthesiology. 2011;28(SUPPL 48):157.
Wang J, Lew AM, Chen H. Identifying mothers’ barriers and facilitators towards help-seeking for postnatal depression in Singapore. Archives of Women’s Mental Health. 2011;14(SUPPL 2):S129.
Wesselhoeft RT, Mors O, Heiervang E, et al. Depressive spectrum disorders in 7–9-year-old children from The Danish National Birth Cohort - A pilot study. European Child and Adolescent Psychiatry. 2011;20(SUPPL 1):S187-S188.
White JS, Wisner KL. Co-location of psychiatric services within a home visiting agency. Archives of Women’s Mental Health. 2011;14(SUPPL 1):S85.
Wisner KL, Moses-Kolko EL, Sit DK. Postpartum depression: a disorder in search of a definition. Arch Womens Ment Health. 2010;13(1):37-40. [pmid: 20127453].
Wroblewski M, Tallon D. Implementing a comprehensive postpartum depression support program. AWHONN Lifelines. 2004;8(3):248-52. [pmid: 15305599].
Yee L, Nakagawa S, Kaimal A, et al. Postpartum sexual functioning and mode of delivery in a diverse population of women. American Journal of Obstetrics and Gynecology. 2012;206(1):S155.
Yoshida K, Fujinaga Y, Yamashita H, et al. Clinical survey of the mother-infant mental health clinic: Psychiatric characteristics of consecutive 109 patients. Neuropsychopharmacology. 2011;36(SUPPL 1):S162-S163.
Youash S, Campbell MK, Avison WR, et al. Pathways for women’s information levels regarding prenatal and postnatal health and postpartum depression. American Journal of Epidemiology. 2011;173(SUPPL 11):S137.

## Not a Randomized Trial, or Not an Observational Study of Appropriate Design With Sample Size >100

Adeyemi A, Mosaku K, Ajenifuja O, et al. Depressive symptoms in a sample of women following perinatal loss. J Natl Med Assoc. 2008;100(12):1463-8. [pmid: 19110916].
Adouard F, Glangeaud-Freudenthal NM, Golse B. Validation of the Edinburgh postnatal depression scale (EPDS) in a sample of women with high-risk pregnancies in France. Arch Womens Ment Health. 2005;8(2):89-95. [pmid: 15883653].
Ahmed A, Stewart DE, Teng L, et al. Experiences of immigrant new mothers with symptoms of depression. Arch Womens Ment Health. 2008;11(4):295-303. [pmid: 18677438].
Areias ME, Kumar R, Barros H, et al. Comparative incidence of depression in women and men, during pregnancy and after childbirth Validation of the Edinburgh Postnatal Depression Scale in Portuguese mothers. Br J Psychiatry. 1996;169(1):30-5. [pmid: 8818365].
Baisch MJ, Carey LK, Conway AE, et al. Perinatal depression: a health marketing campaign to improve screening. Nurs Womens Health. 2010;14(1):20-33. [pmid: 20137040].
Bank AM, Barr R, Calvert SL, et al. Maternal Depression and Family Media Use: A Questionnaire and Diary Analysis. J Child Fam Stud. 2012;21(2):208-216. [pmid: 22745524].
Barrett J, Wonch KE, Gonzalez A, et al. Maternal affect and quality of parenting experiences are related to amygdala response to infant faces. Social Neuroscience. 2012;7(3):252-268.
Beck CT, Indman P. The many faces of postpartum depression. J Obstet Gynecol Neonatal Nurs. 2005;34(5):569-76. [pmid: 16227512].
Beckjord EB, Keyser DJ, Schultz D, et al. Potential benefits of health information technology for integrating physical and behavioral health care: Perinatal depression as a case-in-point. Translational Behavioral Medicine. 2011;1(1):89-92.
Bennett IM, Culhane JF, McCollum KF, et al. Literacy and depressive symptomatology among pregnant Latinas with limited English proficiency. Am J Orthopsychiatry. 2007;77(2):243-8. [pmid: 17535122].
Bielawska-Batorowicz E, Kossakowska-Petrycka K. Depressive mood in men after the birth of their offspring in relation to a partner’s depression, social support, fathers’ personality and prenatal expectations. Journal of Reproductive and Infant Psychology. 2006;24(1):21-29.
Bienfait M, Maury M, Haquet A, et al. Pertinence of the self-report mother-to-infant bonding scale in the neonatal unit of a maternity ward. Early Hum Dev. 2011;87(4):281-7. [pmid: 21316876].
Bilszta J, Ericksen J, Buist A, et al. A qualitative study of health professionals involved in the care and treatment of women with postnatal emotional distress. The International Journal of Mental Health Promotion. 2010;12(3):5-13.
Boyd RC, Zayas LH, McKee MD. Mother-infant interaction, life events and prenatal and postpartum depressive symptoms among urban minority women in primary care. Matern Child Health J. 2006;10(2):139-48. [pmid: 16397831].
Cassidy J, Ziv Y, Stupica B, et al. Enhancing attachment security in the infants of women in a jail-diversion program. Attach Hum Dev. 2010;12(4):333-53. [pmid: 20582844].
Corral M, Wardrop A, Zhang HB. Seasonality of symptoms in women with postpartum depression. Arch Womens Ment Health. 2007;10(1):9-13. [pmid: 17165099].
Corwin EJ, Brownstead J, Barton N, et al. The impact of fatigue on the development of postpartum depression. J Obstet Gynecol Neonatal Nurs. 2005;34(5):577-86. [pmid: 16227513].
Corwin EJ, Johnston N, Pugh L. Symptoms of postpartum depression associated with elevated levels of interleukin-1 beta during the first month postpartum. Biol Res Nurs. 2008;10(2):128-33. [pmid: 18829596].
Craig E, Judd F, Hodgins G. Therapeutic group programme for women with postnatal depression in rural Victoria: a pilot study. Australas Psychiatry. 2005;13(3):291-5. [pmid: 16174204].
Edwards E, Timmons S. A qualitative study of stigma among women suffering postnatal illness. Journal of Mental Health. 2005;14(5):471-481.
Farrow CV, Blissett JM. Is maternal psychopathology related to obesigenic feeding practices at 1 year?. Obes Res. 2005;13(11):1999-2005. [pmid: 16339132].
Fergerson SS, Jamieson DJ, Lindsay M. Diagnosing postpartum depression: can we do better?. Am J Obstet Gynecol. 2002;186(5):899-902. [pmid: 12015507].
Field T, Diego M, Hernandez-Reif M, et al. Prenatal dysthymia versus major depression effects on early mother-infant interactions: a brief report. Infant Behav Dev. 2009;32(1):129-31. [pmid: 19036455].
Field T, Nadel J, Hernandez-Reif M, et al. Depressed mothers’ infants show less negative affect during non-contingent interactions. Infant Behavior and Development. 2005;28(4):426-430.
Garg A, Morton S, Heneghan A. A hospital survey of postpartum depression education at the time of delivery. J Obstet Gynecol Neonatal Nurs. 2005;34(5):587-94. [pmid: 16227514].
Grigoriadis S, de Camps Meschino D, Barrons E, et al. Mood and anxiety disorders in a sample of Canadian perinatal women referred for psychiatric care. Arch Womens Ment Health. 2011;14(4):325-33. [pmid: 21695590].
Hart R, McMahon CA. Mood state and psychological adjustment to pregnancy. Arch Womens Ment Health. 2006;9(6):329-37. [pmid: 16830068].
Heinicke CM, Fineman NR, Ruth G, et al. Relationship-based intervention with at-risk mothers: outcome in the first year of life. Infant Mental Health Journal. 1999;20(4):349-374.
Hornstein C, Trautmann-Villalba P, Hohm E, et al. Maternal bond and mother-child interaction in severe postpartum psychiatric disorders: is there a link?. Arch Womens Ment Health. 2006;9(5):279-84. [pmid: 16937314].
Huot RL, Brennan PA, Stowe ZN, et al. Negative affect in offspring of depressed mothers is predicted by infant cortisol levels at 6 months and maternal depression during pregnancy, but not postpartum. Ann N Y Acad Sci. 2004;1032:234-6. [pmid: 15677418].
Jarjoura D, O’Hara MW. A structural model for postpartum responses to the somatic and cognitive items on the Beck Depression Inventory. Journal of Psychopathology and Behavioral Assessment. 1987;9(4):389-402.
Jolley SN, Elmore S, Barnard KE, et al. Dysregulation of the hypothalamic-pituitary-adrenal axis in postpartum depression. Biol Res Nurs. 2007;8(3):210-22. [pmid: 17172320].
Jomeen J, Martin CR. Reflections on the notion of post-natal depression following examination of the scoring pattern of women on the EPDS during pregnancy and in the post-natal period. J Psychiatr Ment Health Nurs. 2008;15(8):645-8. [pmid: 18803738].
Jones CJ, Creedy DK, Gamble JA. Australian midwives’ awareness and management of antenatal and postpartum depression. Women and Birth. 2012;25(1):23-28. [pmid: 21459691].
Jones GL, Morrell CJ, Cooke JM, et al. The development of two postnatal health instruments: one for mothers (M-PHI) and one for fathers (F-PHI) to measure health during the first year of parenting. Qual Life Res. 2011;20(7):1011-22. [pmid: 21359974].
Judd F, Stafford L, Gibson P, et al. The Early Motherhood Service: an acceptable and accessible perinatal mental health service. Australas Psychiatry. 2011;19(3):240-6. [pmid: 21682623].
Kaplan PA, Burgess AP, Sliter JK, et al. Maternal sensitivity and the learning-promoting effects of depressed and nondepressed mothers’ infant-directed speech. Infancy. 2009;14(2):143-161. [pmid: 20046973].
Kerchner A, Lester W, Stuart SP, et al. Risk of depression and other mental health disorders in women with polycystic ovary syndrome: a longitudinal study. Fertil Steril. 2009;91(1):207-12. [pmid: 18249398].
Kim YK, Hur JW, Kim KH, et al. Prediction of postpartum depression by sociodemographic, obstetric and psychological factors: a prospective study. Psychiatry Clin Neurosci. 2008;62(3):331-40. [pmid: 18588594].
Kuosmanen L, Vuorilehto M, Kumpuniemi S, et al. Post-natal depression screening and treatment in maternity and child health clinics. J Psychiatr Ment Health Nurs. 2010;17(6):554-7. [pmid: 20633083].
Kurzweil S. Relational-developmental therapy group for postnatal depression. Int J Group Psychother. 2008;58(1):17-34. [pmid: 18211212].
Logsdon MC, Myers JA. Comparative performance of two depression screening instruments in adolescent mothers. J Womens Health (Larchmt). 2010;19(6):1123-8. [pmid: 20500127].
Logsdon MC, Foltz MP, Stein B, et al. Adapting and testing telephone-based depression care management intervention for adolescent mothers. Arch Womens Ment Health. 2010;13(4):307-17. [pmid: 20020164].
Logsdon MC, Usui W, Pinto-Foltz M, et al. Intention to seek depression treatment in adolescent mothers and a comparison group of adolescent girls. Arch Psychiatr Nurs. 2009;23(1):41-9. [pmid: 19216987].
Midmer D, Bryanton J, Brown R. Assessing antenatal psychosocial health. Randomized controlled trial of two versions of the ALPHA form. Can Fam Physician. 2004;50:80-7. [pmid: 14761108].
Monk C, Leight KL, Fang Y. The relationship between women’s attachment style and perinatal mood disturbance: implications for screening and treatment. Arch Womens Ment Health. 2008;11(2):117-29. [pmid: 18493708].
Nadel J, Soussignan R, Canet P, et al. Two-month-old infants of depressed mothers show mild, delayed and persistent change in emotional state after non-contingent interaction. Infant Behavior and Development. 2005;28(4):418-425.
Oates MR, Cox JL, Neema S, et al. Postnatal depression across countries and cultures: A qualitative study. British Journal of Psychiatry. 2004;184(SUPPL 46):s10-s16. [pmid: 14754813].
O’Hara MW, Neunaber DJ, Zekoski EM. Prospective study of postpartum depression: prevalence, course, and predictive factors. J Abnorm Psychol. 1984;93(2):158-71. [pmid: 6725749].
Olshansky E, Sereika S. The transition from pregnancy to postpartum in previously infertile women: a focus on depression. Arch Psychiatr Nurs. 2005;19(6):273-80. [pmid: 16308127].
O’Mahony JM, Donnelly TT. The influence of culture on immigrant women’s mental health care experiences from the perspectives of health care providers. Issues Ment Health Nurs. 2007;28(5):453-71. [pmid: 17613147].
O’Toole JK, Burkhardt MC, Solan LG, et al. Resident confidence addressing social history: Is it influenced by availability of social and legal resources?. Clinical Pediatrics. 2012;51(7):625-631. [pmid: 22399566].
Ozbek A, Kumral A, Guvenir T, et al. Maternal psychosocial aspects in hypernatremic dehydration with high sodium concentrations in breast milk: a case-control study. J Paediatr Child Health. 2008;44(1–2):38-43. [pmid: 17854413].
Paulden M, Palmer S, Hewitt C, et al. Screening for postnatal depression in primary care: Cost effectiveness analysis. BMJ. 2010;339:b5203. [pmid: 20028779].
Pedersen CA, Johnson JL, Silva S, et al. Antenatal thyroid correlates of postpartum depression. Psychoneuroendocrinology. 2007;32(3):235-45. [pmid: 17346901].
Poole H, Mason L, Osborn T. Women’s views of being screened for postnatal depression. Community Pract. 2006;79(11):363-7. [pmid: 17100363].
Price SK, Corder-Mabe J, Austin K. Perinatal depression screening and intervention: enhancing health provider involvement. J Womens Health (Larchmt). 2012;21(4):447-55. [pmid: 22309209].
Puckering C, McIntosh E, Hickey A, et al. Mellow Babies: A group intervention for infants and mothers experiencing postnatal depression. Counselling Psychology Review. 2010;25(1):28-38.
Rogers CE, Kidokoro H, Wallendorf M, et al. Identifying mothers of very preterm infants at-risk for postpartum depression and anxiety before discharge. J Perinatol. 2012. Jun. 7. [Epub ahead of print]. [pmid: 22678144].
Ross LE, Villegas L, Dennis C-L, et al. Rural residence and risk for perinatal depression: A Canadian pilot study. Archives of Women’s Mental Health. 2011;14(3):175-185. [pmid: 21311926].
Smart J, Hiscock H. Early infant crying and sleeping problems: a pilot study of impact on parental well-being and parent-endorsed strategies for management. J Paediatr Child Health. 2007;43(4):284-90. [pmid: 17444831].
Sword W, Busser D, Ganann R, et al. Women’s care-seeking experiences after referral for postpartum depression. Qual Health Res. 2008;18(9):1161-73. [pmid: 18689530].
Sword W, Clark AM, Hegadoren K, et al. The complexity of postpartum mental health and illness: a critical realist study. Nurs Inq. 2012;19(1):51-62. [pmid: 22212370].
Sword W, Watt S, Krueger P, et al. The Ontario Mother and Infant Study (TOMIS) III: a multi-site cohort study of the impact of delivery method on health, service use, and costs of care in the first postpartum year. BMC Pregnancy Childbirth. 2009;9:16. [pmid: 19397827].
Thomason E, Stacks AM, McComish JF. Early intervention and perinatal depression: Is there a need for provider training?. Early Child Development and Care. 2010;180(5):671-683.
Thornberry JS, Murray KB, El-Khorazaty MN, et al. Acceptance, Communication Mode and Use of Audio Computer-Assisted Self Interview Using Touchscreen to Identify Risk Factors among Pregnant Minority Women. Methods Rep RTI Press. 2010;15:1001. [pmid: 21637729].
Ugarriza DN. Group therapy and its barriers for women suffering from postpartum depression. Arch Psychiatr Nurs. 2004;18(2):39-48. [pmid: 15106134].
Vliegen N, Luyten P, Biringen Z. A multimethod perspective on emotional availability in the postpartum period. Parenting: Science and Practice. 2009;9(3–4):228-243.
Wilen JM, Mounts KO. Women with depression—”You Can’t Tell by Looking”. Matern Child Health J. 2006;10(5 Suppl):S183-6. [pmid: 16752092].
Wisner KL, Logsdon MC, Shanahan BR. Web-based education for postpartum depression: conceptual development and impact. Arch Womens Ment Health. 2008;11(5–6):377-85. [pmid: 18784975].
Young E. Maternal expectations: do they match experience?. Community Pract. 2008;81(10):27-30. [pmid: 18853885].

## Not a Population of Interest

Aas KK, Tambs K, Kise MS, et al. Genetic testing of newborns for type 1 diabetes susceptibility: a prospective cohort study on effects on maternal mental health. BMC Med Genet. 2010;11:112. [pmid: 20630116].
Ahluwalia IB, Mack KA, Mokdad A. Mental and physical distress and high-risk behaviors among reproductive-age women. Obstet Gynecol. 2004;104(3):477-83. [pmid: 15339756].
Altshuler LL, Cohen LS, Vitonis AF, et al. The Pregnancy Depression Scale (PDS): a screening tool for depression in pregnancy. Arch Womens Ment Health. 2008;11(4):277-85. [pmid: 18581042].
Andersson L, Sundstrom-Poromaa I, Wulff M, et al. Neonatal outcome following maternal antenatal depression and anxiety: a population-based study. Am J Epidemiol. 2004;159(9):872-81. [pmid: 15105180].
Armstrong K, Edwards H. The effects of exercise and social support on mothers reporting depressive symptoms: a pilot randomized controlled trial. Int J Ment Health Nurs. 2003;12(2):130-8. [pmid: 12956024].
Arrindell WA, Barelds DP, Janssen IC, et al. Invariance of SCL-90-R dimensions of symptom distress in patients with peri partum pelvic pain (PPPP) syndrome. Br J Clin Psychol. 2006;45(Pt 3):377-91. [pmid: 17147103].
Asarnow JR, Baraff LJ, Berk M, et al. Pediatric emergency department suicidal patients: two-site evaluation of suicide ideators, single attempters, and repeat attempters. J Am Acad Child Adolesc Psychiatry. 2008;47(8):958-66. [pmid: 18596552].
Austin MP, Hadzi-Pavlovic D, Saint K, et al. Antenatal screening for the prediction of postnatal depression: validation of a psychosocial Pregnancy Risk Questionnaire. Acta Psychiatr Scand. 2005;112(4):310-7. [pmid: 16156839].
Azar R, Paquette D, Zoccolillo M, et al. The association of major depression, conduct disorder, and maternal overcontrol with a failure to show a cortisol buffered response in 4-month-old infants of teenage mothers. Biol Psychiatry. 2007;62(6):573-9. [pmid: 17336943].
Bagner DM, Pettit JW, Lewinsohn PM, et al. Effect of maternal depression on child behavior: a sensitive period?. J Am Acad Child Adolesc Psychiatry. 2010;49(7):699-707. [pmid: 20610139].
Baird J, Hill CM, Kendrick T, et al. Infant sleep disturbance is associated with preconceptional psychological distress: findings from the Southampton Women’s Survey. Sleep. 2009;32(4):566-8. [pmid: 19413152].
Barker ED, Jaffee SR, Uher R, et al. The contribution of prenatal and postnatal maternal anxiety and depression to child maladjustment. Depress Anxiety. 2011;28(8):696-702. [pmid: 21769997].
Bergner A, Beyer R, Klapp BF, et al. Pregnancy after early pregnancy loss: a prospective study of anxiety, depressive symptomatology and coping. J Psychosom Obstet Gynaecol. 2008;29(2):105-13. [pmid: 17943588].
Bernstein IH, Rush AJ, Yonkers K, et al. Symptom features of postpartum depression: are they distinct?. Depress Anxiety. 2008;25(1):20-6. [pmid: 17187349].
Boury JM, Larkin KT, Krummel DA. Factors related to postpartum depressive symptoms in low-income women. Women Health. 2004;39(3):19-34. [pmid: 15256353].
Buist A, Bilszta J, Milgrom J, et al. Health professional’s knowledge and awareness of perinatal depression: results of a national survey. Women Birth. 2006;19(1):11-6. [pmid: 16791999].
Cacciatore J, Radestad I, Frederik Froen J. Effects of contact with stillborn babies on maternal anxiety and depression. Birth. 2008;35(4):313-20. [pmid: 19036044].
Carroll JC, Reid AJ, Biringer A, et al. Effectiveness of the Antenatal Psychosocial Health Assessment (ALPHA) form in detecting psychosocial concerns: a randomized controlled trial. CMAJ. 2005;173(3):253-9. [pmid: 16076821].
Carter FA, Carter JD, Luty SE, et al. Screening and treatment for depression during pregnancy: a cautionary note. Aust N Z J Psychiatry. 2005;39(4):255-61. [pmid: 15777362].
Chadha-Hooks PL, Hui Park J, Hilty DM, et al. Postpartum depression: an original survey of screening practices within a healthcare system. J Psychosom Obstet Gynaecol. 2010;31(3):199-205. [pmid: 20482291].
Chen YH, Lau G. Maternal deaths from suicide in Singapore. Singapore Med J. 2008;49(9):694-7. [pmid: 18830543].
Chisholm D, Conroy S, Glangeaud-Freudenthal N, et al. Health services research into postnatal depression: results from a preliminary cross-cultural study. Br J Psychiatry Suppl. 2004;46:s45-52. [pmid: 14754818].
Chojenta C, Loxton D, Lucke J. How Do Previous Mental Health, Social Support, and Stressful Life Events Contribute to Postnatal Depression in a Representative Sample of Australian Women?. Journal of Midwifery and Women’s Health. 2012;57(2):145-150.
Coleman VH, Carter MM, Morgan MA, et al. United States obstetrician-gynecologists’ accuracy in the simulation of diagnosing anxiety disorders and depression during pregnancy. J Psychosom Obstet Gynaecol. 2008;29(3):173-84. [pmid: 18608826].
Connelly CD, Baker MJ, Hazen AL, et al. Pediatric health care providers’ self-reported practices in recognizing and treating maternal depression. Pediatr Nurs. 2007;33(2):165-72. 127. [pmid: 17542239].
Conroy S, Marks MN, Schacht R, et al. The impact of maternal depression and personality disorder on early infant care. Soc Psychiatry Psychiatr Epidemiol. 2010;45(3):285-92. [pmid: 19466372].
Cooper PJ, Murray L, Wilson A, et al. Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression. I. Impact on maternal mood. Br J Psychiatry. 2003;182:412-9. [pmid: 12724244].
Cox JL, Chapman G, Murray D, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. 1996;39(3):185-9. [pmid: 8856422].
Cumming GP, Klein S, Bolsover D, et al. The emotional burden of miscarriage for women and their partners: trajectories of anxiety and depression over 13 months. BJOG. 2007;114(9):1138-45. [pmid: 17655731].
de Cock ESA, Emons WHM, Nefs G, et al. Dimensionality and scale properties of the Edinburgh Depression Scale (EDS) in patients with type 2 diabetes mellitus: The DiaDDzoB study. BMC Psychiatry. 2011;11:141. [pmid: 21864349].
Deave T, Heron J, Evans J, et al. The impact of maternal depression in pregnancy on early child development. BJOG. 2008;115(8):1043-51. [pmid: 18651886].
Deave T. Associations between child development and women’s attitudes to pregnancy and motherhood. Journal of Reproductive and Infant Psychology. 2005;23(1):63-75.
Delatte R, Cao H, Meltzer-Brody S, et al. Universal screening for postpartum depression: an inquiry into provider attitudes and practice. Am J Obstet Gynecol. 2009;200(5):e63-4. [pmid: 19285644].
Dennis CL, Hodnett E, Kenton L, et al. Effect of peer support on prevention of postnatal depression among high risk women: multisite randomised controlled trial. BMJ. 2009;338:a3064. [pmid: 19147637].
Dennis CL. Peer support for postpartum depression: volunteers’ perceptions, recruitment strategies and training from a randomized controlled trial. Health Promot Int. 2012. Mar. 1. [Epub ahead of print]. [pmid: 22388589].
di Scalea TL, Hanusa BH, Wisner KL. Sexual function in postpartum women treated for depression: Results from a randomized trial of nortriptyline versus sertraline. Journal of Clinical Psychiatry. 2009;70(3):423-428. [pmid: 19284932].
Dietz LJ, Jennings KD, Kelley SA, et al. Maternal depression, paternal psychopathology, and toddlers’ behavior problems. J Clin Child Adolesc Psychol. 2009;38(1):48-61. [pmid: 19130357].
Dritsa M, Da Costa D, Dupuis G, et al. Effects of a home-based exercise intervention on fatigue in postpartum depressed women: results of a randomized controlled trial. Ann Behav Med. 2008;35(2):179-87. [pmid: 18373127].
Dritsa M, Dupuis G, Lowensteyn I, et al. Effects of home-based exercise on fatigue in postpartum depressed women: who is more likely to benefit and why?. J Psychosom Res. 2009;67(2):159-63. [pmid: 19616143].
El Marroun H, Jaddoe VWV, Hudziak JJ, et al. Maternal use of selective serotonin reuptake inhibitors, fetal growth, and risk of adverse birth outcomes. Archives of General Psychiatry. 2012;69(7):706-714. [pmid: 22393202].
Ely GE, Flaherty C, Cuddeback GS. The relationship between depression and other psychosocial problems in a sample of adolescent pregnancy termination patients. Child &. Adolescent Social Work Journal. 2010;27(4):269-282. [pmid: 19852400].
Fairlie TG, Gillman MW, Rich-Edwards J. High pregnancy-related anxiety and prenatal depressive symptoms as predictors of intention to breastfeed and breastfeeding initiation. J Womens Health (Larchmt). 2009;18(7):945-53. [pmid: 19563244].
Field T, Diego M, Hernandez-Reif M. Prenatal dysthymia versus major depression effects on the neonate. Infant Behav Dev. 2008;31(2):190-3. [pmid: 18037494].
Field T, Diego M, Dieter J, et al. Prenatal depression effects on the fetus and the newborn. Infant Behavior & Development. 2004;27(2):216-229.
Field T, Diego M, Hernandez-Reif M, et al. Prenatal dopamine and neonatal behavior and biochemistry. Infant Behav Dev. 2008;31(4):590-3. [pmid: 18774177].
Field T, Diego M, Hernandez-Reif M, et al. Yoga and massage therapy reduce prenatal depression and prematurity. Journal of Bodywork and Movement Therapies. 2011;16(2):204-9. [pmid: 22464118].
Field T, Hernandez-Reif M, Diego M, et al. Prenatal cortisol, prematurity and low birthweight. Infant Behav Dev. 2006;29(2):268-75. [pmid: 17138282].
Field T, Yando R, Bendell D, et al. Prenatal depression effects on pregnancy feelings and substance use. Journal of Child & Adolescent Substance Abuse. 2007;17(1):111-125.
Flynn HA, Sexton M, Ratliff S, et al. Comparative performance of the Edinburgh Postnatal Depression Scale and the Patient Health Questionnaire-9 in pregnant and postpartum women seeking psychiatric services. Psychiatry Res. 2011;187(1–2):130-4. [pmid: 21122923].
Fountoulakis KN, Iacovides A, Karamouzis M, et al. Season of birth, clinical manifestations and Dexamethasone Suppression Test in unipolar major depression. Annals of General Psychiatry. 2007;6:20. [pmid: 17683542].
Freeman MP, Davis M, Sinha P, et al. Omega-3 fatty acids and supportive psychotherapy for perinatal depression: a randomized placebo-controlled study. J Affect Disord. 2008;110(1–2):142-8. [pmid: 18206247].
Gerardin P, Wendland J, Bodeau N, et al. Depression during pregnancy: is the developmental impact earlier in boys? A prospective case-control study. J Clin Psychiatry. 2011;72(3):378-87. [pmid: 21208585].
Ghidini A, Healey A, Andreani M, et al. Pregnancy and women with spinal cord injuries. Acta Obstet Gynecol Scand. 2008;87(10):1006-10. [pmid: 18763171].
Goedhart G, Snijders AC, Hesselink AE, et al. Maternal depressive symptoms in relation to perinatal mortality and morbidity: results from a large multiethnic cohort study. Psychosom Med. 2010;72(8):769-76. [pmid: 20668282].
Goldsmith ME. Postpartum depression screening by family nurse practitioners. J Am Acad Nurse Pract. 2007;19(6):321-7. [pmid: 17535342].
Goodman SH, Broth MR, Hall CM, et al. Treatment of postpartum depression in mothers: Secondary benefits to the infants. Infant Mental Health Journal. 2008;29(5):492-513.
Grote NK, Swartz HA, Geibel SL, et al. A randomized controlled trial of culturally relevant, brief interpersonal psychotherapy for perinatal depression. Psychiatr Serv. 2009;60(3):313-21. [pmid: 19252043].
Harvey ST, Pun PK. Analysis of positive Edinburgh depression scale referrals to a consultation liaison psychiatry service in a two-year period. Int J Ment Health Nurs. 2007;16(3):161-7. [pmid: 17535161].
Hatton DC, Harrison-Hohner J, Matarazzo J, et al. Missed antenatal depression among high risk women: a secondary analysis. Arch Womens Ment Health. 2007;10(3):121-3. [pmid: 17431740].
Howard LM, Goss C, Leese M, et al. The psychosocial outcome of pregnancy in women with psychotic disorders. Schizophr Res. 2004;71(1):49-60. [pmid: 15374572].
Huang H, Chan YF, Katon W, et al. Variations in depression care and outcomes among high-risk mothers from different racial/ethnic groups. Fam Pract. 2011;29(4):394-400. [pmid: 22090192].
Huhtala M, Korja R, Lehtonen L, et al. Parental psychological well-being and cognitive development of very low birth weight infants at 2 years. Acta Paediatrica. 2011;100(12):1555-1560. [pmid: 21787372].
Hutti MH, Armstrong DS, Myers J. Healthcare utilization in the pregnancy following a perinatal loss. MCN Am J Matern Child Nurs. 2011;36(2):104-11. [pmid: 21350373].
Ickovics JR, Reed E, Magriples U, et al. Effects of group prenatal care on psychosocial risk in pregnancy: results from a randomised controlled trial. Psychol Health. 2011;26(2):235-50. [pmid: 21318932].
Jablensky AV, Morgan V, Zubrick SR, et al. Pregnancy, delivery, and neonatal complications in a population cohort of women with schizophrenia and major affective disorders. Am J Psychiatry. 2005;162(1):79-91. [pmid: 15625205].
Johnston BD, Huebner CE, Anderson ML, et al. Healthy steps in an integrated delivery system: child and parent outcomes at 30 months. Arch Pediatr Adolesc Med. 2006;160(8):793-800. [pmid: 16894077].
Jomeen J, Martin CR. Replicability and stability of the multidimensional model of the Edinburgh Postnatal Depression Scale in late pregnancy. J Psychiatr Ment Health Nurs. 2007;14(3):319-24. [pmid: 17430456].
Jonsson U, Bohman H, Hjern A, et al. Intimate relationships and childbearing after adolescent depression: A population-based 15 year follow-up study. Social Psychiatry and Psychiatric Epidemiology. 2011;46(8):711-721. [pmid: 20512560].
Josefsson A, Sydsjo G. A follow-up study of postpartum depressed women: recurrent maternal depressive symptoms and child behavior after four years. Arch Womens Ment Health. 2007;10(4):141-5. [pmid: 17533557].
Kaasen A, Helbig A, Malt UF, et al. The relation of psychological distress to salivary and serum cortisol levels in pregnant women shortly after the diagnosis of a structural fetal anomaly. Acta Obstet Gynecol Scand. 2012;91(1):68-78. [pmid: 21880030].
Kabir K, Sheeder J, Stevens-Simon C. Depression, weight gain, and low birth weight adolescent delivery: do somatic symptoms strengthen or weaken the relationship?. J Pediatr Adolesc Gynecol. 2008;21(6):335-42. [pmid: 19064227].
Kennard BD, Hughes JL, Stewart SM, et al. Maternal depressive symptoms in pediatric major depressive disorder: Relationship to acute treatment outcome. Journal of the American Academy of Child &. Adolescent Psychiatry. 2008;47(6):694-699. [pmid: 18434919].
Kersten-Alvarez LE, Hosman CMH, Riksen-Walraven JM, et al. Early school outcomes for children of postpartum depressed mothers: Comparison with a community sample. Child Psychiatry and Human Development. 2012;43(2):201-218. [pmid: 22011810].
Kitamura T, Shima S, Sugawara M, et al. Psychological and social correlates of the onset of affective disorders among pregnant women. Psychol Med. 1993;23(4):967-75. [pmid: 8134520].
Kopelman RC, Moel J, Mertens C, et al. Barriers to care for antenatal depression. Psychiatr Serv. 2008;59(4):429-32. [pmid: 18378843].
Lancaster CA, Flynn HA, Johnson TR, et al. Peripartum length of stay for women with depressive symptoms during pregnancy. J Womens Health (Larchmt). 2010;19(1):31-7. [pmid: 20088656].
Lara MA, Le HN, Letechipia G, et al. Prenatal depression in Latinas in the U.S and Mexico. Matern Child Health J. 2009;13(4):567-76. [pmid: 18581222].
Lau Y, Chan KS. Perinatal depressive symptoms, sociodemographic correlates, and breast-feeding among Chinese women. J Perinat Neonatal Nurs. 2009;23(4):335-45. [pmid: 19915417].
Lefevre F, Moreau D, Semon E, et al. Maternal depression related to infant’s wheezing. Pediatr Allergy Immunol. 2011;22(6):608-13. [pmid: 21781174].
Letourneau N, Stewart M, Dennis CL, et al. Effect of home-based peer support on maternal–infant interactions among women with postpartum depression: A randomized, controlled trial. International Journal of Mental Health Nursing. 2011;20(5):345-357. [pmid: 21385294].
Lev-Wiesel R, Daphna-Tekoah S. The role of peripartum dissociation as a predictor of posttraumatic stress symptoms following childbirth in Israeli Jewish women. J Trauma Dissociation. 2010;11(3):266-83. [pmid: 20603762].
Lev-Wiesel R, Chen R, Daphna-Tekoah S, et al. Past traumatic events: are they a risk factor for high-risk pregnancy, delivery complications, and postpartum posttraumatic symptoms?. J Womens Health (Larchmt). 2009;18(1):119-25. [pmid: 19132883].
Li D, Liu L, Odouli R. Presence of depressive symptoms during early pregnancy and the risk of preterm delivery: a prospective cohort study. Hum Reprod. 2009;24(1):146-53. [pmid: 18948314].
Mahon PB, Payne JL, MacKinnon DF, et al. Genome-wide linkage and follow-up association study of postpartum mood symptoms. Am J Psychiatry. 2009;166(11):1229-37. [pmid: 19755578].
Mallen C, Mottram S, Thomas E. Birth factors and common mental health problems in young adults: a population-based study in North Staffordshire. Soc Psychiatry Psychiatr Epidemiol. 2008;43(4):325-30. [pmid: 18196185].
Manber R, Schnyer RN, Allen JJ, et al. Acupuncture: a promising treatment for depression during pregnancy. J Affect Disord. 2004;83(1):89-95. [pmid: 15546651].
Marchesi C, Bertoni S, Cantoni A, et al. Is alexithymia a personality trait increasing the risk of depression? A prospective study evaluating alexithymia before, during and after a depressive episode. Psychol Med. 2008;38(12):1717-22. [pmid: 18366825].
Marcus SM, Flynn HA, Blow F, et al. A screening study of antidepressant treatment rates and mood symptoms in pregnancy. Arch Womens Ment Health. 2005;8(1):25-7. [pmid: 15868387].
Martin-Merino E, Ruigomez A, Johansson S, et al. Study of a cohort of patients newly diagnosed with depression in general practice: prevalence, incidence, comorbidity, and treatment patterns. Prim Care Companion J Clin Psychiatry. 2010;12(1). PCC 08m00764. [pmid: 20582294].
Massoudi P, Wickberg B, Hwang P. Screening for postnatal depression in Swedish child health care. Acta Paediatr. 2007;96(6):897-901. [pmid: 17537020].
McCarthy FP, Khashan AS, North RA, et al. A prospective cohort study investigating associations between hyperemesis gravidarum and cognitive, behavioural and emotional well-being in pregnancy. PLoS One. 2011;6(11):e27678. [pmid: 22125621].
McFarland J, Salisbury AL, Battle CL, et al. Major depressive disorder during pregnancy and emotional attachment to the fetus. Arch Womens Ment Health. 2011;14(5):425-34. [pmid: 21938509].
Meltzer-Brody S, Zerwas S, Leserman J, et al. Eating disorders and trauma history in women with perinatal depression. J Womens Health (Larchmt). 2011;20(6):863-70. [pmid: 21671774].
Melville JL, Gavin A, Guo Y, et al. Depressive disorders during pregnancy: prevalence and risk factors in a large urban sample. Obstet Gynecol. 2010;116(5):1064-70. [pmid: 20966690].
Milgrom J, Ericksen J, McCarthy R, et al. Stressful impact of depression on early mother-infant relations. Stress and Health. 2006;22(4):229-238.
Miranda J, Siddique J, Der-Martirosian C, et al. Depression among Latina immigrant mothers separated from their children. Psychiatr Serv. 2005;56(6):717-20. [pmid: 15939949].
Misri S, Kostaras X, Fox D, et al. The impact of partner support in the treatment of postpartum depression. Can J Psychiatry. 2000;45(6):554-8. [pmid: 10986574].
Misri S, Reebye P, Corral M, et al. The use of paroxetine and cognitive-behavioral therapy in postpartum depression and anxiety: a randomized controlled trial. J Clin Psychiatry. 2004;65(9):1236-41. [pmid: 15367052].
Miszkurka M, Goulet L, Zunzunegui MV. Antenatal depressive symptoms among Canadian-born and immigrant women in Quebec: differential exposure and vulnerability to contextual risk factors. Soc Psychiatry Psychiatr Epidemiol. 2012;47(10):1639-48. [pmid: 22237717].
Molina KM, Kiely M. Understanding depressive symptoms among high-risk, pregnant, African-American women. Womens Health Issues. 2011;21(4):293-303. [pmid: 21565525].
Mori A. Supporting stress management for women undergoing the early stages of fertility treatment: a cluster-randomized controlled trial. Jpn J Nurs Sci. 2009;6(1):37-49. [pmid: 19566638].
Mott SL, Schiller CE, Richards JG, et al. Depression and anxiety among postpartum and adoptive mothers. Arch Womens Ment Health. 2011;14(4):335-43. [pmid: 21725836].
Mowbray CT, Bybee D, Oyserman D, et al. Timing of mental illness onset and motherhood. J Nerv Ment Dis. 2005;193(6):369-78. [pmid: 15920377].
Mulcahy R, Reay RE, Wilkinson RB, et al. A randomised control trial for the effectiveness of group Interpersonal Psychotherapy for postnatal depression. Arch Womens Ment Health. 2010;13(2):125-39. [pmid: 19697094].
Munk-Olsen T, Laursen TM, Meltzer-Brody S, et al. Psychiatric disorders with postpartum onset: Possible early manifestations of bipolar affective disorders. Archives of General Psychiatry. 2012;69(4):428-434. [pmid: 22147807].
Nagle C, Gunn J, Bell R, et al. Use of a decision aid for prenatal testing of fetal abnormalities to improve women’s informed decision making: a cluster randomised controlled trial. [ISRCTN22532458]. BJOG. 2008;115(3):339-47. [pmid: 18190370].
Neggers Y, Goldenberg R, Cliver S, et al. The relationship between psychosocial profile, health practices, and pregnancy outcomes. Acta Obstet Gynecol Scand. 2006;85(3):277-85. [pmid: 16553174].
Neugebauer R, Kline J, Markowitz JC, et al. Pilot randomized controlled trial of interpersonal counseling for subsyndromal depression following miscarriage. J Clin Psychiatry. 2006;67(8):1299-304. [pmid: 16965211].
Nikcevic AV, Kuczmierczyk AR, Nicolaides KH. The influence of medical and psychological interventions on women’s distress after miscarriage. J Psychosom Res. 2007;63(3):283-90. [pmid: 17719366].
Nishimura A, Ohashi K. Risk factors of paternal depression in the early postnatal period in Japan. Nurs Health Sci. 2010;12(2):170-6. [pmid: 20602688].
O’Brien LM, Heycock EG, Hanna M, et al. Postnatal depression and faltering growth: a community study. Pediatrics. 2004;113(5):1242-7. [pmid: 15121936].
O’Higgins M, St James Roberts I, Glover V. Postnatal depression and mother and infant outcomes after infant massage. J Affect Disord. 2008;109(1–2):189-92. [pmid: 18086500].
Olson AL, Dietrich AJ, Prazar G, et al. Brief maternal depression screening at well-child visits. Pediatrics. 2006;118(1):207-16. [pmid: 16818567].
Olson AL, Dietrich AJ, Prazar G, et al. Two approaches to maternal depression screening during well child visits. J Dev Behav Pediatr. 2005;26(3):169-76. [pmid: 15956865].
O’Mahen HA, Flynn HA. Preferences and perceived barriers to treatment for depression during the perinatal period. J Womens Health (Larchmt). 2008;17(8):1301-9. [pmid: 18816202].
Parker T, Maviglia MA, Lewis PT, et al. Psychological distress among Plains Indian mothers with children referred to screening for Fetal Alcohol Spectrum Disorders. Subst Abuse Treat Prev Policy. 2010;5:22. [pmid: 20819208].
Pascoe JM, Lee M, Specht SL, et al. Mothers with positive or negative depression screens evaluate a maternal resource guide. J Pediatr Health Care. 2010;24(6):378-84. [pmid: 20971413].
Pearson RM, Lightman SL, Evans J. Symptoms of depression during pregnancy are associated with increased systolic blood pressure responses towards infant distress. Archives of Women’s Mental Health. 2012;15(2):95-105. [pmid: 22382283].
Pedersen W. Abortion and depression: a population-based longitudinal study of young women. Scand J Public Health. 2008;36(4):424-8. [pmid: 18539697].
Pemberton CK, Neiderhiser JM, Leve LD, et al. Influence of parental depressive symptoms on adopted toddler behaviors: an emerging developmental cascade of genetic and environmental effects. Dev Psychopathol. 2010;22(4):803-18. [pmid: 20883583].
Pereira AT, Bos SC, Marques M, et al. The postpartum depression screening scale: is it valid to screen for antenatal depression?. Arch Womens Ment Health. 2011;14(3):227-38. [pmid: 20645114].
Petersen RW, Ung K, Holland C, et al. The impact of molar pregnancy on psychological symptomatology, sexual function, and quality of life. Gynecol Oncol. 2005;97(2):535-42. [pmid: 15863157].
Phillips NK, Hammen CL, Brennan PA, et al. Early adversity and the prospective prediction of depressive and anxiety disorders in adolescents. J Abnorm Child Psychol. 2005;33(1):13-24. [pmid: 15759588].
Pippins JR, Brawarsky P, Jackson RA, et al. Association of breastfeeding with maternal depressive symptoms. J Womens Health (Larchmt). 2006;15(6):754-62. [pmid: 16910907].
Pop VJ, Pommer AM, Pop-Purceleanu M, et al. Development of the Tilburg Pregnancy Distress Scale: the TPDS. BMC Pregnancy Childbirth. 2011;11:80. [pmid: 22029691].
Poursharif B, Korst LM, Fejzo MS, et al. The psychosocial burden of hyperemesis gravidarum. J Perinatol. 2008;28(3):176-81. [pmid: 18059463].
Price SK, Proctor EK. A rural perspective on perinatal depression: prevalence, correlates, and implications for help-seeking among low-income women. J Rural Health. 2009;25(2):158-66. [pmid: 19785581].
Priest SR, Austin MP, Barnett BB, et al. A psychosocial risk assessment model (PRAM) for use with pregnant and postpartum women in primary care settings. Arch Womens Ment Health. 2008;11(5–6):307-17. [pmid: 18726142].
Prusakowski MK, Shofer FS, Rhodes KV, et al. Effect of depression and psychosocial stressors on cessation self-efficacy in mothers who smoke. Matern Child Health J. 2011;15(5):620-6. [pmid: 20607376].
Quinlivan JA, Condon J. Anxiety and depression in fathers in teenage pregnancy. Aust N Z J Psychiatry. 2005;39(10):915-20. [pmid: 16168019].
Quinlivan JA, Tan LH, Steele A, et al. Impact of demographic factors, early family relationships and depressive symptomatology in teenage pregnancy. Aust N Z J Psychiatry. 2004;38(4):197-203. [pmid: 15038797].
Radestad I, Surkan PJ, Steineck G, et al. Long-term outcomes for mothers who have or have not held their stillborn baby. Midwifery. 2009;25(4):422-9. [pmid: 18069101].
Ramchandani P, Stein A, Evans J, et al. Paternal depression in the postnatal period and child development: a prospective population study. Lancet. 2005;365(9478):2201-5. [pmid: 15978928].
Ramchandani PG, O’Connor TG, Evans J, et al. The effects of pre- and postnatal depression in fathers: a natural experiment comparing the effects of exposure to depression on offspring. J Child Psychol Psychiatry. 2008;49(10):1069-78. [pmid: 19017023].
Ramchandani PG, Stein A, O’Connor TG, et al. Depression in men in the postnatal period and later child psychopathology: a population cohort study. J Am Acad Child Adolesc Psychiatry. 2008;47(4):390-8. [pmid: 18388761].
Roca de Bes M, Gutierrez Maldonado J, Gris Martinez JM. Psychosocial risks associated with multiple births resulting from assisted reproduction: a Spanish sample. Fertil Steril. 2009;92(3):1059-66. [pmid: 18973888].
Roman LA, Meghea CI, Raffo JE, et al. Who participates in state sponsored Medicaid enhanced prenatal services?. Matern Child Health J. 2010;14(1):110-20. [pmid: 19085092].
Salisbury AL, Wisner KL, Pearlstein T, et al. Newborn neurobehavioral patterns are differentially related to prenatal maternal major depressive disorder and serotonin reuptake inhibitor treatment. Depression and Anxiety. 2011;28(11):1008-1019. [pmid: 21898709].
Sevil U, Ozkan S. Fathers’ functional status during pregnancy and the early postnatal period. Midwifery. 2009;25(6):665-72. [pmid: 18321620].
Shah SM, Bowen A, Afridi I, et al. Prevalence of antenatal depression: comparison between Pakistani and Canadian women. J Pak Med Assoc. 2011;61(3):242-6. [pmid: 21465937].
Sharp DJ, Chew-Graham C, Tylee A, et al. A pragmatic randomised controlled trial to compare antidepressants with a community-based psychosocial intervention for the treatment of women with postnatal depression: the RESPOND trial. Health Technol Assess. 2010;14(43):iii-iv. ix. xi. 1. 153. [pmid: 20860888].
Simmons LA, Huddleston-Casas C, Berry AA. Low-income rural women and depression: factors associated with self-reporting. Am J Health Behav. 2007;31(6):657-66. [pmid: 17691878].
Siu BWM, Chow HM, Kwok SS, et al. Pathway to care for postnatal depression after implementation of the Comprehensive Child Development Service in a regional hospital in Hong Kong. Asia-Pacific Psychiatry. 2011;3(2):54-60.
Skouteris H, Wertheim EH, Germano C, et al. Assessing sleep during pregnancy: a study across two time points examining the Pittsburgh Sleep Quality Index and associations with depressive symptoms. Womens Health Issues. 2009;19(1):45-51. [pmid: 19111787].
Sleath BL, Thomas N, Jackson E, et al. Physician reported communication about depression and psychosocial issues during postpartum visits. N C Med J. 2007;68(3):151-5. [pmid: 17674685].
Smith T, Kipnis G. Implementing a perinatal mood and anxiety disorders program. MCN Am J Matern Child Nurs. 2012;37(2):80-5. quiz 86-7. [pmid: 22270180].
Stafford L, McNally OM, Gibson P, et al. Long-term psychological morbidity, sexual functioning, and relationship outcomes in women with gestational trophoblastic disease. Int J Gynecol Cancer. 2011;21(7):1256-63. [pmid: 21811174].
Steinberg JR, Becker D, Henderson JT. Does the outcome of a first pregnancy predict depression, suicidal ideation, or lower self-esteem? Data from the National Comorbidity Survey. American Journal of Orthopsychiatry. 2011;81(2):193-201. [pmid: 21486261].
Strass P, Billay E. A public health nursing initiative to promote antenatal health. Can Nurse. 2008;104(2):29-33. [pmid: 18320897].
Sussex B, Corcoran K. The Impact of Domestic Violence on Depression in Teen Mothers: Is the Fear or Threat of Violence Sufficient?. Brief Treatment and Crisis Intervention. 2005;5(1):109-120.
Swanson KM, Chen HT, Graham JC, et al. Resolution of depression and grief during the first year after miscarriage: a randomized controlled clinical trial of couples-focused interventions. J Womens Health (Larchmt). 2009;18(8):1245-57. [pmid: 19630553].
Swanson LM, Pickett SM, Flynn H, et al. Relationships among depression, anxiety, and insomnia symptoms in perinatal women seeking mental health treatment. J Womens Health (Larchmt). 2011;20(4):553-8. [pmid: 21417746].
Tan S, Courtney LP, El-Mohandes AAE, et al. Relationships between self-reported smoking, household environmental tobacco smoke exposure and depressive symptoms in a pregnant minority population. Maternal and Child Health Journal. 2011;15(Suppl 1):S65-S74. [pmid: 21928117].
Tu MT, Grunau RE, Petrie-Thomas J, et al. Maternal stress and behavior modulate relationships between neonatal stress, attention, and basal cortisol at 8 months in preterm infants. Dev Psychobiol. 2007;49(2):150-64. [pmid: 17299787].
Tu MT, Perreault G, Seguin L, et al. Child asthma and change in elevated depressive symptoms among mothers of children of a birth cohort from Quebec. Women Health. 2011;51(5):461-81. [pmid: 21797679].
van Dijk AE, van Eijsden M, Stronks K, et al. Prenatal stress and balance of the child’s cardiac autonomic nervous system at age 5–6 years. PLoS ONE. 2012;7(1):e30413. [pmid: 22272345].
Verbeek T, Bockting CLH, Van Pampus MG, et al. Postpartum depression predicts offspring mental health problems in adolescence independently of parental lifetime psychopathology. Journal of Affective Disorders. 2012;136(3):948-954. [pmid: 21930302].
Viguera AC, Tondo L, Koukopoulos AE, et al. Episdes of mood disorders in 2,252 pregnancies and postpartum periods. American Journal of Psychiatry. 2011;168(11):1179-1185. [pmid: 21799064].
Volgsten H, Ekselius L, Poromaa IS, et al. Personality traits associated with depressive and anxiety disorders in infertile women and men undergoing in vitro fertilization treatment. Acta Obstet Gynecol Scand. 2010;89(1):27-34. [pmid: 19947903].
Warmelink JC, Stramrood CA, Paarlberg KM, et al. Posttraumatic stress disorder, anxiety and depression following pregnancies conceived through fertility treatments: the effects of medically assisted conception on postpartum well-being. J Reprod Med. 2012;57(3–4):115-22. [pmid: 22523870].
Weidner K, Bittner A, Junge-Hoffmeister J, et al. A psychosomatic intervention in pregnant in-patient women with prenatal somatic risks. J Psychosom Obstet Gynaecol. 2010;31(3):188-98. [pmid: 20586556].
Weidner K, Siedentopf F, Zimmermann K, et al. Which gynecological and obstetric patients want to attend psychosomatic services?. J Psychosom Obstet Gynaecol. 2008;29(4):280-9. [pmid: 19065397].
Westdahl C, Milan S, Magriples U, et al. Social support and social conflict as predictors of prenatal depression. Obstet Gynecol. 2007;110(1):134-40. [pmid: 17601908].
Woods SM, Melville JL, Guo Y, et al. Psychosocial stress during pregnancy. Am J Obstet Gynecol. 2010;202(1):61 e1-7. [pmid: 19766975].
Yiu MGC, Szeto WL, Wong GPK, et al. Symptoms of anxiety and depression in the perinatal period: Referrals to the comprehensive child development service in a Hong Kong Regional Hospital. Hong Kong Journal of Psychiatry. 2009;19(3):112-116.
Yonkers KA, Smith MV, Gotman N, et al. Typical somatic symptoms of pregnancy and their impact on a diagnosis of major depressive disorder. Gen Hosp Psychiatry. 2009;31(4):327-33. [pmid: 19555792].
Zajicek-Farber ML. The contributions of parenting and postnatal depression on emergent language of children in low-income families. Journal of Child and Family Studies. 2010;19(3):257-269.

## Study Locations Did Not Include at Least One High-Income Economy

Abbaszadeh A, Kermani FP, Safizadeh H, et al. Violence during pregnancy and postpartum depression. Pakistan Journal of Medical Sciences. 2011;27(1):177-181.
Acele EO, Karacam Z. Sexual problems in women during the first postpartum year and related conditions. J Clin Nurs. 2011. Epub Oct 19. [pmid: 22008061].
Akman C, Uguz F, Kaya N. Postpartum-onset major depression is associated with personality disorders. Compr Psychiatry. 2007;48(4):343-7. [pmid: 17560955].
Ali NS, Azam IS, Ali BS, et al. Frequency and associated factors for anxiety and depression in pregnant women: a hospital-based cross-sectional study. Scientific World Journal. Epub May 2. 2012;2012:653098. [pmid: 22629180].
Chen CH, Tseng YF, Chou FH, et al. Effects of support group intervention in postnatally distressed women. A controlled study in Taiwan. J Psychosom Res. 2000;49(6):395-9. [pmid: 11182431].
Da Silva Magalhães PV, Pinheiro RT, Horta BL, et al. Validity of the Beck Depression Inventory in the postpartum period. International Journal of Psychiatry in Clinical Practice. 2008;12(1):81-84.
Figueira P, Malloy-Diniz L, Campos SB, et al. An association study between the Val66Met polymorphism of the BDNF gene and postpartum depression. Arch Womens Ment Health. 2010;13(3):285-9. [pmid: 20169377].
Flores-Quijano ME, Cordova A, Contreras-Ramirez V, et al. Risk for postpartum depression, breastfeeding practices, and mammary gland permeability. J Hum Lact. 2008;24(1):50-7. [pmid: 18281356].
Gao LL, Chan SW, Sun K. Effects of an interpersonal-psychotherapy-oriented childbirth education programme for Chinese first-time childbearing women at 3-month follow up: Randomised controlled trial. Int J Nurs Stud. 2011. Epub Oct 1. [pmid: 21962336].
Gao LL, Chan SW, Li X, et al. Evaluation of an interpersonal-psychotherapy-oriented childbirth education programme for Chinese first-time childbearing women: a randomised controlled trial. Int J Nurs Stud. 2010;47(10):1208-16. [pmid: 20362992].
Kalita KN. Developmental profile of infants born to mothers with postpartum depression and anxiety: A comparative study. Journal of Indian Association for Child and Adolescent Mental Health. 2010;6(1):3-12.
Lara MA, Navarro C, Navarrete L. Outcome results of a psycho-educational intervention in pregnancy to prevent PPD: a randomized control trial. J Affect Disord. 2010;122(1–2):109-17. [pmid: 19596446].
Lara MA, Navarro C, Navarrete L, et al. Retention rates and potential predictors in a longitudinal randomized control trial to prevent postpartum depression. Salud Mental. 2010;33(5):429-436.
Le HN, Perry DF, Ortiz G. The Postpartum Depression Screening Scale-Spanish version: examining the psychometric properties and prevalence of risk for postpartum depression. J Immigr Minor Health. 2010;12(2):249-58. [pmid: 19449208].
Li L, Liu F, Zhang H, et al. Chinese version of the Postpartum Depression Screening Scale: translation and validation. Nurs Res. 2011;60(4):231-9. [pmid: 21691238].
Mao Q, Zhu LX, Su XY. A comparison of postnatal depression and related factors between Chinese new mothers and fathers. J Clin Nurs. 2011;20(5–6):645-52. [pmid: 21320193].
Mariam KA, Srinivasan K. Antenatal psychological distress and postnatal depression: A prospective study from an urban clinic. Asian Journal of Psychiatry. 2009;2(2):71-73. [pmid: 23051032].
Mokhber N, Namjoo M, Tara F, et al. Effect of supplementation with selenium on postpartum depression: a randomized double-blind placebo-controlled trial. J Matern Fetal Neonatal Med. 2011;24(1):104-8. [pmid: 20528216].
Orhon FS, Soykan A, Ulukol B. Patient compliance to psychiatric interventions and course of postpartum mood disorders. Int J Psychiatry Med. 2007;37(4):445-57. [pmid: 18441631].
Orhon FS, Ulukol B, Soykan A. Postpartum mood disorders and maternal perceptions of infant patterns in well-child follow-up visits. Acta Paediatr. 2007;96(12):1777-83. [pmid: 18001335].
Orun E, Yalcin SS, Aykut O, et al. Breast milk lead and cadmium levels from suburban areas of Ankara. Sci Total Environ. 2011;409(13):2467-72. [pmid: 21496879].
Pinheiro RT, da Silva RA, Magalhaes PV, et al. Two studies on suicidality in the postpartum. Acta Psychiatr Scand. 2008;118(2):160-3. [pmid: 18498435].
Quelopana AM. Violence against women and postpartum depression: the experience of chilean women. Women Health. 2012;52(5):437-53. [pmid: 22747182].
Reichenheim ME, Moraes CL, Oliveira AS, et al. Revisiting the dimensional structure of the Edinburgh Postnatal Depression Scale (EPDS): empirical evidence for a general factor. BMC Med Res Methodol. 2011;11:93. [pmid: 21689442].
Reid M, Glazener C, Murray GD, et al. A two-centred pragmatic randomised controlled trial of two interventions of postnatal support. BJOG. 2002;109(10):1164-70. [pmid: 12387471].
Sercekus P, Mete S. Effects of antenatal education on maternal prenatal and postpartum adaptation. J Adv Nurs. 2010;66(5):999-1010. [pmid: 20337796].
Silva R, Jansen K, Souza L, et al. Sociodemographic risk factors of perinatal depression: a cohort study in the public health care system. Rev Bras Psiquiatr. 2012;34(2):143-8. [pmid: 22729409].
Wissart J, Parshad O, Kulkarni S. Prevalence of pre- and postpartum depression in Jamaican women. BMC Pregnancy Childbirth. 2005;5:15. [pmid: 16277665].
Xie RH, Lei J, Wang S, et al. Cesarean section and postpartum depression in a cohort of Chinese women with a high cesarean delivery rate. J Womens Health (Larchmt). 2011;20(12):1881-6. [pmid: 21877916].
Yang SN, Shen LJ, Ping T, et al. The delivery mode and seasonal variation are associated with the development of postpartum depression. J Affect Disord. 2011;132(1–2):158-64. [pmid: 21377210].
Yurdakul Z, Akman I, Kuscu MK, et al. Maternal psychological problems associated with neonatal intensive care admission. Int J Pediatr. 2009;2009:591359. [pmid: 20041013].
Zubaran C, Foresti K. Investigating quality of life and depressive symptoms in the postpartum period. Women Birth. 2011;24(1):10-6. [pmid: 20739246].
Zubaran C, Schumacher MV, Foresti K, et al. The Portuguese version of the Postpartum Depression Screening Scale-Short Form. J Obstet Gynaecol Res. 2010;36(5):950-7. [pmid: 20722983].

## No Interventions of Interest, or Timing of Intervention Not Within Range

Affonso DD, Lovett S, Paul SM, et al. A standardized interview that differentiates pregnancy and postpartum symptoms from perinatal clinical depression. Birth. 1990;17(3):121-30. [pmid: 2222637].
Alder J, Fink N, Urech C, et al. Identification of antenatal depression in obstetric care. Arch Gynecol Obstet. 2011;284(6):1403-9. [pmid: 21424404].
Allison KC, Wenzel A, Kleiman K, et al. Development of a brief measure of postpartum distress. J Womens Health (Larchmt). 2011;20(4):617-23. [pmid: 21413895].
Ammaniti M, Speranza AM, Tambelli R, et al. A prevention and promotion intervention program in the field of mother-infant relationship. Infant Mental Health Journal. 2006;27(1):70-90.
Appleby L, Warner R, Whitton A, et al. A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. 1997;314(7085):932-6. [pmid: 9099116].
Armstrong K, Edwards H. The effectiveness of a pram-walking exercise programme in reducing depressive symptomatology for postnatal women. Int J Nurs Pract. 2004;10(4):177-94. [pmid: 15265228].
Armstrong KL, Fraser JA, Dadds MR, et al. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
Armstrong SJ, Small RE. The paradox of screening: rural women’s views on screening for postnatal depression. BMC Public Health. 2010;10:744. [pmid: 21122148].
Austin MP, Frilingos M, Lumley J, et al. Brief antenatal cognitive behaviour therapy group intervention for the prevention of postnatal depression and anxiety: a randomised controlled trial. J Affect Disord. 2008;105(1–3):35-44. [pmid: 17490753].
Bansil P, Kuklina EV, Meikle SF, et al. Maternal and fetal outcomes among women with depression. J Womens Health (Larchmt). 2010;19(2):329-34. [pmid: 20095906].
Barkin JL, Wisner KL, Bromberger JT, et al. Assessment of functioning in new mothers. J Womens Health (Larchmt). 2010;19(8):1493-9. [pmid: 20629572].
Bennett IM, Palmer S, Marcus S, et al. One end has nothing to do with the other: patient attitudes regarding help seeking intention for depression in gynecologic and obstetric settings. Arch Womens Ment Health. 2009;12(5):301-8. [pmid: 19730982].
Bifulco A, Figueiredo B, Guedeney N, et al. Maternal attachment style and depression associated with childbirth: Preliminary results from a European and US cross-cultural study. British Journal of Psychiatry. 2004;184(SUPPL 46):s31-s37.
Blackmore ER, Carroll J, Reid A, et al. The use of the Antenatal Psychosocial Health Assessment (ALPHA) tool in the detection of psychosocial risk factors for postpartum depression: a randomized controlled trial. J Obstet Gynaecol Can. 2006;28(10):873-8. [pmid: 17140502].
Bryan TL, Georgiopoulos AM, Harms RW, et al. Incidence of postpartum depression in Olmsted County, Minnesota. A population-based, retrospective study. J Reprod Med. 1999;44(4):351-8. [pmid: 10319305].
Cho HJ, Kwon JH, Lee JJ. Antenatal cognitive-behavioral therapy for prevention of postpartum depression: a pilot study. Yonsei Med J. 2008;49(4):553-62. [pmid: 18729297].
Comtois KA, Schiff MA, Grossman DC. Psychiatric risk factors associated with postpartum suicide attempt in Washington State, 1992–2001. Am J Obstet Gynecol. 2008;199(2):120 e1-5. [pmid: 18355781].
Conroy S, Pariante CM, Marks MN, et al. Maternal psychopathology and infant development at 18 months: The impact of maternal personality disorder and depression. Journal of the American Academy of Child and Adolescent Psychiatry. 2012;51(1):51-61. [pmid: 22176939].
Cooper C, Jones L, Dunn E, et al. Clinical presentation of postnatal and non-postnatal depressive episodes. Psychol Med. 2007;37(9):1273-80. [pmid: 17349101].
Cox JL, Connor Y, Kendell RE. Prospective study of the psychiatric disorders of childbirth. Br J Psychiatry. 1982;140:111-7. [pmid: 7074291].
Da Costa D, Dritsa M, Verreault N, et al. Sleep problems and depressed mood negatively impact health-related quality of life during pregnancy. Arch Womens Ment Health. 2010;13(3):249-57. [pmid: 19728037].
Damato EG. Prenatal attachment and other correlates of postnatal maternal attachment to twins. Adv Neonatal Care. 2004;4(5):274-91. [pmid: 15517522].
De Las Cuevas C, de la Rosa MA, Troyano JM, et al. Are psychotropics drugs used in pregnancy?. Pharmacoepidemiol Drug Saf. 2007;16(9):1018-23. [pmid: 17455181].
Della Vedova AM, Ducceschi B, Cesana BM, et al. Maternal bonding and risk of depression in late pregnancy: A survey of Italian nulliparous women. Journal of Reproductive and Infant Psychology. 2011;29(3):208-222.
Dencker A, Taft C, Bergqvist L, et al. Childbirth experience questionnaire (CEQ): development and evaluation of a multidimensional instrument. BMC Pregnancy Childbirth. 2010;10:81. [pmid: 21143961].
Dennis CL, Boyce P. Further psychometric testing of a brief personality scale to measure vulnerability to postpartum depression. J Psychosom Obstet Gynaecol. 2004;25(3–4):305-11. [pmid: 15715029].
Dietz PM, Williams SB, Callaghan WM, et al. Clinically identified maternal depression before, during, and after pregnancies ending in live births. Am J Psychiatry. 2007;164(10):1515-20. [pmid: 17898342].
Evans J, Melotti R, Heron J, et al. The timing of maternal depressive symptoms and child cognitive development: a longitudinal study. J Child Psychol Psychiatry. 2012;53(6):632-40. [pmid: 22211468].
Fernandez YGE, Lacaze C, Ratanasen M. Continuous quality improvement for postpartum depression screening and referral. Pediatr Int. 2011;53(2):277-9. [pmid: 21366803].
Ferro MA, Avison WR, Campbell MK, et al. The impact of maternal depressive symptoms on health-related quality of life in children with epilepsy: a prospective study of family environment as mediators and moderators. Epilepsia. 2011;52(2):316-25. [pmid: 21054352].
Field T, Diego M, Hernandez-Reif M, et al. Pregnancy massage reduces prematurity, low birthweight and postpartum depression. Infant Behav Dev. 2009;32(4):454-60. [pmid: 19646762].
Fisher JR, Hammarberg K, Baker GH. Antenatal mood and fetal attachment after assisted conception. Fertil Steril. 2008;89(5):1103-12. [pmid: 17706213].
Fisher JR, Wynter KH, Rowe HJ. Innovative psycho-educational program to prevent common postpartum mental disorders in primiparous women: a before and after controlled study. BMC Public Health. 2010;10:432. [pmid: 20653934].
Ford E, Ayers S. Support during birth interacts with prior trauma and birth intervention to predict postnatal post-traumatic stress symptoms. Psychology & Health. 2011;26(12):1553-1570. [pmid: 21598181].
Forty L, Jones L, Macgregor S, et al. Familiality of postpartum depression in unipolar disorder: results of a family study. Am J Psychiatry. 2006;163(9):1549-53. [pmid: 16946179].
Fransson E, Örtenstrand A, Hjelmstedt A. Antenatal depressive symptoms and preterm birth: A prospective study of a Swedish national sample. Birth: Issues in Perinatal Care. 2011;38(1):10-16. [pmid: 21332769].
Freeman MP, Hibbeln JR, Wisner KL, et al. Randomized dose-ranging pilot trial of omega-3 fatty acids for postpartum depression. Acta Psychiatr Scand. 2006;113(1):31-5. [pmid: 16390366].
Gamble J, Creedy D, Moyle W, et al. Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. 2005;32(1):11-9. [pmid: 15725200].
Gaugler-Senden IP, Duivenvoorden HJ, Filius A, et al. Maternal psychosocial outcome after early onset preeclampsia and preterm birth. J Matern Fetal Neonatal Med. 2011. Epub May 11. [pmid: 21557690].
Gee CB, Rhodes JE. A social support and social strain measure for minority adolescent mothers: a confirmatory factor analytic study. Child Care Health Dev. 2008;34(1):87-97. [pmid: 18171449].
Gemmill AW, Leigh B, Ericksen J, et al. A survey of the clinical acceptability of screening for postnatal depression in depressed and non-depressed women. BMC Public Health. 2006;6:211. [pmid: 16914061].
Glavin K, Smith L, Sorum R, et al. Supportive counselling by public health nurses for women with postpartum depression. J Adv Nurs. 2010;66(6):1317-27. [pmid: 20384641].
Gunning M, Conroy S, Valoriani V, et al. Measurement of mother-infant interactions and the home environment in a European setting: preliminary results from a cross-cultural study. Br J Psychiatry Suppl. 2004;46:s38-44. [pmid: 14754817].
Hagan R, Evans SF, Pope S. Preventing postnatal depression in mothers of very preterm infants: a randomised controlled trial. BJOG. 2004;111(7):641-7. [pmid: 15198752].
Hall PL, Papageorgiou C. Negative thoughts after childbirth: development and preliminary validation of a self-report scale. Depress Anxiety. 2005;22(3):121-9. [pmid: 16220554].
Harrison PA, Sidebottom AC. Systematic prenatal screening for psychosocial risks. J Health Care Poor Underserved. 2008;19(1):258-76. [pmid: 18264001].
Harvey ST, Fisher LJ, Green VM. Evaluating the clinical efficacy of a primary care-focused, nurse-led, consultation liaison model for perinatal mental health. Int J Ment Health Nurs. 2012;21(1):75-81. [pmid: 21895906].
Haslam DM, Pakenham KI, Smith A. Social Support and Postpartum Depressive Symptomatology: The Mediating Role of Maternal Self-efficacy. Infant Mental Health Journal. 2006;27(3):276-291.
Hayes BA, Muller R. Prenatal depression: a randomized controlled trial in the emotional health of primiparous women. Res Theory Nurs Pract. 2004;18(2–3):165-83. [pmid: 15553345].
Hiscock H, Bayer J, Gold L, et al. Improving infant sleep and maternal mental health: a cluster randomised trial. Arch Dis Child. 2007;92(11):952-8. [pmid: 17158146].
Hiscock H, Bayer JK, Hampton A, et al. Long-term mother and child mental health effects of a population-based infant sleep intervention: cluster-randomized, controlled trial. Pediatrics. 2008;122(3):e621-7. [pmid: 18762495].
Howell EA, Balbierz A, Wang J, et al. Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol. 2012;119(5):942-9. [pmid: 22488220].
Howell EA, Mora PA, DiBonaventura MD, et al. Modifiable factors associated with changes in postpartum depressive symptoms. Arch Womens Ment Health. 2009;12(2):113-20. [pmid: 19238520].
Jansen AJ, Essink-Bot ML, Duvekot JJ, et al. Psychometric evaluation of health-related quality of life measures in women after different types of delivery. J Psychosom Res. 2007;63(3):275-81. [pmid: 17719365].
Jardri R, Maron M, Delion P, et al. Pain as a confounding factor in postnatal depression screening. J Psychosom Obstet Gynaecol. 2010;31(4):252-5. [pmid: 20937012].
Jevitt CM, Groer MW, Crist NF, et al. Postpartum stressors: A content analysis. Issues in Mental Health Nursing. 2012;33(5):309-318. [pmid: 22545638].
Kammerer M, Marks MN, Pinard C, et al. Symptoms associated with the DSM IV diagnosis of depression in pregnancy and post partum. Arch Womens Ment Health. 2009;12(3):135-41. [pmid: 19337702].
Klemetti R, Kurinczuk JJ, Redshaw M. Older women’s pregnancy related symptoms, health and use of antenatal services. Eur J Obstet Gynecol Reprod Biol. 2011;154(2):157-62. [pmid: 21112684].
Koubaa S, Hallstrom T, Hirschberg AL. Early maternal adjustment in women with eating disorders. Int J Eat Disord. 2008;41(5):405-10. [pmid: 18306346].
Labad J, Vilella E, Reynolds RM, et al. Increased morning adrenocorticotrophin hormone (ACTH) levels in women with postpartum thoughts of harming the infant. Psychoneuroendocrinology. 2011;36(6):924-928. [pmid: 21168281].
Lacoursiere DY, Baksh L, Bloebaum L, et al. Maternal body mass index and self-reported postpartum depressive symptoms. Matern Child Health J. 2006;10(4):385-90. [pmid: 16673179].
Lagerberg D, Magnusson M, Sundelin C. Drawing the line in the Edinburgh Postnatal Depression Scale (EPDS): a vital decision. Int J Adolesc Med Health. 2011;23(1):27-32. [pmid: 21721360].
Lal M, Pattison HM, Allan TF, et al. Postcesarean pelvic floor dysfunction contributes to undisclosed psychosocial morbidity. J Reprod Med. 2009;54(2):53-60. [pmid: 19301567].
Leddy MA, Farrow VA, Joseph GF Jr, et al. Obstetrician/gynecologists and postpartum mental health: differences between CME course takers and nontakers. J Contin Educ Health Prof. 2012;32(1):39-47. [pmid: 22447710].
Lester BM, Miller RJ, Hawes K, et al. Infant neurobehavioral development. Semin Perinatol. 2011;35(1):8-19. [pmid: 21255702].
Lincoln A, Feyerharm R, Damron P, et al. Maternal depression after delivery in Oklahoma. J Okla State Med Assoc. 2008;101(12):307-11. [pmid: 19177992].
Logsdon MC, Wisner K, Sit D, et al. Depression treatment and maternal functioning. Depress Anxiety. 2011;28(11):1020-6. [pmid: 21898714].
Macedo A, Marques M, Bos S, et al. Mother’s personality and infant temperament. Infant Behav Dev. 2011;34(4):552-68. [pmid: 21802732].
Marcenko MO, Spence M. Home visitation services for at-risk pregnant and postpartum women: a randomized trial. Am J Orthopsychiatry. 1994;64(3):468-78. [pmid: 7977669].
Marks MN, Siddle K, Warwick C. Can we prevent postnatal depression? A randomized controlled trial to assess the effect of continuity of midwifery care on rates of postnatal depression in high-risk women. J Matern Fetal Neonatal Med. 2003;13(2):119-27. [pmid: 12735413].
Marrs CR, Durette RT, Ferraro DP, et al. Dimensions of postpartum psychiatric distress: preliminary evidence for broadening clinical scope. J Affect Disord. 2009;115(1–2):100-11. [pmid: 18829117].
Mazzeo SE, Landt MCTS-Ot, Jones I, et al. Associations among postpartum depression, eating disorders, and perfectionism in a population-based sample of adult women. International Journal of Eating Disorders. 2006;39(3):202-211. [pmid: 16498586].
McAuliffe A, Russell NE, Fenton J. Psychological services for women giving birth in a large Irish tertiary referral maternity unit. Psychiatrist. 2011;35(3):92-94.
McGarry J, Kim H, Sheng X, et al. Postpartum depression and help-seeking behavior. J Midwifery Womens Health. 2009;54(1):50-6. [pmid: 19114239].
McLearn KT, Minkovitz CS, Strobino DM, et al. The timing of maternal depressive symptoms and mothers’ parenting practices with young children: implications for pediatric practice. Pediatrics. 2006;118(1):e174-82. [pmid: 16818531].
Milgrom J, Holt CJ, Gemmill AW, et al. Treating postnatal depressive symptoms in primary care: a randomised controlled trial of GP management, with and without adjunctive counselling. BMC Psychiatry. 2011;11:95. [pmid: 21615968].
Munk-Olsen T, Gasse C, Laursen TM. Prevalence of antidepressant use and contacts with psychiatrists and psychologists in pregnant and postpartum women. Acta Psychiatrica Scandinavica. 2012;125(4):318-324. [pmid: 22118213].
Muñoz RF, Le H-N, Ippen CG, et al. Prevention of postpartum depression in low-income women: Development of the Mamás y Bebés/Mothers and Babies course. Cognitive and Behavioral Practice. 2007;14(1):70-83.
Naicker K, Wickham M, Colman I. Timing of first exposure to maternal depression and adolescent emotional disorder in a national Canadian cohort. PLoS ONE. 2012;7(3):e33422. [pmid: 22461893].
Oommen H, Rantanen A, Kaunonen M, et al. Social support provided to Finnish mothers and fathers by nursing professionals in the postnatal ward. Midwifery. 2011;27(5):754-61. [pmid: 20888673].
Patel SR, Wisner KL. Decision making for depression treatment during pregnancy and the postpartum period. Depress Anxiety. 2011;28(7):589-95. [pmid: 21681871].
Pedersen P, Baker JL, Henriksen TB, et al. Influence of psychosocial factors on postpartum weight retention. Obesity (Silver Spring). 2011;19(3):639-46. [pmid: 20706201].
Persson EK, Dykes AK. Important variables for parents’ postnatal sense of security: evaluating a new Swedish instrument (the PPSS instrument). Midwifery. 2009;25(4):449-60. [pmid: 18082919].
Plaza A, Torres A, Martin-Santos R, et al. Validation and test-retest reliability of Early Trauma Inventory in Spanish postpartum women. J Nerv Ment Dis. 2011;199(4):280-5. [pmid: 21451355].
Polanska K, Hanke W, Sobala W, et al. Predictors of smoking relapse after delivery: prospective study in central Poland. Matern Child Health J. 2011;15(5):579-86. [pmid: 20623367].
Pop VJ, Essed GG, de Geus CA, et al. Prevalence of post partum depression--or is it post-puerperium depression?. Acta Obstet Gynecol Scand. 1993;72(5):354-8. [pmid: 8392265].
Price SK, Handrick SL. A culturally relevant and responsive approach to screening for perinatal depression. Research on Social Work Practice. 2009;19(6):705-714.
Priest SR, Henderson J, Evans SF, et al. Stress debriefing after childbirth: a randomised controlled trial. Med J Aust. 2003;178(11):542-5. [pmid: 12765500].
Reay R, Matthey S, Ellwood D, et al. Long-term outcomes of participants in a perinatal depression early detection program. J Affect Disord. 2011;129(1–3):94-103. [pmid: 20800898].
Reck C, Stehle E, Reinig K, et al. Maternity blues as a predictor of DSM-IV depression and anxiety disorders in the first three months postpartum. J Affect Disord. 2009;113(1–2):77-87. [pmid: 18573539].
Redshaw M, Heikkila K. Ethnic differences in women’s worries about labour and birth. Ethn Health. 2011;16(3):213-23. [pmid: 21500115].
Redshaw M, Martin C, Rowe R, et al. The Oxford Worries about Labour Scale: women’s experience and measurement characteristics of a measure of maternal concern about labour and birth. Psychol Health Med. 2009;14(3):354-66. [pmid: 19444713].
Rees DI, Sabia JJ. The relationship between abortion and depression: new evidence from the fragile families and child wellbeing study. Med Sci Monit. 2007;13(10):CR430-6. [pmid: 17901849].
Reid T, Bramwell R, Booth N, et al. A new stressor scale for parents experiencing neonatal intensive care: The NUPS (Neonatal Unit Parental Stress) scale. Journal of Reproductive and Infant Psychology. 2007;25(1):66-82.
Robinson M, Oddy WH, Li J, et al. Pre- and postnatal influences on preschool mental health: a large-scale cohort study. J Child Psychol Psychiatry. 2008;49(10):1118-28. [pmid: 19017026].
Rowlands I, Lee C. Adjustment after miscarriage: Predicting positive mental health trajectories among young Australian women. Psychol Health Med. 2010;15(1):34-49. [pmid: 20391223].
Rudman A, Waldenstrom U. Critical views on postpartum care expressed by new mothers. BMC Health Serv Res. 2007;7:178. [pmid: 17983479].
Ryan P, Weiss M, Traxel N, et al. Testing the integrated theory of health behaviour change for postpartum weight management. J Adv Nurs. 2011;67(9):2047-59. [pmid: 21507051].
Salisbury AL, Lester BM, Seifer R, et al. Prenatal cocaine use and maternal depression: effects on infant neurobehavior. Neurotoxicol Teratol. 2007;29(3):331-40. [pmid: 17258430].
Schmied V, Cooke M, Gutwein R, et al. An evaluation of strategies to improve the quality and content of hospital-based postnatal care in a metropolitan Australian hospital. J Clin Nurs. 2009;18(13):1850-61. [pmid: 19638047].
Sealy PA, Fraser J, Simpson JP, et al. Community awareness of postpartum depression. J Obstet Gynecol Neonatal Nurs. 2009;38(2):121-33. [pmid: 19323709].
Segre LS, O’Hara MW, Fisher SD. Perinatal Depression Screening in Healthy Start: An Evaluation of the Acceptability of Technical Assistance Consultation. Community Ment Health J. 2012. Epub Mar 27. [pmid: 22451017].
Singh PK, Lustman PJ, Clouse RE, et al. Association of depression with complications of diabetic pregnancy: A retrospective analysis. Journal of Clinical Psychology in Medical Settings. 2004;11(1):49-54.
Stadlmayr W, Bitzer J, Amsler F, et al. Acute stress reactions in the first 3 weeks postpartum: a study of 219 parturients. Eur J Obstet Gynecol Reprod Biol. 2007;135(1):65-72. [pmid: 17194520].
Stramrood CA, Huis In ‘t Veld EM, Van Pampus MG, et al. Measuring posttraumatic stress following childbirth: a critical evaluation of instruments. J Psychosom Obstet Gynaecol. 2010;31(1):40-9. [pmid: 20146642].
Strom M, Mortensen EL, Halldorsson TI, et al. Fish and long-chain n-3 polyunsaturated fatty acid intakes during pregnancy and risk of postpartum depression: a prospective study based on a large national birth cohort. Am J Clin Nutr. 2009;90(1):149-55. [pmid: 19474139].
Tham V, Christensson K, Ryding EL. Sense of coherence and symptoms of post-traumatic stress after emergency caesarean section. Acta Obstet Gynecol Scand. 2007;86(9):1090-6. [pmid: 17712650].
Tsai PJ, Nakashima L, Yamamoto J, et al. Postpartum follow-up rates before and after the postpartum follow-up initiative at Queen Emma Clinic. Hawaii Med J. 2011;70(3):56-9. [pmid: 21365543].
Turton P, Badenhorst W, Pawlby S, et al. Psychological vulnerability in children next-born after stillbirth: a case-control follow-up study. J Child Psychol Psychiatry. 2009;50(12):1451-8. [pmid: 19594837].
Ugarriza DN, Schmidt L. Telecare for women with postpartum depression. J Psychosoc Nurs Ment Health Serv. 2006;44(1):37-45. [pmid: 16475443].
Vesga-Lopez O, Blanco C, Keyes K, et al. Psychiatric disorders in pregnant and postpartum women in the United States. Arch Gen Psychiatry. 2008;65(7):805-15. [pmid: 18606953].
Waldenstrom U, Brown S, McLachlan H, et al. Does team midwife care increase satisfaction with antenatal, intrapartum, and postpartum care? A randomized controlled trial. Birth. 2000;27(3):156-67. [pmid: 11251496].
Walkup JT, Barlow A, Mullany BC, et al. Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. J Am Acad Child Adolesc Psychiatry. 2009;48(6):591-601. [pmid: 19454915].
Watson JP, Elliott SA, Rugg AJ, et al. Psychiatric disorder in pregnancy and the first postnatal year. Br J Psychiatry. 1984;144:453-62. [pmid: 6733369].
Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: A naturalistic study. Journal of Reproductive and Infant Psychology. 2005;23(1):33-41.
Wiggins M, Oakley A, Roberts I, et al. Postnatal support for mothers living in disadvantaged inner city areas: a randomised controlled trial. J Epidemiol Community Health. 2005;59(4):288-95. [pmid: 15767382].
Wiggins M, Oakley A, Roberts I, et al. The Social Support and Family Health Study: a randomised controlled trial and economic evaluation of two alternative forms of postnatal support for mothers living in disadvantaged inner-city areas. Health Technol Assess. ix. 2004;8(32):iii-x. 1. 120. [pmid: 15298823].
Wiklund I, Mohlkert P, Edman G. Evaluation of a brief cognitive intervention in patients with signs of postnatal depression: a randomized controlled trial. Acta Obstet Gynecol Scand. 2010;89(8):1100-4. [pmid: 20636249].
Wilson DA, Bobier C, Macdonald EM. A perinatal psychiatric service audit in New Zealand: patient characteristics and outcomes. Arch Womens Ment Health. 2004;7(1):71-9. [pmid: 14963736].
Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. 2009;34(5):297-302. [pmid: 19713798].
Wisner KL, Hanusa BH, Perel JM, et al. Postpartum depression: a randomized trial of sertraline versus nortriptyline. J Clin Psychopharmacol. 2006;26(4):353-60. [pmid: 16855451].
Wisner KL, Perel JM, Peindl KS, et al. Prevention of postpartum depression: a pilot randomized clinical trial. Am J Psychiatry. 2004;161(7):1290-2. [pmid: 15229064].
Wisner KL, Perel JM, Peindl KS, et al. Prevention of recurrent postpartum depression: a randomized clinical trial. J Clin Psychiatry. 2001;62(2):82-6. [pmid: 11247106].
Wittkowski A, Harvey J, Wieck A. A survey of instruments used for the psychological assessment of patients admitted to mother and baby inpatient facilities. Arch Womens Ment Health. 2007;10(5):237-40. [pmid: 17680331].
Wittkowski A, Williams J, Wieck A. An examination of the psychometric properties and factor structure of the Post-partum Bonding Questionnaire in a clinical inpatient sample. Br J Clin Psychol. 2010;49(Pt 2):163-72. [pmid: 19460238].
Woolhouse H, Brown S, Krastev A, et al. Seeking help for anxiety and depression after childbirth: results of the Maternal Health Study. Arch Womens Ment Health. 2009;12(2):75-83. [pmid: 19214705].
Yonkers KA, Gotman N, Smith MV, et al. Does antidepressant use attenuate the risk of a major depressive episode in pregnancy?. Epidemiology. 2011;22(6):848-854. [pmid: 21900825].
Yonkers KA, Lin H, Howell HB, et al. Pharmacologic treatment of postpartum women with new-onset major depressive disorder: a randomized controlled trial with paroxetine. J Clin Psychiatry. 2008;69(4):659-65. [pmid: 18363420].
Ystrom E. Breastfeeding cessation and symptoms of anxiety and depression: a longitudinal cohort study. BMC Pregnancy Childbirth. 2012;12(1):36. [pmid: 22621668].

## No Comparator of Interest

Allen AM, Prince CB, Dietz PM. Postpartum depressive symptoms and smoking relapse. Am J Prev Med. 2009;36(1):9-12. [pmid: 19095161].
Armstrong S, Small R. Screening for postnatal depression: not a simple task. Aust N Z J Public Health. 2007;31(1):57-61. [pmid: 17333610].
Baker-Ericzén MJ, Mueggenborg MG, Hartigan P, et al. Partnership for women’s health: A new-age collaborative program for addressing maternal depression in the postpartum period. Families, Systems, & Health. 2008;26(1):30-43.
Bandyopadhyay M, Small R, Watson LF, et al. Life with a new baby: how do immigrant and Australian-born women’s experiences compare?. Aust N Z J Public Health. 2010;34(4):412-21. [pmid: 20649783].
Barnes J, Ram B, Leach P, et al. Factors associated with negative emotional expression: A study of mothers of young infants. Journal of Reproductive and Infant Psychology. 2007;25(2):122-138.
Cerulli C, Talbot NL, Tang W, et al. Co-occurring intimate partner violence and mental health diagnoses in perinatal women. Journal of Women’s Health. 2011;20(12):1797-1803. [pmid: 21923282].
Chen H, Wang J, Ch’ng YC, et al. Identifying mothers with postpartum depression early: integrating perinatal mental health care into the obstetric setting. ISRN Obstet Gynecol. 2011;2011:309189. [pmid: 21941662].
Dalfrà MG, Nicolucci A, Bisson T, et al. Quality of life in pregnancy and post-partum: A study in diabetic patients. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care &. Rehabilitation. 2012;21(2):291-298. [pmid: 21633879].
Darcy JM, Grzywacz JG, Stephens RL, et al. Maternal depressive symptomatology: 16-month follow-up of infant and maternal health-related quality of life. J Am Board Fam Med. 2011;24(3):249-57. [pmid: 21551396].
Ginsburg GS, Barlow A, Goklish N, et al. Postpartum Depression Prevention for Reservation-Based American Indians: Results from a Pilot Randomized Controlled Trial. Child Youth Care Forum. 2012;41(3):229-245. [pmid: 22701296].
Hanington L, Heron J, Stein A, et al. Parental depression and child outcomes – is marital conflict the missing link?. Child: Care, Health and Development. 2012;38(4):520-529. [pmid: 21771000].
Hunker DF, Patrick TE, Albrecht SA, et al. Is difficult childbirth related to postpartum maternal outcomes in the early postpartum period?. Arch Womens Ment Health. 2009;12(4):211-9. [pmid: 19350370].
Iles J, Slade P, Spiby H. Posttraumatic stress symptoms and postpartum depression in couples after childbirth: the role of partner support and attachment. J Anxiety Disord. 2011;25(4):520-30. [pmid: 21295438].
Imsiragic AS, Begic D, Martic-Biocina S. Acute stress and depression 3 days after vaginal delivery--observational, comparative study. Coll Antropol. 2009;33(2):521-7. [pmid: 19662773].
Ishikawa N, Goto S, Murase S, et al. Prospective study of maternal depressive symptomatology among Japanese women. J Psychosom Res. 2011;71(4):264-9. [pmid: 21911105].
Jardri R, Maron M, Pelta J, et al. Impact of midwives’ training on postnatal depression screening in the first week post delivery: a quality improvement report. Midwifery. 2010;26(6):622-9. [pmid: 19211177].
Jewell JS, Dunn AL, Bondy J, et al. Prevalence of self-reported postpartum depression specific to season and latitude of birth: evaluating the PRAMS data. Matern Child Health J. 2010;14(2):261-7. [pmid: 19669394].
Jomeen J, Martin CR. The impact of choice of maternity care on psychological health outcomes for women during pregnancy and the postnatal period. J Eval Clin Pract. 2008;14(3):391-8. [pmid: 18373580].
Josefsson A, Larsson C, Sydsjo G, et al. Temperament and character in women with postpartum depression. Arch Womens Ment Health. 2007;10(1):3-7. [pmid: 17143777].
Kabir K, Sheeder J, Kelly LS. Identifying postpartum depression: are 3 questions as good as 10?. Pediatrics. 2008;122(3):e696-702. [pmid: 18762505].
Katz KS, Blake SM, Milligan RA, et al. The design, implementation and acceptability of an integrated intervention to address multiple behavioral and psychosocial risk factors among pregnant African American women. BMC Pregnancy Childbirth. 2008;8:22. [pmid: 18578875].
Kehler HL, Chaput KH, Tough SC. Risk factors for cessation of breastfeeding prior to six months postpartum among a community sample of women in Calgary, Alberta. Can J Public Health. 2009;100(5):376-80. [pmid: 19994742].
Keim SA, Daniels JL, Dole N, et al. A prospective study of maternal anxiety, perceived stress, and depressive symptoms in relation to infant cognitive development. Early Hum Dev. 2011;87(5):373-80. [pmid: 21420261].
Kennedy HP, Farrell T, Paden R, et al. A randomized clinical trial of group prenatal care in two military settings. Mil Med. 2011;176(10):1169-77. [pmid: 22128654].
Lau Y, Chan KS. Influence of intimate partner violence during pregnancy and early postpartum depressive symptoms on breastfeeding among chinese women in Hong Kong. J Midwifery Womens Health. 2007;52(2):e15-20. [pmid: 17336812].
Lau Y, Wong DF. The role of social support in helping Chinese women with perinatal depressive symptoms cope with family conflict. J Obstet Gynecol Neonatal Nurs. 2008;37(5):556-71. [pmid: 18811775].
Le HN, Perry DF, Stuart EA. Randomized controlled trial of a preventive intervention for perinatal depression in high-risk Latinas. J Consult Clin Psychol. 2011;79(2):135-41. [pmid: 21319897].
Leahy-Warren P, McCarthy G, Corcoran P. First-time mothers: social support, maternal parental self-efficacy and postnatal depression. J Clin Nurs. 2012;21(3–4):388-97. [pmid: 21435059].
Leahy-Warren P, McCarthy G, Corcoran P. Postnatal depression in first-time mothers: prevalence and relationships between functional and structural social support at 6 and 12 weeks postpartum. Arch Psychiatr Nurs. 2011;25(3):174-84. [pmid: 21621731].
Lee DT, Ngai IS, Ng MM, et al. Antenatal taboos among Chinese women in Hong Kong. Midwifery. 2009;25(2):104-13. [pmid: 17408821].
Lefkowitz DS, Baxt C, Evans JR. Prevalence and correlates of posttraumatic stress and postpartum depression in parents of infants in the Neonatal Intensive Care Unit (NICU). J Clin Psychol Med Settings. 2010;17(3):230-7. [pmid: 20632076].
Leigh B, Milgrom J. Risk factors for antenatal depression, postnatal depression and parenting stress. BMC Psychiatry. 2008;8:24. [pmid: 18412979].
Lilja G, Edhborg M, Nissen E. Depressive mood in women at childbirth predicts their mood and relationship with infant and partner during the first year postpartum. Scandinavian Journal of Caring Sciences. 2012;26(2):245-253. [pmid: 21950600].
Logsdon MC, Birkimer JC, Simpson T, et al. Postpartum depression and social support in adolescents. J Obstet Gynecol Neonatal Nurs. 2005;34(1):46-54. [pmid: 15673645].
Logsdon MC, Usui WM, Nering M. Validation of Edinburgh postnatal depression scale for adolescent mothers. Arch Womens Ment Health. 2009;12(6):433-40. [pmid: 19639384].
Lumley J, Watson L, Small R, et al. PRISM (Program of Resources, Information and Support for Mothers): a community-randomised trial to reduce depression and improve women’s physical health six months after birth. [ISRCTN03464021]. BMC Public Health. 2006;6:37. [pmid: 16483383].
Marques M, Bos S, Soares MJ, et al. Is insomnia in late pregnancy a risk factor for postpartum depression/depressive symptomatology?. Psychiatry Res. 2011;186(2–3):272-80. [pmid: 20638730].
Matthey S, Phillips J, White T, et al. Routine psychosocial assessment of women in the antenatal period: frequency of risk factors and implications for clinical services. Arch Womens Ment Health. 2004;7(4):223-9. [pmid: 15338316].
Matthey S. Using the Edinburgh Postnatal Depression Scale to screen for anxiety disorders. Depress Anxiety. 2008;25(11):926-31. [pmid: 18041072].
Mautner E, Greimel E, Trutnovsky G, et al. Quality of life outcomes in pregnancy and postpartum complicated by hypertensive disorders, gestational diabetes, and preterm birth. J Psychosom Obstet Gynaecol. 2009;30(4):231-7. [pmid: 19845493].
McCallum SM, Rowe HJ, Gurrin L, et al. Unsettled infant behaviour and health service use: a cross-sectional community survey in Melbourne, Australia. J Paediatr Child Health. 2011;47(11):818-23. [pmid: 21679331].
McCarter-Spaulding D, Horowitz JA. How does postpartum depression affect breastfeeding?. MCN Am J Matern Child Nurs. 2007;32(1):10-7. [pmid: 17308452].
McConachie H, Hammal D, Welsh B, et al. Wellbeing of new mothers. Community Pract. 2008;81(3):19-22. [pmid: 18416404].
McLearn KT, Minkovitz CS, Strobino DM, et al. Maternal depressive symptoms at 2 to 4 months post partum and early parenting practices. Arch Pediatr Adolesc Med. 2006;160(3):279-84. [pmid: 16520447].
McMahon C, Barnett B, Kowalenko N, et al. Psychological factors associated with persistent postnatal depression: past and current relationships, defence styles and the mediating role of insecure attachment style. J Affect Disord. 2005;84(1):15-24. [pmid: 15620381].
McMahon CA, Barnett B, Kowalenko NM, et al. Maternal attachment state of mind moderates the impact of postnatal depression on infant attachment. J Child Psychol Psychiatry. 2006;47(7):660-9. [pmid: 16790001].
McMahon CA, Boivin J, Gibson FL, et al. Older first-time mothers and early postpartum depression: a prospective cohort study of women conceiving spontaneously or with assisted reproductive technologies. Fertil Steril. 2011;96(5):1218-24. [pmid: 21963230].
Mechakra-Tahiri S, Zunzunegui MV, Seguin L. Self-rated health and postnatal depressive symptoms among immigrant mothers in Quebec. Women Health. 2007;45(4):1-17. [pmid: 18032165].
Milgrom J, Negri LM, Gemmill AW, et al. A randomized controlled trial of psychological interventions for postnatal depression. Br J Clin Psychol. 2005;44(Pt 4):529-42. [pmid: 16368032].
Miller L, Shade M, Vasireddy V. Beyond screening: assessment of perinatal depression in a perinatal care setting. Arch Womens Ment Health. 2009;12(5):329-34. [pmid: 19499284].
Miller RL, Pallant JF, Negri LM. Anxiety and stress in the postpartum: is there more to postnatal distress than depression?. BMC Psychiatry. 2006;6:12. [pmid: 16563155].
Mitchell AM, Mittelstaedt ME, Schott-Baer D. Postpartum depression: the reliability of telephone screening. MCN Am J Matern Child Nurs. 2006;31(6):382-7. [pmid: 17149115].
Miyake Y, Sasaki S, Tanaka K, et al. Dietary folate and vitamins B12, B6, and B2 intake and the risk of postpartum depression in Japan: the Osaka Maternal and Child Health Study. J Affect Disord. 2006;96(1–2):133-8. [pmid: 16815556].
Miyake Y, Sasaki S, Yokoyama T, et al. Risk of postpartum depression in relation to dietary fish and fat intake in Japan: the Osaka Maternal and Child Health Study. Psychol Med. 2006;36(12):1727-35. [pmid: 16938145].
Miyake Y, Tanaka K, Sasaki S, et al. Employment, income, and education and risk of postpartum depression: the Osaka Maternal and Child Health Study. J Affect Disord. 2011;130(1–2):133-7. [pmid: 21055825].
Monti F, Agostini F, Marano G, et al. The course of maternal depressive symptomatology during the first 18 months postpartum in an Italian sample. Arch Womens Ment Health. 2008;11(3):231-8. [pmid: 18493711].
Mori T, Tsuchiya KJ, Matsumoto K, et al. Psychosocial risk factors for postpartum depression and their relation to timing of onset: the Hamamatsu Birth Cohort (HBC) Study. J Affect Disord. 2011;135(1–3):341-6. [pmid: 21824663].
Morrell CJ, Warner R, Slade P, et al. Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PoNDER trial. Health Technol Assess. 2009;13(30):iii-iv. xi. xiii. 1. 153. [pmid: 19555590].
Morse C, Durkin S, Buist A, et al. Improving the postnatal outcomes of new mothers. J Adv Nurs. 2004;45(5):465-74. [pmid: 15009349].
Moss KM, Skouteris H, Wertheim EH, et al. Depressive and anxiety symptoms through late pregnancy and the first year post birth: an examination of prospective relationships. Arch Womens Ment Health. 2009;12(5):345-9. [pmid: 19565328].
Muller MA, Bleker OP, Bonsel GJ, et al. Nuchal translucency screening and anxiety levels in pregnancy and puerperium. Ultrasound Obstet Gynecol. 2006;27(4):357-61. [pmid: 16565991].
Murakami K, Miyake Y, Sasaki S, et al. Dietary glycemic index and load and the risk of postpartum depression in Japan: the Osaka Maternal and Child Health Study. J Affect Disord. 2008;110(1–2):174-9. [pmid: 18192024].
Murphy KE, Hannah ME, Willan AR, et al. Maternal side-effects after multiple courses of antenatal corticosteroids (MACS): the three-month follow-up of women in the randomized controlled trial of MACS for preterm birth study. J Obstet Gynaecol Can. 2011;33(9):909-21. [pmid: 21923988].
Navarro P, Garcia-Esteve L, Ascaso C, et al. Non-psychotic psychiatric disorders after childbirth: prevalence and comorbidity in a community sample. J Affect Disord. 2008;109(1–2):171-6. [pmid: 18001842].
Ngai FW, Chan SW, Ip WY. The effects of a childbirth psychoeducation program on learned resourcefulness, maternal role competence and perinatal depression: a quasi-experiment. Int J Nurs Stud. 2009;46(10):1298-306. [pmid: 19361801].
Ngai FW, Wai-Chi Chan S, Ip WY. Predictors and correlates of maternal role competence and satisfaction. Nurs Res. 2010;59(3):185-93. [pmid: 20404775].
Nishioka E, Haruna M, Ota E, et al. A prospective study of the relationship between breastfeeding and postpartum depressive symptoms appearing at 1–5 months after delivery. J Affect Disord. 2011;133(3):553-9. [pmid: 21705090].
Nishizono-Maher A, Kishimoto J, Yoshida H, et al. The role of self-report questionnaire in the screening of postnatal depression-a community sample survey in central Tokyo. Soc Psychiatry Psychiatr Epidemiol. 2004;39(3):185-90. [pmid: 14999450].
Norman E, Sherburn M, Osborne RH, et al. An exercise and education program improves well-being of new mothers: a randomized controlled trial. Phys Ther. 2010;90(3):348-55. [pmid: 20056720].
Okubo H, Miyake Y, Sasaki S, et al. Dietary patterns during pregnancy and the risk of postpartum depression in Japan: the Osaka Maternal and Child Health Study. Br J Nutr. 2011;105(8):1251-7. [pmid: 21144112].
O’Mahen HA, Flynn HA, Chermack S, et al. Illness perceptions associated with perinatal depression treatment use. Arch Womens Ment Health. 2009;12(6):447-50. [pmid: 19471852].
Oppo A, Mauri M, Ramacciotti D, et al. Risk factors for postpartum depression: the role of the Postpartum Depression Predictors Inventory-Revised (PDPI-R). Results from the Perinatal Depression-Research & Screening Unit (PNDReScU) study. Arch Womens Ment Health. 2009;12(4):239-49. [pmid: 19415454].
Ortenstrand A, Waldenstrom U. Mothers’ experiences of child health clinic services in Sweden. Acta Paediatr. 2005;94(9):1285-94. [pmid: 16278995].
Pallant JF, Miller RL, Tennant A. Evaluation of the Edinburgh Post Natal Depression Scale using Rasch analysis. BMC Psychiatry. 2006;6:28. [pmid: 16768803].
Panthangi V, West P, Savoy-Moore RT, et al. Is seasonal variation another risk factor for postpartum depression?. J Am Board Fam Med. 2009;22(5):492-7. [pmid: 19734394].
Patel RR, Murphy DJ, Peters TJ. Operative delivery and postnatal depression: a cohort study. BMJ. 2005;330(7496):879. [pmid: 15734748].
Paulson JF, Dauber S, Leiferman JA. Individual and combined effects of postpartum depression in mothers and fathers on parenting behavior. Pediatrics. 2006;118(2):659-68. [pmid: 16882821].
Paulson JF, Keefe HA, Leiferman JA. Early parental depression and child language development. J Child Psychol Psychiatry. 2009;50(3):254-62. [pmid: 19175819].
Pawar G, Wetzker C, Gjerdingen D. Prevalence of depressive symptoms in the immediate postpartum period. J Am Board Fam Med. 2011;24(3):258-61. [pmid: 21551397].
Pawlby S, Sharp D, Hay D, et al. Postnatal depression and child outcome at 11 years: the importance of accurate diagnosis. J Affect Disord. 2008;107(1–3):241-5. [pmid: 17854906].
Peindl KS, Wisner KL, Hanusa BH. Identifying depression in the first postpartum year: guidelines for office-based screening and referral. J Affect Disord. 2004;80(1):37-44. [pmid: 15094256].
Perren S, von Wyl A, Burgin D, et al. Depressive symptoms and psychosocial stress across the transition to parenthood: associations with parental psychopathology and child difficulty. J Psychosom Obstet Gynaecol. 2005;26(3):173-83. [pmid: 16295515].
Phillips J, Charles M, Sharpe L, et al. Validation of the subscales of the Edinburgh Postnatal Depression Scale in a sample of women with unsettled infants. J Affect Disord. 2009;118(1–3):101-12. [pmid: 19275960].
Phillips J, Sharpe L, Matthey S. Rates of depressive and anxiety disorders in a residential mother-infant unit for unsettled infants. Aust N Z J Psychiatry. 2007;41(10):836-42. [pmid: 17828657].
Phillips J, Sharpe L, Nemeth D. Maternal psychopathology and outcomes of a residential mother-infant intervention for unsettled infant behaviour. Aust N Z J Psychiatry. 2010;44(3):280-9. [pmid: 20180728].
Phillips J, Sharpe L, Matthey S, et al. Maternally focused worry. Arch Womens Ment Health. 2009;12(6):409-18. [pmid: 19626414].
Podolska MZ, Bidzan M, Majkowicz M, et al. Personality traits assessed by the NEO Five-Factor Inventory (NEO-FFI) as part of the perinatal depression screening program. Med Sci Monit. 2010;16(9):PH77-81. [pmid: 20802425].
Poehlmann J, Schwichtenberg AJ, Bolt D, et al. Predictors of depressive symptom trajectories in mothers of preterm or low birth weight infants. J Fam Psychol. 2009;23(5):690-704. [pmid: 19803605].
Price SK. Stepping back to gain perspective: pregnancy loss history, depression, and parenting capacity in the Early Childhood Longitudinal Study, Birth Cohort (ECLS-B). Death Stud. 2008;32(2):97-122. [pmid: 18693378].
Rambelli C, Montagnani MS, Oppo A, et al. Panic disorder as a risk factor for post-partum depression: Results from the Perinatal Depression-Research & Screening Unit (PND-ReScU) study. J Affect Disord. 2010;122(1–2):139-43. [pmid: 19651446].
Ramos-Marcuse F, Oberlander SE, Papas MA, et al. Stability of maternal depressive symptoms among urban, low-income, African American adolescent mothers. J Affect Disord. 2010;122(1–2):68-75. [pmid: 19615755].
Ravn IH, Smith L, Smeby NA, et al. Effects of early mother-infant intervention on outcomes in mothers and moderately and late preterm infants at age 1 year: A randomized controlled trial. Infant Behav Dev. 2012;35(1):36-47. [pmid: 22024475].
Reck C, Klier CM, Pabst K, et al. The German version of the Postpartum Bonding Instrument: psychometric properties and association with postpartum depression. Arch Womens Ment Health. 2006;9(5):265-71. [pmid: 16937316].
Reck C, Struben K, Backenstrass M, et al. Prevalence, onset and comorbidity of postpartum anxiety and depressive disorders. Acta Psychiatr Scand. 2008;118(6):459-68. [pmid: 18840256].
Records K, Rice MJ. Lifetime physical and sexual abuse and the risk for depression symptoms in the first 8 months after birth. J Psychosom Obstet Gynaecol. 2009;30(3):181-90. [pmid: 19728219].
Records K, Rice M, Beck CT. Psychometric assessment of the Postpartum Depression Predictors Inventory-Revised. J Nurs Meas. 2007;15(3):189-202. [pmid: 18232618].
Repokari L, Punamaki RL, Poikkeus P, et al. The impact of successful assisted reproduction treatment on female and male mental health during transition to parenthood: a prospective controlled study. Hum Reprod. 2005;20(11):3238-47. [pmid: 16037103].
Romito P, Pomicino L, Lucchetta C, et al. The relationships between physical violence, verbal abuse and women’s psychological distress during the postpartum period. J Psychosom Obstet Gynaecol. 2009;30(2):115-21. [pmid: 19533491].
Romito P, Turan JM, Neilands T, et al. Violence and women’s psychological distress after birth: an exploratory study in Italy. Health Care Women Int. 2009;30(1–2):160-80. [pmid: 19116827].
Ross LE, Sellers EM, Gilbert Evans SE, et al. Mood changes during pregnancy and the postpartum period: development of a biopsychosocial model. Acta Psychiatr Scand. 2004;109(6):457-66. [pmid: 15117291].
Rothenberger SE, Resch F, Doszpod N, et al. Prenatal stress and infant affective reactivity at five months of age. Early Hum Dev. 2011;87(2):129-36. [pmid: 21194854].
Rowe HJ, Fisher JR, Loh WM. The Edinburgh Postnatal Depression Scale detects but does not distinguish anxiety disorders from depression in mothers of infants. Arch Womens Ment Health. 2008;11(2):103-8. [pmid: 18463939].
Ryding EL, Wiren E, Johansson G, et al. Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. 2004;31(4):247-53. [pmid: 15566336].
Saisto T, Salmela-Aro K, Nurmi JE, et al. Longitudinal study on the predictors of parental stress in mothers and fathers of toddlers. J Psychosom Obstet Gynaecol. 2008;29(3):213-22. [pmid: 18608816].
Salonen AH, Kaunonen M, Astedt-Kurki P, et al. Parenting self-efficacy after childbirth. J Adv Nurs. 2009;65(11):2324-36. [pmid: 19761456].
Saurel-Cubizolles MJ, Romito P, Lelong N. Women’s psychological health according to their maternal status: a study in France. J Psychosom Obstet Gynaecol. 2007;28(4):243-9. [pmid: 17966051].
Savage J, Giarratano G, Bustamante-Forest R, et al. Post-Katrina perinatal mood and the use of alternative therapies. J Holist Nurs. 2010;28(2):123-32. quiz 133-5. [pmid: 20522707].
Scharfe E. Maternal Attachment Representations and Initiation and Duration of Breastfeeding. J Hum Lact. 2012;28(2):218-25. [pmid: 22253361].
Schytt E, Waldenstrom U. Risk factors for poor self-rated health in women at 2 months and 1 year after childbirth. J Womens Health (Larchmt). 2007;16(3):390-405. [pmid: 17439384].
Sheeder J, Kabir K, Stafford B. Screening for postpartum depression at well-child visits: is once enough during the first 6 months of life?. Pediatrics. 2009;123(6):e982-8. [pmid: 19482749].
Sidor A, Kunz E, Schweyer D, et al. Links between maternal postpartum depressive symptoms, maternal distress, infant gender and sensitivity in a high-risk population. Child Adolesc Psychiatry Ment Health. 2011;5(1):7. [pmid: 21385422].
Sjostrom H, Langius-Eklof A, Hjertberg R. Well-being and sense of coherence during pregnancy. Acta Obstet Gynecol Scand. 2004;83(12):1112-8. [pmid: 15548141].
Skalkidou A, Sylven SM, Papadopoulos FC, et al. Risk of postpartum depression in association with serum leptin and interleukin-6 levels at delivery: a nested case-control study within the UPPSAT cohort. Psychoneuroendocrinology. 2009;34(9):1329-37. [pmid: 19427131].
Smith DC, Munroe ML, Foglia LM, et al. Effects of deployment on depression screening scores in pregnancy at an army military treatment facility. Obstet Gynecol. 2010;116(3):679-84. [pmid: 20733452].
Solberg O, Dale MT, Holmstrom H, et al. Emotional reactivity in infants with congenital heart defects and maternal symptoms of postnatal depression. Arch Womens Ment Health. 2011;14(6):487-92. [pmid: 22020995].
Songoygard KM, Stafne SN, Evensen KA, et al. Does exercise during pregnancy prevent postnatal depression? A randomized controlled trial. Acta Obstet Gynecol Scand. 2012;91(1):62-7. [pmid: 21880023].
Stapleton LRT, Schetter CD, Westling E, et al. Perceived partner support in pregnancy predicts lower maternal and infant distress. Journal of Family Psychology. 2012;26(3):453-463. [pmid: 22662772].
Stein A, Malmberg LE, Sylva K, et al. The influence of maternal depression, caregiving, and socioeconomic status in the post-natal year on children’s language development. Child Care Health Dev. 2008;34(5):603-12. [pmid: 18549438].
Stewart DE, Gagnon A, Saucier JF, et al. Postpartum depression symptoms in newcomers. Can J Psychiatry. 2008;53(2):121-4. [pmid: 18357931].
Surkan PJ, Gottlieb BR, McCormick MC, et al. Impact of a Health Promotion Intervention on Maternal Depressive Symptoms at 15 months Postpartum. Matern Child Health J. 2012;16(1):139-48. [pmid: 21153759].
Swalm D, Brooks J, Doherty D, et al. Using the Edinburgh postnatal depression scale to screen for perinatal anxiety. Arch Womens Ment Health. 2010;13(6):515-22. [pmid: 20574749].
Taft AJ, Small R, Hegarty KL, et al. Mothers’ AdvocateS In the Community (MOSAIC)--non-professional mentor support to reduce intimate partner violence and depression in mothers: a cluster randomised trial in primary care. BMC Public Health. 2011;11:178. [pmid: 21429226].
Tammentie T, Tarkka MT, Astedt-Kurki P, et al. Family dynamics and postnatal depression. J Psychiatr Ment Health Nurs. 2004;11(2):141-9. [pmid: 15009488].
Tandon SD, Perry DF, Mendelson T, et al. Preventing perinatal depression in low-income home visiting clients: a randomized controlled trial. J Consult Clin Psychol. 2011;79(5):707-12. [pmid: 21806298].
Taylor A, Atkins R, Kumar R, et al. A new Mother-to-Infant Bonding Scale: links with early maternal mood. Arch Womens Ment Health. 2005;8(1):45-51. [pmid: 15868385].
Teissedre F, Chabrol H. Detecting women at risk for postnatal depression using the Edinburgh Postnatal Depression Scale at 2 to 3 days postpartum. Can J Psychiatry. 2004;49(1):51-4. [pmid: 14763678].
Tiwari A, Leung WC, Leung TW, et al. A randomised controlled trial of empowerment training for Chinese abused pregnant women in Hong Kong. BJOG. 2005;112(9):1249-56. [pmid: 16101604].
Tuohy A, McVey C. Subscales measuring symptoms of non-specific depression, anhedonia, and anxiety in the Edinburgh Postnatal Depression Scale. Br J Clin Psychol. 2008;47(Pt 2):153-69. [pmid: 17761026].
Walker LO, Im EO, Tyler DO. Maternal Health Needs and Interest in Screening for Depression and Health Behaviors During Pediatric Visits. J Pediatr Health Care. 2012. Jan. 10. [Epub ahead of print]. [pmid: 22240267].

## No Outcomes of Interest

Aasheim V, Waldenstrom U, Hjelmstedt A, et al. Associations between advanced maternal age and psychological distress in primiparous women, from early pregnancy to 18 months postpartum. BJOG. 2012;119(9):1108-16. [pmid: 22703587].
Abbott MW, Williams MM. Postnatal depressive symptoms among Pacific mothers in Auckland: prevalence and risk factors. Aust N Z J Psychiatry. 2006;40(3):230-8. [pmid: 16476150].
Affonso DD, De AK, Horowitz AJ, et al. An international study exploring levels of postpartum depressive symptomatology. J Psychosom Res. 2000;49(3):207-16. [pmid: 11110992].
Aguado J, Campbell A, Ascaso C, et al. Examining the Factor Structure and Discriminant Validity of the 12-Item General Health Questionnaire (GHQ-12) Among Spanish Postpartum Women. Assessment. 2010. Nov. 12. [Epub ahead of print]. [pmid: 21075958].
Akerjordet K, Severinsson E. Emotional intelligence, reactions and thoughts: part 2: a pilot study. Nurs Health Sci. 2009;11(3):213-20. [pmid: 19689628].
Al Dallal FH, Grant IN. Postnatal depression among bahraini women: Prevalence of symptoms and psychosocial risk factors ORIGINAL (NON-ENGLISH) TITLE Depression postnatale chez des femmes bahreinies: Prevalence des symptomes et des facteurs de risque psychosociaux. Eastern Mediterranean Health Journal. 2012;18(5):432-438. [pmid: 22764428].
Albacar G, Sans T, Martín-Santos R, et al. An association between plasma ferritin concentrations measured 48h after delivery and postpartum depression. Journal of Affective Disorders. 2011;131(1–3):136-142. [pmid: 21130499].
Alcorn KL, O’Donovan A, Patrick JC, et al. A prospective longitudinal study of the prevalence of post-traumatic stress disorder resulting from childbirth events. Psychol Med. 2010;40(11):1849-59. [pmid: 20059799].
Almeida CP, Cunha FF, Pires EP, et al. Common mental disorders in pregnancy in the context of interpartner violence. J Psychiatr Ment Health Nurs. 2012. Jun. 6. [Epub ahead of print]. [pmid: 22672493].
Anderson LN, Campbell MK, da Silva O, et al. Effect of maternal depression and anxiety on use of health services for infants. Can Fam Physician. 2008;54(12):1718-1719 e5. [pmid: 19074718].
Appleby L, Gregoire A, Platz C, et al. Screening women for high risk of postnatal depression. J Psychosom Res. 1994;38(6):539-45. [pmid: 7990062].
Appolonio KK, Fingerhut R. Postpartum depression in a military sample. Mil Med. 2008;173(11):1085-91. [pmid: 19055183].
Apter G, Devouche E, Gratier M, et al. What lies behind postnatal depression: is it only a mood disorder?. J Pers Disord. 2012;26(3):357-67. [pmid: 22686224].
Araya R, Hu X, Heron J, et al. Effects of stressful life events, maternal depression and 5-HTTLPR genotype on emotional symptoms in pre-adolescent children. Am J Med Genet B Neuropsychiatr Genet. 2009;150B(5):670-82. [pmid: 19016475].
Aubuchon-Endsley NL, Thomas DG, Kennedy TS, et al. Interactive relations among maternal depressive symptomatology, nutrition, and parenting. Women Health. 2012;52(3):197-213. [pmid: 22533896].
Austin MP, Hadzi-Pavlovic D, Leader L, et al. Maternal trait anxiety, depression and life event stress in pregnancy: relationships with infant temperament. Early Hum Dev. 2005;81(2):183-90. [pmid: 15748973].
Austin MP, Tully L, Parker G. Examining the relationship between antenatal anxiety and postnatal depression. J Affect Disord. 2007;101(1–3):169-74. [pmid: 17196663].
Azorin J-M, Angst J, Gamma A, et al. Identifying features of bipolarity in patients with first-episode postpartum depression: Findings from the international BRIDGE study. Journal of Affective Disorders. 2012;136(3):710-715. [pmid: 22044629].
Bacchus L, Mezey G, Bewley S. Domestic violence: prevalence in pregnant women and associations with physical and psychological health. Eur J Obstet Gynecol Reprod Biol. 2004;113(1):6-11. [pmid: 15036702].
Bae HS, Kim SY, Ahnv HS, et al. Comparison of nutrient intake, life style variables, and pregnancy outcomes by the depression degree of pregnant women. Nutr Res Pract. 2010;4(4):323-31. [pmid: 20827349].
Baker L, Oswalt K. Screening for postpartum depression in a rural community. Community Ment Health J. 2008;44(3):171-80. [pmid: 18049894].
Baker L, Cross S, Greaver L, et al. Prevalence of postpartum depression in a native American population. Matern Child Health J. 2005;9(1):21-5. [pmid: 15880971].
Banti S, Mauri M, Oppo A, et al. From the third month of pregnancy to 1 year postpartum. Prevalence, incidence, recurrence, and new onset of depression. Results from the perinatal depression-research & screening unit study. Compr Psychiatry. 2011;52(4):343-51. [pmid: 21683171].
Barbadoro P, Cotichelli G, Chiatti C, et al. Socio-economic determinants and self-reported depressive symptoms during postpartum period. Women Health. 2012;52(4):352-68. [pmid: 22591232].
Barker ED, Maughan B. Differentiating early-onset persistent versus childhood-limited conduct problem youth. Am J Psychiatry. 2009;166(8):900-8. [pmid: 19570930].
Barnet B, Liu J, Devoe M. Double jeopardy: depressive symptoms and rapid subsequent pregnancy in adolescent mothers. Arch Pediatr Adolesc Med. 2008;162(3):246-52. [pmid: 18316662].
Barnet B, Liu J, DeVoe M, et al. Home visiting for adolescent mothers: effects on parenting, maternal life course, and primary care linkage. Ann Fam Med. 2007;5(3):224-32. [pmid: 17548850].
Battle CL, Zlotnick C, Miller IW, et al. Clinical characteristics of perinatal psychiatric patients: a chart review study. J Nerv Ment Dis. 2006;194(5):369-77. [pmid: 16699387].
Beck CT, Gable RK. Postpartum Depression Screening Scale: development and psychometric testing. Nurs Res. 2000;49(5):272-82. [pmid: 11009122].
Beck CT, Gable RK, Sakala C, et al. Posttraumatic stress disorder in new mothers: results from a two-stage U.S. national survey. Birth. 2011;38(3):216-27. [pmid: 21884230].
Beck CT, Records K, Rice M. Further development of the Postpartum Depression Predictors Inventory-Revised. J Obstet Gynecol Neonatal Nurs. 2006;35(6):735-45. [pmid: 17105638].
Beebe B, Jaffe J, Buck K, et al. Six-week postpartum maternal depression symptoms and 4-month mother-infant self- and interactive contingency. Infant Mental Health Journal. 2008;29(5):442-471.
Beeghly M, Olson KL, Weinberg MK, et al. Prevalence, stability, and socio-demographic correlates of depressive symptoms in Black mothers during the first 18 months postpartum. Matern Child Health J. 2003;7(3):157-68. [pmid: 14509411].
Beeghly M, Weinberg MK, Olson KL, et al. Stability and change in level of maternal depressive symptomatology during the first postpartum year. J Affect Disord. 2002;71(1–3):169-80. [pmid: 12167513].
Bener A, Gerber LM, Sheikh J. Prevalence of psychiatric disorders and associated risk factors in women during their postpartum period: a major public health problem and global comparison. Int J Womens Health. 2012;4:191-200. [pmid: 22654524].
Bennett IM, Coco A, Coyne JC, et al. Efficiency of a two-item pre-screen to reduce the burden of depression screening in pregnancy and postpartum: an IMPLICIT network study. J Am Board Fam Med. 2008;21(4):317-25. [pmid: 18612058].
Bentley SM, Melville JL, Berry BD, et al. Implementing a clinical and research registry in obstetrics: overcoming the barriers. Gen Hosp Psychiatry. 2007;29(3):192-8. [pmid: 17484935].
Benvenuti P, Ferrara M, Niccolai C, et al. The Edinburgh Postnatal Depression Scale: validation for an Italian sample. J Affect Disord. 1999;53(2):137-41. [pmid: 10360408].
Bernazzani O, Conroy S, Marks MN, et al. Contextual Assessment of the Maternity Experience: development of an instrument for cross-cultural research. Br J Psychiatry Suppl. 2004;46:s24-30. [pmid: 14754815].
Bernazzani O, Marks MN, Bifulco A, et al. Assessing psychosocial risk in pregnant/postpartum women using the Contextual Assessment of Maternity Experience (CAME)--recent life adversity, social support and maternal feelings. Soc Psychiatry Psychiatr Epidemiol. 2005;40(6):497-508. [pmid: 16003600].
Beydoun HA, Al-Sahab B, Beydoun MA, et al. Intimate partner violence as a risk factor for postpartum depression among Canadian women in the Maternity Experience Survey. Ann Epidemiol. 2010;20(8):575-83. [pmid: 20609336].
Bielinski-Blattmann D, Lemola S, Jaussi C, et al. Postpartum depressive symptoms in the first 17 months after childbirth: the impact of an emotionally supportive partnership. Int J Public Health. 2009;54(5):333-9. [pmid: 19636511].
Biesmans K, Franck E, Ceulemans C, et al. Weight During the Postpartum Period: What Can Health Care Workers Do?. Matern Child Health J. 2012. Jul. 15. [Epub ahead of print]. [pmid: 22798141].
Bijlenga D, Boers KE, Birnie E, et al. Maternal health-related quality of life after induction of labor or expectant monitoring in pregnancy complicated by intrauterine growth retardation beyond 36 weeks. Qual Life Res. 2011;20(9):1427-36. [pmid: 21468753].
Bijlenga D, Koopmans CM, Birnie E, et al. Health-related quality of life after induction of labor versus expectant monitoring in gestational hypertension or preeclampsia at term. Hypertens Pregnancy. 2011;30(3):260-74. [pmid: 21740249].
Bilszta JL, Gu YZ, Meyer D, et al. A geographic comparison of the prevalence and risk factors for postnatal depression in an Australian population. Aust N Z J Public Health. 2008;32(5):424-30. [pmid: 18959545].
Birmingham MC, Chou KJ, Crain EF. Screening for postpartum depression in a pediatric emergency department. Pediatr Emerg Care. 2011;27(9):795-800. [pmid: 21878826].
Bland M. The influence of birth experience on postpartum depression. Midwifery Today Int Midwife. Spring. 2009;(89):20-1. 65. 6. [pmid: 19397148].
Bloch M, Rotenberg N, Koren D, et al. Risk factors for early postpartum depressive symptoms. Gen Hosp Psychiatry. 2006;28(1):3-8. [pmid: 16377359].
Blom EA, Jansen PW, Verhulst FC, et al. Perinatal complications increase the risk of postpartum depression. The Generation R Study BJOG. 2010;117(11):1390-8. [pmid: 20682022].
Bodecs T, Horvath B, Szilagyi E, et al. Effects of depression, anxiety, self-esteem, and health behaviour on neonatal outcomes in a population-based Hungarian sample. Eur J Obstet Gynecol Reprod Biol. 2011;154(1):45-50. [pmid: 20884107].
Bodecs T, Mate O, Horvath B, et al. Barriers of antenatal folate-supplementation: The role of depression and trait-anxiety on periconceptional folate-intake. International Journal of Psychiatry in Clinical Practice. 2010;14(2):102-108.
Boothe AS, Brouwer RJ, Carter-Edwards L, et al. Unmet social support for healthy behaviors among overweight and obese postpartum women: results from the Active Mothers Postpartum Study. J Womens Health (Larchmt). 2011;20(11):1677-85. [pmid: 21916619].
Bowen A, Bowen R, Butt P, et al. Patterns of depression and treatment in pregnant and postpartum women. Can J Psychiatry. 2012;57(3):161-7. [pmid: 22398002].
Brand SR, Brennan PA, Newport DJ, et al. The impact of maternal childhood abuse on maternal and infant HPA axis function in the postpartum period. Psychoneuroendocrinology. 2010;35(5):686-93. [pmid: 19931984].
Breitkopf CR, Primeau LA, Levine RE, et al. Anxiety symptoms during pregnancy and postpartum. J Psychosom Obstet Gynaecol. 2006;27(3):157-62. [pmid: 17214450].
Britton JR. Global satisfaction with perinatal hospital care: stability and relationship to anxiety, depression, and stressful medical events. Am J Med Qual. 2006;21(3):200-5. [pmid: 16679440].
Britton JR. Infant temperament and maternal anxiety and depressed mood in the early postpartum period. Women Health. 2011;51(1):55-71. [pmid: 21391161].
Brooks J, Nathan E, Speelman C, et al. Tailoring screening protocols for perinatal depression: prevalence of high risk across obstetric services in Western Australia. Arch Womens Ment Health. 2009;12(2):105-12. [pmid: 19221864].
Brown JD, Harris SK, Woods ER, et al. Longitudinal study of depressive symptoms and social support in adolescent mothers. Maternal and Child Health Journal. 2012;16(4):894-901. [pmid: 21556696].
Brown SJ, Lumley JM, McDonald EA, et al. Maternal health study: a prospective cohort study of nulliparous women recruited in early pregnancy. BMC Pregnancy Childbirth. 2006;6:12. [pmid: 16608507].
Brown VB, Melchior LA. Women with co-occurring disorders (COD): treatment settings and service needs. J Psychoactive Drugs. 2008;(Suppl 5):365-76. [pmid: 19248394].
Brugha TS, Morrell CJ, Slade P, et al. Universal prevention of depression in women postnatally: cluster randomized trial evidence in primary care. Psychol Med. 2011;41(4):739-48. [pmid: 20716383].
Buist A, Bilszta J, Barnett B, et al. Recognition and management of perinatal depression in general practice--a survey of GPs and postnatal women. Aust Fam Physician. 2005;34(9):787-90. [pmid: 16184215].
Buist A, Condon J, Brooks J, et al. Acceptability of routine screening for perinatal depression. J Affect Disord. 2006;93(1–3):233-7. [pmid: 16647761].
Buist A, Ellwood D, Brooks J, et al. National program for depression associated with childbirth: the Australian experience. Best Pract Res Clin Obstet Gynaecol. 2007;21(2):193-206. [pmid: 17175198].
Buist A, Speelman C, Hayes B, et al. Impact of education on women with perinatal depression. J Psychosom Obstet Gynaecol. 2007;28(1):49-54. [pmid: 17454513].
Buist AE, Austin MP, Hayes BA, et al. Postnatal mental health of women giving birth in Australia 2002–2004 findings from the beyondblue National Postnatal Depression Program. Aust N Z J Psychiatry. 2008;42(1):66-73. [pmid: 18058446].
Cacciatore J, Schnebly S, Froen JF. The effects of social support on maternal anxiety and depression after stillbirth. Health Soc Care Community. 2009;17(2):167-76. [pmid: 19281517].
Campbell A, Hayes B, Buckby B. Aboriginal and Torres Strait Islander women’s experience when interacting with the Edinburgh Postnatal Depression Scale: a brief note. Aust J Rural Health. 2008;16(3):124-31. [pmid: 18471181].
Carty EM, Bradley CF. A randomized, controlled evaluation of early postpartum hospital discharge. Birth. 1990;17(4):199-204. [pmid: 2285437].
Carvalho Bos S, Pereira AT, Marques M, et al. The BDI-II factor structure in pregnancy and postpartum: Two or three factors?. Eur Psychiatry. 2009;24(5):334-40. [pmid: 19091525].
Certain HE, Mueller M, Jagodzinski T, et al. Domestic abuse during the previous year in a sample of postpartum women. J Obstet Gynecol Neonatal Nurs. 2008;37(1):35-41. [pmid: 18226155].
Chabrol H, Teissedre F. Relation between Edinburgh Postnatal Depression Scale scores at 2–3 days and 4–6 weeks postpartum. Journal of Reproductive and Infant Psychology. 2004;22(1):33-39.
Chae HJ, Song JE, Kim S. Predictors of maternal identity of Korean primiparas. J Korean Acad Nurs. 2011;41(6):733-41. [pmid: 22310857].
Chase SK, Beatty JR, Ondersma SJ. A randomized trial of the effects of anonymity and quasi anonymity on disclosure of child maltreatment-related outcomes among postpartum women. Child Maltreat. 2011;16(1):33-40. [pmid: 21131632].
Chatzi L, Melaki V, Sarri K, et al. Dietary patterns during pregnancy and the risk of postpartum depression: the mother-child ‘Rhea’ cohort in Crete, Greece. Public Health Nutr. 2011;14(9):1663-70. [pmid: 21477412].
Chaudron LH, Kitzman HJ, Peifer KL, et al. Prevalence of maternal depressive symptoms in low-income Hispanic women. J Clin Psychiatry. 2005;66(4):418-23. [pmid: 15816782].
Chaudron LH, Kitzman HJ, Peifer KL, et al. Self-recognition of and provider response to maternal depressive symptoms in low-income Hispanic women. J Womens Health (Larchmt). 2005;14(4):331-8. [pmid: 15916507].
Chaudron LH, Szilagyi PG, Kitzman HJ, et al. Detection of postpartum depressive symptoms by screening at well-child visits. Pediatrics. 2004;113(3 Pt 1):551-8. [pmid: 14993549].
Chen H, Chan YH, Tan KH, et al. Depressive symptomatology in pregnancy - a Singaporean perspective. Soc Psychiatry Psychiatr Epidemiol. 2004;39(12):975-9. [pmid: 15583905].
Chien LY, Tai CJ, Yeh MC. Domestic decision-making power, social support, and postpartum depression symptoms among immigrant and native women in Taiwan. Nurs Res. 2012;61(2):103-10. [pmid: 22307142].
Chittleborough CR, Lawlor DA, Lynch JW. Prenatal prediction of poor maternal and offspring outcomes: Implications for selection into intensive parent support programs. Maternal and Child Health Journal. 2012;16(4):909-920. [pmid: 21573859].
Cho J, Holditch-Davis D, Miles MS. Effects of maternal depressive symptoms and infant gender on the interactions between mothers and their medically at-risk infants. Journal of Obstetric, Gynecologic, & Neonatal Nursing: Clinical Scholarship for the Care of Women, Childbearing Families, & Newborns. 2008;37(1):58-70.
Cho YJ, Han JY, Choi JS, et al. Prenatal multivitamins containing folic acid do not decrease prevalence of depression among pregnant women. J Obstet Gynaecol. 2008;28(5):482-4. [pmid: 18850419].
Choi H, Yamashita T, Wada Y, et al. Factors associated with postpartum depression and abusive behavior in mothers with infants. Psychiatry Clin Neurosci. 2010;64(2):120-7. [pmid: 20132523].
Choi SK, Kim JJ, Park YG, et al. The Simplified Edinburgh Postnatal Depression Scale (EPDS) for Antenatal Depression: Is It a Valid Measure for Pre-Screening?. Int J Med Sci. 2012;9(1):40-6. [pmid: 22211088].
Choi Y, Bishai D, Minkovitz CS. Multiple births are a risk factor for postpartum maternal depressive symptoms. Pediatrics. 2009;123(4):1147-54. [pmid: 19336374].
Christensen AL, Perry DF, Le HN, et al. Correlates of unintended birth among low-income Hispanic immigrants at high risk for depression. J Immigr Minor Health. 2011;13(3):478-86. [pmid: 21240558].
Christensen AL, Stuart EA, Perry DF, et al. Unintended pregnancy and perinatal depression trajectories in low-income, high-risk Hispanic immigrants. Prev Sci. 2011;12(3):289-99. [pmid: 21537899].
Christie J, Bunting B. The effect of health visitors’ postpartum home visit frequency on first-time mothers: cluster randomised trial. Int J Nurs Stud. 2011;48(6):689-702. [pmid: 21129744].
Chung EK, McCollum KF, Elo IT, et al. Maternal depressive symptoms and infant health practices among low-income women. Pediatrics. 2004;113(6):e523-9. [pmid: 15173532].
Church NF, Brechman-Toussaint ML, Hine DW. Do dysfunctional cognitions mediate the relationship between risk factors and postnatal depression symptomatology?. J Affect Disord. 2005;87(1):65-72. [pmid: 15922455].
Cigoli V, Gilli G, Saita E. Relational factors in psychopathological responses to childbirth. J Psychosom Obstet Gynaecol. 2006;27(2):91-7. [pmid: 16808083].
Claesson IM, Josefsson A, Sydsjo G. Prevalence of anxiety and depressive symptoms among obese pregnant and postpartum women: an intervention study. BMC Public Health. 2010;10:766. [pmid: 21162715].
Clark A, Skouteris H, Wertheim EH, et al. The relationship between depression and body dissatisfaction across pregnancy and the postpartum: a prospective study. J Health Psychol. 2009;14(1):27-35. [pmid: 19129334].
Clemmens D, Driscoll JW, Beck CT. Postpartum depression as profiled through the depression screening scale. MCN Am J Matern Child Nurs. 2004;29(3):180-5. [pmid: 15123975].
Coates AO, Schaefer CA, Alexander JL. Detection of postpartum depression and anxiety in a large health plan. J Behav Health Serv Res. 2004;31(2):117-33. [pmid: 15255221].
Coelho HF, Murray L, Royal-Lawson M, et al. Antenatal anxiety disorder as a predictor of postnatal depression: a longitudinal study. J Affect Disord. 2011;129(1–3):348-53. [pmid: 20805004].
Comasco E, Sylven SM, Papadopoulos FC, et al. Postpartum depression symptoms: a case-control study on monoaminergic functional polymorphisms and environmental stressors. Psychiatr Genet. 2011;21(1):19-28. [pmid: 21099450].
Comasco E, Sylven SM, Papadopoulos FC, et al. Postpartum depressive symptoms and the BDNF Val66Met functional polymorphism: effect of season of delivery. Arch Womens Ment Health. 2011;14(6):453-63. [pmid: 21997575].
Conde A, Figueiredo B, Bifulco A. Attachment style and psychological adjustment in couples. Attach Hum Dev. 2011;13(3):271-91. [pmid: 21506031].
Condon JT, Corkindale CJ. The assessment of depression in the postnatal period: a comparison of four self-report questionnaires. Aust N Z J Psychiatry. 1997;31(3):353-9. [pmid: 9226080].
Cooke M, Schmied V, Sheehan A. An exploration of the relationship between postnatal distress and maternal role attainment, breast feeding problems and breast feeding cessation in Australia. Midwifery. 2007;23(1):66-76. [pmid: 17011682].
Cornish AM, McMahon CA, Ungerer JA, et al. Maternal depression and the experience of parenting in the second postnatal year. Journal of Reproductive and Infant Psychology. 2006;24(2):121-132.
Cornish AM, McMahon CA, Ungerer JA, et al. Postnatal depression and infant cognitive and motor development in the second postnatal year: The impact of depression chronicity and infant gender. Infant Behavior & Development. 2005;28(4):407-417.
Costas J, Gratacos M, Escaramis G, et al. Association study of 44 candidate genes with depressive and anxiety symptoms in post-partum women. J Psychiatr Res. 2010;44(11):717-24. [pmid: 20092830].
Cowley-Malcolm ET, Fairbairn-Dunlop TP, Paterson J, et al. Child discipline and nurturing practices among a cohort of Pacific mothers living in New Zealand. Pac Health Dialog. 2009;15(1):36-45. [pmid: 19585733].
Cox JE, Buman M, Valenzuela J, et al. Depression, parenting attributes, and social support among adolescent mothers attending a teen tot program. J Pediatr Adolesc Gynecol. 2008;21(5):275-81. [pmid: 18794023].
Csatordai S, Kozinszky Z, Devosa I, et al. Obstetric and sociodemographic risk of vulnerability to postnatal depression. Patient Educ Couns. 2007;67(1–2):84-92. [pmid: 17379470].
Curro V, De Rosa E, Maulucci S, et al. The use of Edinburgh Postnatal Depression Scale to identify postnatal depression symptoms at well child visit. Ital J Pediatr. 2009;35(1):32. [pmid: 19863812].
Dagher RK, Shenassa ED. Prenatal health behaviors and postpartum depression: is there an association?. Arch Womens Ment Health. 2012;15(1):31-7. [pmid: 22215286].
Dagher RK, McGovern PM, Alexander BH, et al. The psychosocial work environment and maternal postpartum depression. Int J Behav Med. 2009;16(4):339-46. [pmid: 19288209].
Dagher RK, McGovern PM, Dowd BE, et al. Postpartum Depression and Health Services Expenditures Among Employed Women. J Occup Environ Med. 2012;54(2):210-5. [pmid: 22267187].
Dagher RK, McGovern PM, Dowd BE, et al. Postpartum depressive symptoms and the combined load of paid and unpaid work: a longitudinal analysis. Int Arch Occup Environ Health. 2011;84(7):735-43. [pmid: 21373878].
Dailey DE, Humphreys JC. Social stressors associated with antepartum depressive symptoms in low-income African American women. Public Health Nurs. 2011;28(3):203-12. [pmid: 21535105].
D’Amelio R, Rauccio V, Melluso J, et al. Is it possible to predict postnatal depression? Research into the origin of blues and depression. The role of the gynaecologist. Clin Exp Obstet Gynecol. 2006;33(3):151-3. [pmid: 17089578].
Davey HL, Tough SC, Adair CE, et al. Risk factors for sub-clinical and major postpartum depression among a community cohort of Canadian women. Matern Child Health J. 2011;15(7):866-75. [pmid: 18256913].
Davila M, McFall SL, Cheng D. Acculturation and depressive symptoms among pregnant and postpartum Latinas. Matern Child Health J. 2009;13(3):318-25. [pmid: 18636323].
Davis S, Cross J, Lind BK. Exploring the Postpartum Adjustment Questionnaire as a predictor of postpartum depression. J Obstet Gynecol Neonatal Nurs. 2008;37(6):622-30. [pmid: 19012712].
Dayan J, Creveuil C, Dreyfus M, et al. Developmental model of depression applied to prenatal depression: role of present and past life events, past emotional disorders and pregnancy stress. PLoS One. 2010;5(9):e12942. [pmid: 20877652].
Dayan J, Creveuil C, Marks MN, et al. Prenatal depression, prenatal anxiety, and spontaneous preterm birth: a prospective cohort study among women with early and regular care. Psychosom Med. 2006;68(6):938-46. [pmid: 17079701].
de Alencar AE, Arraes LC, de Albuquerque EC, et al. Effect of kangaroo mother care on postpartum depression. J Trop Pediatr. 2009;55(1):36-8. [pmid: 19066171].
De Magistris A, Coni E, Puddu M, et al. Screening of postpartum depression: comparison between mothers in the neonatal intensive care unit and in the neonatal section. J Matern Fetal Neonatal Med. 2010;23(Suppl 3):101-3. [pmid: 20807154].
de Paz NC, Sanchez SE, Huaman LE, et al. Risk of placental abruption in relation to maternal depressive, anxiety and stress symptoms. J Affect Disord. 2011;130(1–2):280-4. [pmid: 20692040].
de Tychey C, Briancon S, Lighezzolo J, et al. Quality of life, postnatal depression and baby gender. J Clin Nurs. 2008;17(3):312-22. [pmid: 17931379].
de Tychey C, Spitz E, Briancon S, et al. Pre- and postnatal depression and coping: a comparative approach. J Affect Disord. 2005;85(3):323-6. [pmid: 15780702].
Demissie Z, Siega-Riz AM, Evenson KR, et al. Associations between physical activity and postpartum depressive symptoms. J Womens Health (Larchmt). 2011;20(7):1025-34. [pmid: 21668353].
Demissie Z, Siega-Riz AM, Evenson KR, et al. Physical activity and depressive symptoms among pregnant women: the PIN3 study. Arch Womens Ment Health. 2011;14(2):145-57. [pmid: 21107623].
Dennis CL, Letourneau N. Global and relationship-specific perceptions of support and the development of postpartum depressive symptomatology. Soc Psychiatry Psychiatr Epidemiol. 2007;42(5):389-95. [pmid: 17396205].
Dennis CL, McQueen K. Does maternal postpartum depressive symptomatology influence infant feeding outcomes?. Acta Paediatr. 2007;96(4):590-4. [pmid: 17391475].
Dennis CL, Ross L. Relationships among infant sleep patterns, maternal fatigue, and development of depressive symptomatology. Birth. 2005;32(3):187-93. [pmid: 16128972].
Dennis CL, Ross L. Women’s perceptions of partner support and conflict in the development of postpartum depressive symptoms. J Adv Nurs. 2006;56(6):588-99. [pmid: 17118038].
Dennis CL, Ross LE. Depressive symptomatology in the immediate postnatal period: identifying maternal characteristics related to true- and false-positive screening scores. Can J Psychiatry. 2006;51(5):265-73. [pmid: 16986815].
Dennis CL, Ross LE. The clinical utility of maternal self-reported personal and familial psychiatric history in identifying women at risk for postpartum depression. Acta Obstet Gynecol Scand. 2006;85(10):1179-85. [pmid: 17068676].
Dennis CL, Janssen PA, Singer J. Identifying women at-risk for postpartum depression in the immediate postpartum period. Acta Psychiatr Scand. 2004;110(5):338-46. [pmid: 15458557].
Dennis CL. Can we identify mothers at risk for postpartum depression in the immediate postpartum period using the Edinburgh Postnatal Depression Scale?. J Affect Disord. 2004;78(2):163-9. [pmid: 14706728].
Dennis CL. Influence of depressive symptomatology on maternal health service utilization and general health. Arch Womens Ment Health. 2004;7(3):183-91. [pmid: 15241664].
Dennis CL. Postpartum depression peer support: maternal perceptions from a randomized controlled trial. Int J Nurs Stud. 2010;47(5):560-8. [pmid: 19962699].
Dennis CL. The effect of peer support on postpartum depression: a pilot randomized controlled trial. Can J Psychiatry. 2003;48(2):115-24. [pmid: 12655910].
Dipietro JA, Costigan KA, Sipsma HL. Continuity in self-report measures of maternal anxiety, stress, and depressive symptoms from pregnancy through two years postpartum. J Psychosom Obstet Gynaecol. 2008;29(2):115-24. [pmid: 18655259].
Donnot J, Vauclair J, Brejard V. Newborn right-holding is related to depressive symptoms in bottle-feeding mothers but not in breastfeeding mothers. Infant Behav Dev. 2008;31(3):352-60. [pmid: 18279969].
Doornbos B, van Goor SA, Dijck-Brouwer DA, et al. Supplementation of a low dose of DHA or DHA+AA does not prevent peripartum depressive symptoms in a small population based sample. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(1):49-52. [pmid: 18955102].
Dorheim SK, Bondevik GT, Eberhard-Gran M, et al. Sleep and depression in postpartum women: a population-based study. Sleep. 2009;32(7):847-55. [pmid: 19639747].
Drewett R, Blair P, Emmett P, et al. Failure to thrive in the term and preterm infants of mothers depressed in the postnatal period: a population-based birth cohort study. J Child Psychol Psychiatry. 2004;45(2):359-66. [pmid: 14982248].
Dubowitz H, Feigelman S, Lane W, et al. Screening for depression in an urban pediatric primary care clinic. Pediatrics. 2007;119(3):435-43. [pmid: 17332195].
Dudas RB, Csatordai S, Devosa I, et al. Obstetric and psychosocial risk factors for depressive symptoms during pregnancy. Psychiatry Res. 2012. May. 11. [Epub ahead of print]. [pmid: 22578932].
Dunn S, Davies B, McCleary L, et al. The relationship between vulnerability factors and breastfeeding outcome. J Obstet Gynecol Neonatal Nurs. 2006;35(1):87-97. [pmid: 16466356].
Eastwood JG, Phung H, Barnett B. Postnatal depression and socio-demographic risk: factors associated with Edinburgh Depression Scale scores in a metropolitan area of New South Wales, Australia. Aust N Z J Psychiatry. 2011;45(12):1040-6. [pmid: 22017687].
Eberhard-Gran M, Eskild A, Samuelsen SO, et al. A short matrix-version of the Edinburgh Depression Scale. Acta Psychiatr Scand. 2007;116(3):195-200. [pmid: 17655561].
Eberhard-Gran M, Tambs K, Opjordsmoen S, et al. Depression during pregnancy and after delivery: a repeated measurement study. J Psychosom Obstet Gynaecol. 2004;25(1):15-21. [pmid: 15376401].
Edge D, Baker D, Rogers A. Perinatal depression among black Caribbean women. Health Soc Care Community. 2004;12(5):430-8. [pmid: 15373822].
Edge D. Ethnicity, psychosocial risk, and perinatal depression--a comparative study among inner-city women in the United Kingdom. J Psychosom Res. 2007;63(3):291-5. [pmid: 17719367].
Edhborg M, Matthiesen AS, Lundh W, et al. Some early indicators for depressive symptoms and bonding 2 months postpartum--a study of new mothers and fathers. Arch Womens Ment Health. 2005;8(4):221-31. [pmid: 16172838].
Edhborg M. Comparisons of different instruments to measure blues and to predict depressive symptoms 2 months postpartum: a study of new mothers and fathers. Scand J Caring Sci. 2008;22(2):186-95. [pmid: 18489688].
Edwards B, Galletly C, Semmler-Booth T, et al. Antenatal psychosocial risk factors and depression among women living in socioeconomically disadvantaged suburbs in Adelaide, South Australia. Aust N Z J Psychiatry. 2008;42(1):45-50. [pmid: 18058443].
Edwards B, Galletly C, Semmler-Booth T, et al. Does antenatal screening for psychosocial risk factors predict postnatal depression? A follow-up study of 154 women in Adelaide, South Australia. Aust N Z J Psychiatry. 2008;42(1):51-5. [pmid: 18058444].
Ehrlich M, Harville E, Xiong X, et al. Loss of resources and hurricane experience as predictors of postpartum depression among women in southern Louisiana. J Womens Health (Larchmt). 2010;19(5):877-84. [pmid: 20438305].
Eilat-Tsanani S, Merom A, Romano S, et al. The effect of postpartum depression on women’s consultations with physicians. Isr Med Assoc J. 2006;8(6):406-10. [pmid: 16833170].
Eisenach JC, Pan PH, Smiley R, et al. Severity of acute pain after childbirth, but not type of delivery, predicts persistent pain and postpartum depression. Pain. 2008;140(1):87-94. [pmid: 18818022].
Elsenbruch S, Benson S, Rucke M, et al. Social support during pregnancy: effects on maternal depressive symptoms, smoking and pregnancy outcome. Hum Reprod. 2007;22(3):869-77. [pmid: 17110400].
Emmanuel EN, Creedy DK, St John W, et al. Maternal role development: the impact of maternal distress and social support following childbirth. Midwifery. 2011;27(2):265-72. [pmid: 19656594].
Ersek JL, Brunner Huber LR. Physical activity prior to and during pregnancy and risk of postpartum depressive symptoms. J Obstet Gynecol Neonatal Nurs. 2009;38(5):556-66. [pmid: 19883477].
Ertel KA, Koenen KC, Rich-Edwards JW, et al. Antenatal and postpartum depressive symptoms are differentially associated with early childhood weight and adiposity. Paediatr Perinat Epidemiol. 2010;24(2):179-89. [pmid: 20415775].
Ertel KA, Koenen KC, Rich-Edwards JW, et al. Maternal depressive symptoms not associated with reduced height in young children in a US prospective cohort study. PLoS One. 2010;5(10):e13656. [pmid: 21048958].
Escriba-Aguir V, Artazcoz L. Gender differences in postpartum depression: a longitudinal cohort study. J Epidemiol Community Health. 2011;65(4):320-6. [pmid: 20515899].
Evans J, Heron J, Lewis G, et al. Negative self-schemas and the onset of depression in women: longitudinal study. Br J Psychiatry. 2005;186:302-7. [pmid: 15802686].
Evans J, Melotti R, Heron J, et al. The timing of maternal depressive symptoms and child cognitive development: a longitudinal study. J Child Psychol Psychiatry. 2011;53(6):632-40. [pmid: 22211468].
Fairbrother N, Woody SR. Fear of childbirth and obstetrical events as predictors of postnatal symptoms of depression and post-traumatic stress disorder. J Psychosom Obstet Gynaecol. 2007;28(4):239-42. [pmid: 17966050].
Feldman R, Granat A, Pariente C, et al. Maternal depression and anxiety across the postpartum year and infant social engagement, fear regulation, and stress reactivity. J Am Acad Child Adolesc Psychiatry. 2009;48(9):919-27. [pmid: 19625979].
Felice E, Saliba J, Grech V, et al. Antenatal psychiatric morbidity in Maltese women. Gen Hosp Psychiatry. 2007;29(6):501-5. [pmid: 18022043].
Field T, Diego M, Hernandez-Reif M, et al. Depressed pregnant black women have a greater incidence of prematurity and low birthweight outcomes. Infant Behav Dev. 2009;32(1):10-6. [pmid: 19004502].
Figueiredo B, Conde A. Anxiety and depression in women and men from early pregnancy to 3-months postpartum. Arch Womens Ment Health. 2011;14(3):247-55. [pmid: 21479759].
Figueiredo B, Conde A. Anxiety and depression symptoms in women and men from early pregnancy to 3-months postpartum: parity differences and effects. J Affect Disord. 2011;132(1–2):146-57. [pmid: 21420178].
Figueiredo B, Pacheco A, Costa R. Depression during pregnancy and the postpartum period in adolescent and adult Portuguese mothers. Arch Womens Ment Health. 2007;10(3):103-9. [pmid: 17510776].
Figueiredo B, Pacheco A, Costa R, et al. Mother’s anxiety and depression during the third pregnancy trimester and neonate’s mother versus stranger’s face/voice visual preference. Early Hum Dev. 2010;86(8):479-85. [pmid: 20663619].
Fisher JR, Hammarberg K, Baker HW. Assisted conception is a risk factor for postnatal mood disturbance and early parenting difficulties. Fertil Steril. 2005;84(2):426-30. [pmid: 16084885].
Fisher SD, Kopelman R, O’Hara MW. Partner report of paternal depression using the Edinburgh Postnatal Depression Scale-Partner. Arch Womens Ment Health. 2012;15(4):283-8. [pmid: 22648681].
Flach C, Leese M, Heron J, et al. Antenatal domestic violence, maternal mental health and subsequent child behaviour: a cohort study. BJOG. 2011;118(11):1383-91. [pmid: 21692968].
Fleming AS, Klein E, Corter C. The effects of a social support group on depression, maternal attitudes and behavior in new mothers. J Child Psychol Psychiatry. 1992;33(4):685-98. [pmid: 1601943].
Freeman MP, Wright R, Watchman M, et al. Postpartum depression assessments at well-baby visits: screening feasibility, prevalence, and risk factors. J Womens Health (Larchmt). 2005;14(10):929-35. [pmid: 16372894].
Friedman DD, Beebe B, Jaffe J, et al. Microanalysis of 4-month infant vocal affect qualities and maternal postpartum depression. Clinical Social Work Journal. 2010;38(1):8-16.
Fujita M, Endoh Y, Saimon N, et al. Effect of massaging babies on mothers: pilot study on the changes in mood states and salivary cortisol level. Complement Ther Clin Pract. 2006;12(3):181-5. [pmid: 16835028].
Gagliardi L, Petrozzi A, Rusconi F. Symptoms of maternal depression immediately after delivery predict unsuccessful breast feeding. Arch Dis Child. 2010;97(4):355-7. [pmid: 21127006].
Galler JR, Harrison RH, Ramsey F, et al. Postpartum feeding attitudes, maternal depression, and breastfeeding in Barbados. Infant Behav Dev. 2006;29(2):189-203. [pmid: 17138274].
Galler JR, Harrison RH, Ramsey F, et al. Postpartum maternal mood, feeding practices, and infant temperament in Barbados. Infant Behavior & Development. 2004;27(3):267-287.
Gao W, Paterson J, Abbott M, et al. Pacific Islands families study: intimate partner violence and postnatal depression. J Immigr Minor Health. 2010;12(2):242-8. [pmid: 18807186].
Garabedian MJ, Lain KY, Hansen WF, et al. Violence against women and postpartum depression. J Womens Health (Larchmt). 2011;20(3):447-53. [pmid: 21323583].
Gardner F, Dezateux C, Elbourne D, et al. The hip trial: psychosocial consequences for mothers of using ultrasound to manage infants with developmental hip dysplasia. Arch Dis Child Fetal Neonatal Ed. 2005;90(1):F17-24. [pmid: 15613565].
Gauthier L, Guay F, Senecal C, et al. Women’s depressive symptoms during the transition to motherhood: the role of competence, relatedness, and autonomy. J Health Psychol. 2010;15(8):1145-56. [pmid: 20453050].
Gavin AR, Holzman C, Siefert K, et al. Maternal depressive symptoms, depression, and psychiatric medication use in relation to risk of preterm delivery. Womens Health Issues. 2009;19(5):325-34. [pmid: 19733802].
Gelabert E, Subira S, Garcia-Esteve L, et al. Perfectionism dimensions in major postpartum depression. J Affect Disord. 2012;136(1–2):17-25. [pmid: 21930303].
Gelabert E, Subira S, Plaza A, et al. The Vulnerable Personality Style Questionnaire: psychometric properties in Spanish postpartum women. Arch Womens Ment Health. 2011;14(2):115-24. [pmid: 21052750].
George L, Elliott SA. Searching for antenatal predictors of postnatal depressive symptomatology: Unexpected findings from a study of obsessive-compulsive personality traits. Journal of Reproductive and Infant Psychology. 2004;22(1):25-31.
Georgsson Ohman S, Grunewald C, Waldenstrom U. Perception of risk in relation to ultrasound screening for Down’s syndrome during pregnancy. Midwifery. 2009;25(3):264-76. [pmid: 17920172].
Georgsson Ohman S, Saltvedt S, Grunewald C, et al. Does fetal screening affect women’s worries about the health of their baby? A randomized controlled trial of ultrasound screening for Down’s syndrome versus routine ultrasound screening. Acta Obstet Gynecol Scand. 2004;83(7):634-40. [pmid: 15225187].
Giacobbe A, Maggio Savasta L, De Dominici R, et al. The influence of planned kinds of delivery on pregnant women’s emotional state. J Matern Fetal Neonatal Med. 2011;25(7):1188-90. [pmid: 21740317].
Giakoumaki O, Vasilaki K, Lili L, et al. The role of maternal anxiety in the early postpartum period: screening for anxiety and depressive symptomatology in Greece. J Psychosom Obstet Gynaecol. 2009;30(1):21-8. [pmid: 19308779].
Giallo R, Wade C, Cooklin A, et al. Assessment of maternal fatigue and depression in the postpartum period: Support for two separate constructs. Journal of Reproductive and Infant Psychology. 2011;29(1):69-80.
Gjerdingen D, Crow S, McGovern P, et al. Changes in depressive symptoms over 0–9 months postpartum. J Womens Health (Larchmt). 2011;20(3):381-6. [pmid: 21351876].
Gjerdingen DK, Center BA. The relationship of postpartum partner satisfaction to parents’ work, health, and social characteristics. Women Health. 2004;40(4):25-39. [pmid: 15911508].
Glasser S, Barell V, Shoham A, et al. Prospective study of postpartum depression in an Israeli cohort: prevalence, incidence and demographic risk factors. J Psychosom Obstet Gynaecol. 1998;19(3):155-64. [pmid: 9844846].
Glasser S, Stoski E, Kneler V, et al. Postpartum depression among Israeli Bedouin women. Arch Womens Ment Health. 2011;14(3):203-8. [pmid: 21479760].
Glasser S, Tanous M, Shihab S, et al. Perinatal Depressive Symptoms Among Arab Women in Northern Israel. Matern Child Health J. 2011;16(6):1197-205. [pmid: 21735141].
Glavin K, Smith L, Sorum R. Prevalence of postpartum depression in two municipalities in Norway. Scand J Caring Sci. 2009;23(4):705-10. [pmid: 19490523].
Goecke TW, Voigt F, Faschingbauer F, et al. The association of prenatal attachment and perinatal factors with pre- and postpartum depression in first-time mothers. Arch Gynecol Obstet. 2012;286(2):309-16. [pmid: 22437190].
Gonidakis F, Rabavilas AD, Varsou E, et al. A 6-month study of postpartum depression and related factors in Athens Greece. Compr Psychiatry. 2008;49(3):275-82. [pmid: 18396187].
Goodman JH. Influences of maternal postpartum depression on fathers and on father-infant interaction. Infant Mental Health Journal. 2008;29(6):624-643.
Gordon TE, Cardone IA, Kim JJ, et al. Universal perinatal depression screening in an Academic Medical Center. Obstet Gynecol. 2006;107(2 Pt 1):342-7. [pmid: 16449122].
Gorman LL, O’Hara MW, Figueiredo B, et al. Adaptation of the structured clinical interview for DSM-IV disorders for assessing depression in women during pregnancy and post-partum across countries and cultures. Br J Psychiatry Suppl. 2004;46:s17-23. [pmid: 14754814].
Goto A, Nguyen QV, Nguyen TT, et al. Associations of Psychosocial Factors with Maternal Confidence Among Japanese and Vietnamese Mothers. J Child Fam Stud. 2010;19(1):118-127. [pmid: 20157347].
Goulet L, D’Amour D, Pineault R. Type and timing of services following postnatal discharge: do they make a difference?. Women Health. 2007;45(4):19-39. [pmid: 18032166].
Gourounti K, Lykeridou K, Taskou C, et al. A survey of worries of pregnant women: Reliability and validity of the Greek version of the Cambridge Worry Scale. Midwifery. 2011. Oct. 18. [Epub ahead of print]. [pmid: 22015218].
Goyal D, Gay C, Lee K. Fragmented maternal sleep is more strongly correlated with depressive symptoms than infant temperament at three months postpartum. Arch Womens Ment Health. 2009;12(4):229-37. [pmid: 19396527].
Goyal D, Gay C, Lee KA. How much does low socioeconomic status increase the risk of prenatal and postpartum depressive symptoms in first-time mothers?. Womens Health Issues. 2010;20(2):96-104. [pmid: 20133153].
Goyal D, Gay CL, Lee KA. Patterns of sleep disruption and depressive symptoms in new mothers. J Perinat Neonatal Nurs. 2007;21(2):123-9. [pmid: 17505232].
Grant KA, McMahon C, Austin MP. Maternal anxiety during the transition to parenthood: a prospective study. J Affect Disord. 2008;108(1–2):101-11. [pmid: 18001841].
Gray PH, Edwards DM, O’Callaghan MJ, et al. Parenting stress in mothers of preterm infants during early infancy. Early Hum Dev. 2012;88(1):45-9. [pmid: 21782361].
Green K, Broome H, Mirabella J. Postnatal depression among mothers in the United Arab Emirates: socio-cultural and physical factors. Psychol Health Med. 2006;11(4):425-31. [pmid: 17129919].
Groer M, Davis M, Casey K, et al. Neuroendocrine and immune relationships in postpartum fatigue. MCN Am J Matern Child Nurs. 2005;30(2):133-8. [pmid: 15775810].
Groer MW. Differences between exclusive breastfeeders, formula-feeders, and controls: a study of stress, mood, and endocrine variables. Biol Res Nurs. 2005;7(2):106-17. [pmid: 16267372].
Grote V, Vik T, von Kries R, et al. Maternal postnatal depression and child growth: a European cohort study. BMC Pediatr. 2010;10:14. [pmid: 20226021].
Grussu P, Quatraro RM. Prevalence and risk factors for a high level of postnatal depression symptomatology in Italian women: a sample drawn from ante-natal classes. Eur Psychiatry. 2009;24(5):327-33. [pmid: 19328659].
Grussu P, Nasta MT, Quatraro RM. Serum cholesterol concentration and distress in the initial days after childbirth. Psychiatry Res. 2007;151(1–2):159-62. [pmid: 17368562].
Gunn J, Lumley J, Chondros P, et al. Does an early postnatal check-up improve maternal health: results from a randomised trial in Australian general practice. Br J Obstet Gynaecol. 1998;105(9):991-7. [pmid: 9763051].
Gutke A, Josefsson A, Oberg B. Pelvic girdle pain and lumbar pain in relation to postpartum depressive symptoms. Spine (Phila Pa 1976). 2007;32(13):1430-6. [pmid: 17545912].
Haas JS, Jackson RA, Fuentes-Afflick E, et al. Changes in the health status of women during and after pregnancy. J Gen Intern Med. 2005;20(1):45-51. [pmid: 15693927].
Haga SM, Ulleberg P, Slinning K, et al. A longitudinal study of postpartum depressive symptoms: multilevel growth curve analyses of emotion regulation strategies, breastfeeding self-efficacy, and social support. Arch Womens Ment Health. 2012;15(3):175-84. [pmid: 22451329].
Hairston IS, Waxler E, Seng JS, et al. The role of infant sleep in intergenerational transmission of trauma. Sleep. 2011;34(10):1373-83. [pmid: 21966069].
Hammarberg K, Rowe HJ, Fisher JR. Early post-partum adjustment and admission to parenting services in Victoria, Australia after assisted conception. Hum Reprod. 2009;24(11):2801-9. [pmid: 19661124].
Hanington L, Ramchandani P, Stein A. Parental depression and child temperament: assessing child to parent effects in a longitudinal population study. Infant Behav Dev. 2010;33(1):88-95. [pmid: 20056283].
Hanna B, Jarman H, Savage S. The clinical application of three screening tools for recognizing post-partum depression. Int J Nurs Pract. 2004;10(2):72-9. [pmid: 15056345].
Hanna B, Jarman H, Savage S, et al. The early detection of postpartum depression: midwives and nurses trial a checklist. J Obstet Gynecol Neonatal Nurs. 2004;33(2):191-7. [pmid: 15095798].
Hanusa BH, Scholle SH, Haskett RF, et al. Screening for depression in the postpartum period: a comparison of three instruments. J Womens Health (Larchmt). 2008;17(4):585-96. [pmid: 18345995].
Harrington AR, Greene-Harrington CC. Healthy Start screens for depression among urban pregnant, postpartum and interconceptional women. J Natl Med Assoc. 2007;99(3):226-31. [pmid: 17393946].
Harville EW, Xiong X, Buekens P, et al. Resilience after hurricane Katrina among pregnant and postpartum women. Womens Health Issues. 2010;20(1):20-7. [pmid: 20123173].
Harville EW, Xiong X, Pridjian G, et al. Postpartum mental health after Hurricane Katrina: a cohort study. BMC Pregnancy Childbirth. 2009;9:21. [pmid: 19505322].
Hatton DC, Harrison-Hohner J, Coste S, et al. Symptoms of postpartum depression and breastfeeding. J Hum Lact. 2005;21(4):444-9. quiz 450-4. [pmid: 16280561].
Hauge LJ, Torgersen L, Vollrath M. Associations between maternal stress and smoking: Findings from a population-based prospective cohort study. Addiction. 2012;107(6):1168-1173. [pmid: 22188214].
Hayes BA, Muller R, Bradley BS. Perinatal depression: a randomized controlled trial of an antenatal education intervention for primiparas. Birth. 2001;28(1):28-35. [pmid: 11264626].
Hayes DK, Ta VM, Hurwitz EL, et al. Disparities in self-reported postpartum depression among Asian, Hawaiian, and Pacific Islander Women in Hawaii: Pregnancy Risk Assessment Monitoring System (PRAMS), 2004–2007. Matern Child Health J. 2010;14(5):765-73. [pmid: 19653084].
Heilemann M, Frutos L, Lee K, et al. Protective strength factors, resources, and risks in relation to depressive symptoms among childbearing women of Mexican descent. Health Care Women Int. 2004;25(1):88-106. [pmid: 14742112].
Henshaw C, Foreman D, Cox J. Postnatal blues: a risk factor for postnatal depression. J Psychosom Obstet Gynaecol. 2004;25(3–4):267-72. [pmid: 15715025].
Heron J, Haque S, Oyebode F, et al. A longitudinal study of hypomania and depression symptoms in pregnancy and the postpartum period. Bipolar Disord. 2009;11(4):410-7. [pmid: 19500094].
Heron J, O’Connor TG, Evans J, et al. The course of anxiety and depression through pregnancy and the postpartum in a community sample. J Affect Disord. 2004;80(1):65-73. [pmid: 15094259].
Herring SJ, Rich-Edwards JW, Oken E, et al. Association of postpartum depression with weight retention 1 year after childbirth. Obesity (Silver Spring). 2008;16(6):1296-301. [pmid: 18369338].
Hibino Y, Takaki J, Kambayashi Y, et al. Relationship between the Noto-Peninsula earthquake and maternal postnatal depression and child-rearing. Environ Health Prev Med. 2009;14(5):255-60. [pmid: 19568831].
Highet NJ, Gemmill AW, Milgrom J. Depression in the perinatal period: awareness, attitudes and knowledge in the Australian population. Aust N Z J Psychiatry. 2011;45(3):223-31. [pmid: 21438748].
Hill PD, Aldag JC. Maternal perceived quality of life following childbirth. J Obstet Gynecol Neonatal Nurs. 2007;36(4):328-34. [pmid: 17594407].
Hiltunen P, Jokelainen J, Ebeling H, et al. Seasonal variation in postnatal depression. J Affect Disord. 2004;78(2):111-8. [pmid: 14706721].
Hiltunen P, Raudaskoski T, Ebeling H, et al. Does pain relief during delivery decrease the risk of postnatal depression?. Acta Obstet Gynecol Scand. 2004;83(3):257-61. [pmid: 14995921].
Hinshaw K, Simpson S, Cummings S, et al. A randomised controlled trial of early versus delayed oxytocin augmentation to treat primary dysfunctional labour in nulliparous women. BJOG. 2008;115(10):1289-95. discussion 1295-6. [pmid: 18715415].
Hodgkinson SC, Colantuoni E, Roberts D, et al. Depressive symptoms and birth outcomes among pregnant teenagers. J Pediatr Adolesc Gynecol. 2010;23(1):16-22. [pmid: 19679498].
Hoedjes M, Berks D, Vogel I, et al. Postpartum depression after mild and severe preeclampsia. J Womens Health (Larchmt). 2011;20(10):1535-42. [pmid: 21815820].
Holbrook A, Kaltenbach K. Co-Occurring Psychiatric Symptoms in Opioid-Dependent Women: The Prevalence of Antenatal and Postnatal Depression. Am J Drug Alcohol Abuse. 2012. Jul. 11. [Epub ahead of print]. [pmid: 22783870].
Holub CK, Kershaw TS, Ethier KA, et al. Prenatal and parenting stress on adolescent maternal adjustment: identifying a high-risk subgroup. Matern Child Health J. 2007;11(2):153-9. [pmid: 17066314].
Honey KL, Bennett P, Morgan M. A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. 2002;41(Pt 4):405-9. [pmid: 12437794].
Honey KL, Bennett P, Morgan M. Predicting postnatal depression. J Affect Disord. 2003;76(1–3):201-10. [pmid: 12943950].
Hood KK, Bennett Johnson S, Carmichael SK, et al. Depressive symptoms in mothers of infants identified as genetically at risk for type 1 diabetes. Diabetes Care. 2005;28(8):1898-903. [pmid: 16043729].
Horowitz JA, Cousins A. Postpartum depression treatment rates for at-risk women. Nurs Res. 2006;55(2 Suppl):S23-7. [pmid: 16601631].
Horowitz JA, Bell M, Trybulski J, et al. Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323-9. [pmid: 11775301].
Horowitz JA, Murphy CA, Gregory KE, et al. A community-based screening initiative to identify mothers at risk for postpartum depression. J Obstet Gynecol Neonatal Nurs. 2011;40(1):52-61. [pmid: 21121945].
Horowitz JA, Murphy CA, Gregory KE, et al. Community-based postpartum depression screening: Results from the CARE study. Psychiatric Services. 2009;60(11):1432-1434. [pmid: 19880456].
Horowitz JA. Community-based postpartum depression screening within the first month after delivery. Contemp Nurse. 2006;21(1):85-93. [pmid: 16594885].
Horwitz SM, Briggs-Gowan MJ, Storfer-Isser A, et al. Prevalence, correlates, and persistence of maternal depression. J Womens Health (Larchmt). 2007;16(5):678-91. [pmid: 17627403].
Howell EA, Mora P, Leventhal H. Correlates of early postpartum depressive symptoms. Matern Child Health J. 2006;10(2):149-57. [pmid: 16341910].
Huang YC, Mathers NJ. A comparison of sexual satisfaction and post-natal depression in the UK and Taiwan. Int Nurs Rev. 2006;53(3):197-204. [pmid: 16879182].
Huang ZJ, Wong FY, Ronzio CR, et al. Depressive symptomatology and mental health help-seeking patterns of U.S.- and foreign-born mothers. Matern Child Health J. 2007;11(3):257-67. [pmid: 17171544].
Hullfish KL, Fenner DE, Sorser SA, et al. Postpartum depression, urge urinary incontinence, and overactive bladder syndrome: is there an association?. Int Urogynecol J Pelvic Floor Dysfunct. 2007;18(10):1121-6. [pmid: 17308861].
Husain N, Cruickshank K, Husain M, et al. Social stress and depression during pregnancy and in the postnatal period in British Pakistani mothers: A cohort study. J Affect Disord. 2012;140(3):268-76. [pmid: 22608713].
Ingram J, Taylor J. Predictors of postnatal depression: Using an antenatal needs assessment discussion tool. Journal of Reproductive and Infant Psychology. 2007;25(3):210-222.
Jackson FM, Rowley DL, Curry Owens T. Contextualized stress, global stress, and depression in well-educated, pregnant, African-American women. Womens Health Issues. 2012;22(3):e329-36. [pmid: 22382126].
Jevitt C, Zapata L, Harrington M, et al. Screening for perinatal depression with limited psychiatric resources. Journal of the American Psychiatric Nurses Association. 2005;11(6):359-363.
Johanson R, Chapman G, Murray D, et al. The North Staffordshire Maternity Hospital prospective study of pregnancy-associated depression. J Psychosom Obstet Gynaecol. 2000;21(2):93-7. [pmid: 10994181].
Jomeen J, Martin C. Is the hospital anxiety and depression scale (HAPS) a reliable screening tool in early pregnancy?. Psychology & Health. 2004;19(6):787-800.
Jomeen J, Martin CR. Assessment and relationship of sleep quality to depression in early pregnancy. Journal of Reproductive and Infant Psychology. 2007;25(1):87-99.
Jomeen J, Martin CR. Confirmation of an occluded anxiety component within the Edinburgh Postnatal Depression Scale (EPDS) during early pregnancy. Journal of Reproductive and Infant Psychology. 2005;23(2):143-154.
Jones L, Scott J, Cooper C, et al. Cognitive style, personality and vulnerability to postnatal depression. Br J Psychiatry. 2010;196(3):200-5. [pmid: 20194541].
Josefsson A, Berg G, Nordin C, et al. Prevalence of depressive symptoms in late pregnancy and postpartum. Acta Obstet Gynecol Scand. 2001;80(3):251-5. [pmid: 11207491].
Kaminsky LM, Carlo J, Muench MV, et al. Screening for postpartum depression with the Edinburgh Postnatal Depression Scale in an indigent population: does a directed interview improve detection rates compared with the standard self-completed questionnaire?. J Matern Fetal Neonatal Med. 2008;21(5):321-5. [pmid: 18446659].
Karam F, Berard A, Sheehy O, et al. Reliability and validity of the 4-item perceived stress scale among pregnant women: Results from the OTIS antidepressants study. Res Nurs Health. 2012;35(4):363-375. [pmid: 22511354].
Kerruish NJ, Campbell-Stokes PL, Gray A, et al. Maternal psychological reaction to newborn genetic screening for type 1 diabetes. Pediatrics. 2007;120(2):e324-35. [pmid: 17609310].
Kim C, Brawarsky P, Jackson RA, et al. Changes in health status experienced by women with gestational diabetes and pregnancy-induced hypertensive disorders. J Womens Health (Larchmt). 2005;14(8):729-36. [pmid: 16232105].
Kim HG, Geppert J, Quan T, et al. Screening for postpartum depression among low-income mothers using an interactive voice response system. Maternal and Child Health Journal. 2012;16(4):921-928. [pmid: 21584791].
Kim JJ, Gordon TE, La Porte LM, et al. The utility of maternal depression screening in the third trimester. Am J Obstet Gynecol. 2008;199(5):509 e1-5. [pmid: 18533122].
King PA. Replicability of structural models of the Edinburgh Postnatal Depression Scale (EPDS) in a community sample of postpartum African American women with low socioeconomic status. Arch Womens Ment Health. 2012;15(2):77-86. [pmid: 22297555].
Klier CM, Muzik M, Dervic K, et al. The role of estrogen and progesterone in depression after birth. J Psychiatr Res. 2007;41(3–4):273-9. [pmid: 17049560].
Klier CM, Rosenblum KL, Zeller M, et al. A multirisk approach to predicting chronicity of postpartum depression symptoms. Depress Anxiety. 2008;25(8):718-24. [pmid: 18729148].
Korhonen M, Luoma I, Salmelin R, et al. A longitudinal study of maternal prenatal, postnatal and concurrent depressive symptoms and adolescent well-being. Journal of Affective Disorders. 2012;136(3):680-692. [pmid: 22036793].
Korja R, Savonlahti E, Ahlqvist-Bjorkroth S, et al. Maternal depression is associated with mother-infant interaction in preterm infants. Acta Paediatr. 2008;97(6):724-30. [pmid: 18373715].
Kornfeld BD, Bair-Merritt MH, Frosch E, et al. Postpartum Depression and Intimate Partner Violence in Urban Mothers: Co-Occurrence and Child Healthcare Utilization. J Pediatr. 2012;161(2):348-53. e2. [pmid: 22404952].
Kozinszky Z, Dudas RB, Csatordai S, et al. Social dynamics of postpartum depression: a population-based screening in South-Eastern Hungary. Soc Psychiatry Psychiatr Epidemiol. 2011;46(5):413-23. [pmid: 20300729].
Kozinszky Z, Dudas RB, Devosa I, et al. Can a Brief Antepartum Preventive Group Intervention Help Reduce Postpartum Depressive Symptomatology?. Psychother Psychosom. 2012;81(2):98-107. [pmid: 22261988].
Krause KM, Ostbye T, Swamy GK. Occurrence and correlates of postpartum depression in overweight and obese women: results from the active mothers postpartum (AMP) study. Matern Child Health J. 2009;13(6):832-8. [pmid: 18836820].
Kuo SY, Yang YL, Kuo PC, et al. Trajectories of Depressive Symptoms and Fatigue Among Postpartum Women. J Obstet Gynecol Neonatal Nurs. 2012;41(2):216-26. [pmid: 22375929].
Kuo WH, Wilson TE, Holman S, et al. Depressive symptoms in the immediate postpartum period among Hispanic women in three U.S. cities. J Immigr Health. 2004;6(4):145-53. [pmid: 16228697].
Kurtz Landy C, Sword W, Ciliska D. Urban women’s socioeconomic status, health service needs and utilization in the four weeks after postpartum hospital discharge: findings of a Canadian cross-sectional survey. BMC Health Serv Res. 2008;8:203. [pmid: 18834521].
La Porte LM, Kim JJ, Adams M, et al. The pattern of depression screening results across successive pregnancies. Am J Obstet Gynecol. 2012;206(3):261 e1-4. [pmid: 22277930].
LaCoursiere DY, Barrett-Connor E, O’Hara MW, et al. The association between prepregnancy obesity and screening positive for postpartum depression. BJOG. 2010;117(8):1011-8. [pmid: 20536433].
LaCoursiere DY, Hirst KP, Barrett-Connor E. Depression and pregnancy stressors affect the association between abuse and postpartum depression. Matern Child Health J. 2012;16(4):929-935. [pmid: 21584792].
Lagerberg D, Magnusson M. Infant gender and postpartum sadness in the light of region of birth and some other factors: a contribution to the knowledge of postpartum depression. Arch Womens Ment Health. 2012;15(2):121-30. [pmid: 22382282].
Lanes A, Kuk JL, Tamim H. Prevalence and characteristics of postpartum depression symptomatology among Canadian women: a cross-sectional study. BMC Public Health. 2011;11:302. [pmid: 21569372].
Lansakara N, Brown SJ, Gartland D. Birth outcomes, postpartum health and primary care contacts of immigrant mothers in an Australian nulliparous pregnancy cohort study. Matern Child Health J. 2010;14(5):807-16. [pmid: 19697112].
Lanzi RG, Bert SC, Jacobs BK. Depression among a sample of first-time adolescent and adult mothers. J Child Adolesc Psychiatr Nurs. 2009;22(4):194-202. [pmid: 19930300].
Larsson C, Sydsjo G, Josefsson A. Health, sociodemographic data, and pregnancy outcome in women with antepartum depressive symptoms. Obstet Gynecol. 2004;104(3):459-66. [pmid: 15339754].
Lau C, Hurst NM, Smith EO, et al. Ethnic/racial diversity, maternal stress, lactation and very low birthweight infants. J Perinatol. 2007;27(7):399-408. [pmid: 17592486].
Lau Y, Wong DF. Are concern for face and willingness to seek help correlated to early postnatal depressive symptoms among Hong Kong Chinese women? A cross-sectional questionnaire survey. Int J Nurs Stud. 2008;45(1):51-64. [pmid: 17056045].
Lau Y, Wong DF, Chan KS. The utility of screening for perinatal depression in the second trimester among Chinese: a three-wave prospective longitudinal study. Arch Womens Ment Health. 2010;13(2):153-64. [pmid: 20058040].
Lavender T, Walkinshaw SA. Can midwives reduce postpartum psychological morbidity? A randomized trial. Birth. 1998;25(4):215-9. [pmid: 9892887].
Le HN, Perry DF, Sheng X. Using the internet to screen for postpartum depression. Matern Child Health J. 2009;13(2):213-21. [pmid: 18278545].
Lee AM, Lam SK, Sze Mun Lau SM, et al. Prevalence, course, and risk factors for antenatal anxiety and depression. Obstet Gynecol. 2007;110(5):1102-12. [pmid: 17978126].
Lee DT, Yip AS, Leung TY, et al. Ethnoepidemiology of postnatal depression. Prospective multivariate study of sociocultural risk factors in a Chinese population in Hong Kong. Br J Psychiatry. 2004;184:34-40. [pmid: 14702225].
Lee DT, Yip SK, Chiu HF, et al. Detecting postnatal depression in Chinese women Validation of the Chinese version of the Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1998;172:433-7. [pmid: 9747407].
Leeds L, Hargreaves I. The psychological consequences of childbirth. Journal of Reproductive and Infant Psychology. 2008;26(2):108-122.
Leonardoua AA, Zervas YM, Papageorgiou CC, et al. Validation of the Edinburgh Postnatal Depression Scale and prevalence of postnatal depression at two months postpartum in a sample of Greek mothers. Journal of Reproductive and Infant Psychology. 2009;27(1):28-39.
Leung SS, Martinson IM, Arthur D. Postpartum depression and related psychosocial variables in Hong Kong Chinese women: findings from a prospective study. Res Nurs Health. 2005;28(1):27-38. [pmid: 15625707].
Leung WC, Kung F, Lam J, et al. Domestic violence and postnatal depression in a Chinese community. International Journal of Gynaecology and Obstetrics. 2002;79(2):159-66. [pmid: 12427403].
Lewis SJ, Araya R, Leary S, et al. Folic acid supplementation during pregnancy may protect against depression 21 months after pregnancy, an effect modified by MTHFR C677T genotype. Eur J Clin Nutr. 2012;66(1):97-103. [pmid: 21772318].
MacArthur C, Winter HR, Bick DE, et al. Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet. 2002;359(9304):378-85. [pmid: 11844507].
Magnusson M, Lagerberg D, Sundelin C. How can we identify vulnerable mothers who do not reach the cut off 12 points in EPDS?. J Child Health Care. 2011;15(1):39-49. [pmid: 21451009].
Maia BR, Marques M, Bos S, et al. Epidemiology of perinataldepression in Portugal categorical and dimensional approach ORIGINAL (NON-ENGLISH) TITLE Epidemiologia da depressao perinatal em Portugal abordagem categorical e dimensional. Acta Medica Portuguesa. 2011;24(SUPPL 2):443-448. [pmid: 22849933].
Makrides M, Gibson RA, McPhee AJ, et al. Effect of DHA supplementation during pregnancy on maternal depression and neurodevelopment of young children: a randomized controlled trial. JAMA. 2010;304(15):1675-83. [pmid: 20959577].
Mamun AA, Clavarino AM, Najman JM, et al. Maternal depression and the quality of marital relationship: a 14-year prospective study. J Womens Health (Larchmt). 2009;18(12):2023-31. [pmid: 20044866].
Mancini F, Carlson C, Albers L. Use of the Postpartum Depression Screening Scale in a collaborative obstetric practice. J Midwifery Womens Health. 2007;52(5):429-34. [pmid: 17826704].
Mann JR, McKeown RE, Bacon J, et al. Do antenatal religious and spiritual factors impact the risk of postpartum depressive symptoms?. J Womens Health (Larchmt). 2008;17(5):745-55. [pmid: 18537478].
Martín-Santos R, Gelabert E, Subirà S, et al. Research Letter: Is neuroticism a risk factor for postpartum depression?. Psychological Medicine. 2012;42(7):1559-1565. [pmid: 22622082].
Mason ZS, Briggs RD, Silver EJ. Maternal attachment feelings mediate between maternal reports of depression, infant social–emotional development, and parenting stress. Journal of Reproductive and Infant Psychology. 2011;29(4):382-394.
Matsumoto K, Tsuchiya KJ, Itoh H, et al. Age-specific 3-month cumulative incidence of postpartum depression: the Hamamatsu Birth Cohort (HBC) Study. J Affect Disord. 2011;133(3):607-10. [pmid: 21601291].
Matteo B, Miriam I, Giulia B, et al. Determinants of ante-partum depression: a multicenter study. Soc Psychiatry Psychiatr Epidemiol. 2012. Apr. 17. [Epub ahead of print]. [pmid: 22526826].
Matthey S, Ross-Hamid C. Repeat testing on the Edinburgh Depression Scale and the HADS-A in pregnancy: Differentiating between transient and enduring distress. J Affect Disord. 2012. Jun. 11. [Epub ahead of print]. [pmid: 22695259].
Mayberry LJ, Horowitz JA, Declercq E. Depression symptom prevalence and demographic risk factors among U.S. women during the first 2 years postpartum. J Obstet Gynecol Neonatal Nurs. 2007;36(6):542-9. [pmid: 17973697].
McCoy SJ, Beal JM, Saunders B, et al. Risk factors for postpartum depression: a retrospective investigation. J Reprod Med. 2008;53(3):166-70. [pmid: 18441719].
McCoy SJ, Beal JM, Shipman SB, et al. Risk factors for postpartum depression: a retrospective investigation at 4-weeks postnatal and a review of the literature. J Am Osteopath Assoc. 2006;106(4):193-8. [pmid: 16627773].
McDonald S, Wall J, Forbes K, et al. Development of a prenatal psychosocial screening tool for post-partum depression and anxiety. Paediatr Perinat Epidemiol. 2012;26(4):316-27. [pmid: 22686383].
McGrath JM, Records K, Rice M. Maternal depression and infant temperament characteristics. Infant Behavior & Development. 2008;31(1):71-80. [pmid: 17714790].
McKee MD, Zayas LH, Jankowski KRB. Breastfeeding intention and practice in an urban minority population: Relationship to maternal depressive symptoms and mother-infant closeness. Journal of Reproductive and Infant Psychology. 2004;22(3):167-181.
McVey C, Tuohy A. Differential effects of marital relationship and social support on three subscales identified within the Edinburgh Postnatal Depression Scale. Journal of Reproductive and Infant Psychology. 2007;25(3):203-209.
Mehta D, Quast C, Fasching PA, et al. The 5-HTTLPR polymorphism modulates the influence on environmental stressors on peripartum depression symptoms. J Affect Disord. 2011;136(3):1192-7. [pmid: 22209125].
Melchior M, Chastang J-F, de Lauzon B, et al. Maternal depression, socioeconomic position, and temperament in early childhood: The EDEN mother–child cohort. Journal of Affective Disorders. 2012;137(1–3):165-169. [pmid: 22118857].
Melnyk BM, Feinstein NF, Alpert-Gillis L, et al. Reducing premature infants’ length of stay and improving parents’ mental health outcomes with the Creating Opportunities for Parent Empowerment (COPE) Neonatal Intensive Care Unit Program: A randomized, controlled trial. Pediatrics. 2006;118(5):e1414-e1427. [pmid: 17043133].
Meltzer-Brody S, Stuebe A, Dole N, et al. Elevated corticotropin releasing hormone (CRH) during pregnancy and risk of postpartum depression (PPD). J Clin Endocrinol Metab. 2011;96(1):E40-7. [pmid: 20943787].
Mezey G, Bacchus L, Bewley S, et al. Domestic violence, lifetime trauma and psychological health of childbearing women. BJOG. 2005;112(2):197-204. [pmid: 15663584].
Micali N, Simonoff E, Treasure J. Pregnancy and post-partum depression and anxiety in a longitudinal general population cohort: the effect of eating disorders and past depression. J Affect Disord. 2011;131(1–3):150-7. [pmid: 21146231].
Miles MS, Holditch-Davis D, Schwartz TA, et al. Depressive Symptoms in Mothers of Prematurely Born Infants. Journal of Developmental and Behavioral Pediatrics. 2007;28(1):36-44. [pmid: 17353730].
Milgrom J, Ericksen J, Negri L, et al. Screening for postnatal depression in routine primary care: properties of the Edinburgh Postnatal Depression Scale in an Australian sample. Aust N Z J Psychiatry. 2005;39(9):833-9. [pmid: 16168042].
Milgrom J, Gemmill AW, Bilszta JL, et al. Antenatal risk factors for postnatal depression: a large prospective study. J Affect Disord. 2008;108(1–2):147-57. [pmid: 18067974].
Milgrom J, Schembri C, Ericksen J, et al. Towards parenthood: An antenatal intervention to reduce depression, anxiety and parenting difficulties. Journal of Affective Disorders. 2011;130(3):385-394. [pmid: 21112641].
Miller LS, Boyd BJ, Chernov AJ. Improving the identification and treatment of postpartum depression in a managed care organization. Journal of Clinical Outcomes Management. 2004;11(3):157-161.
Mishina H, Hayashino Y, Fukuhara S. Test performance of two-question screening for postpartum depressive symptoms. Pediatr Int. 2009;51(1):48-53. [pmid: 19371277].
Mishina H, Hayashino Y, Takayama JI, et al. Can pediatricians accurately identify maternal depression at well-child visits?. Pediatr Int. 2010;52(2):284-9. [pmid: 19807879].
Modlin E, Maxson P. Breaking the cycle of maternal depression: An initiative to improve children’s environmental health. International Journal of Child Health and Human Development. 2010;3(4):407-413.
Mora PA, Bennett IM, Elo IT, et al. Distinct trajectories of perinatal depressive symptomatology: evidence from growth mixture modeling. Am J Epidemiol. 2009;169(1):24-32. [pmid: 19001135].
Morrell CJ, Spiby H, Stewart P, et al. Costs and effectiveness of community postnatal support workers: randomised controlled trial. BMJ. 2000;321(7261):593-8. [pmid: 10977833].
Nagata M, Nagai Y, Sobajima H, et al. Depression in the early postpartum period and attachment to children--in mothers of NICU infants. Infant and Child Development. 2004;13(2):93-110.
Nagy E, Molnar P, Pal A, et al. Prevalence rates and socioeconomic characteristics of post-partum depression in Hungary. Psychiatry Res. 2011;185(1–2):113-20. [pmid: 20965093].
Nielsen Forman D, Videbech P, Hedegaard M, et al. Postpartum depression: identification of women at risk. BJOG. 2000;107(10):1210-7. [pmid: 11028570].
O’Connor TG, Caprariello P, Blackmore ER, et al. Prenatal mood disturbance predicts sleep problems in infancy and toddlerhood. Early Hum Dev. 2007;83(7):451-8. [pmid: 17008033].
O’Hara MA, Schlechte JA, Lewis DA, et al. Controlled prospective study of postpartum mood disorders: psychological, environmental, and hormonal variables. J Abnorm Psychol. 1991;100(1):63-73. [pmid: 2005273].
Parfitt YM, Ayers S. The effect of post-natal symptoms of post-traumatic stress and depression on the couple’s relationship and parent-baby bond. Journal of Reproductive and Infant Psychology. 2009;27(2):127-142.
Payne JL, Fields ES, Meuchel JM, et al. Post adoption depression. Archives of Women’s Mental Health. 2010;13(2):147-151.
Petrou S, Morrell J, Spiby H. Assessing the empirical validity of alternative multi-attribute utility measures in the maternity context. Health Qual Life Outcomes. 2009;7:40. [pmid: 19419553].
Phillips J, Sharpe L, Matthey S, et al. Subtypes of postnatal depression? A comparison of women with recurrent and de novo postnatal depression. J Affect Disord. 2010;120(1–3):67-75. [pmid: 19443041].
Pop VJ, Komproe IJ, van Son MJ. Characteristics of the Edinburgh Post Natal Depression Scale in The Netherlands. J Affect Disord. 1992;26(2):105-10. [pmid: 1447427].
Punamaki RL, Repokari L, Vilska S, et al. Maternal mental health and medical predictors of infant developmental and health problems from pregnancy to one year: does former infertility matter?. Infant Behav Dev. 2006;29(2):230-42. [pmid: 17138278].
Quinlivan JA, Luehr B, Evans SF. Teenage mother’s predictions of their support levels before and actual support levels after having a child. J Pediatr Adolesc Gynecol. 2004;17(4):273-8. [pmid: 15288029].
Rich-Edwards JW, Kleinman K, Abrams A, et al. Sociodemographic predictors of antenatal and postpartum depressive symptoms among women in a medical group practice. J Epidemiol Community Health. 2006;60(3):221-7. [pmid: 16476752].
Rich-Edwards JW, Mohllajee AP, Kleinman K, et al. Elevated midpregnancy corticotropin-releasing hormone is associated with prenatal, but not postpartum, maternal depression. J Clin Endocrinol Metab. 2008;93(5):1946-51. [pmid: 18303075].
Robrecht DT, Millegan J, Leventis LL, et al. Spousal military deployment as a risk factor for postpartum depression. J Reprod Med. 2008;53(11):860-4. [pmid: 19097519].
Rogal SS, Poschman K, Belanger K, et al. Effects of posttraumatic stress disorder on pregnancy outcomes. Journal of Affective Disorders. 2007;102(1–3):137-143. [pmid: 17291588].
Ronzio CR, Mitchell SJ. The highs and lows of maternal depression: cluster analysis of depression symptoms in a sample of African American women. J Investig Med. 2010;58(7):887-92. [pmid: 20571439].
Rubertsson C, Waldenström U, Wickberg B, et al. Depressive mood in early pregnancy and postpartum: prevalence and women at risk in a national Swedish sample. Journal of Reproductive and Infant Psychology. 2005;23(2):155-166.
Rubertsson C, Wickberg B, Gustavsson P, et al. Depressive symptoms in early pregnancy, two months and one year postpartum-prevalence and psychosocial risk factors in a national Swedish sample. Arch Womens Ment Health. 2005;8(2):97-104. [pmid: 15883652].
Rubin LH, Cook JA, Grey DD, et al. Perinatal depressive symptoms in HIV-infected versus HIV-uninfected women: a prospective study from preconception to postpartum. J Womens Health (Larchmt). 2011;20(9):1287-95. [pmid: 21732738].
Rychnovsky J, Beck CT. Screening for postpartum depression in military women with the Postpartum Depression Screening Scale. Mil Med. 2006;171(11):1100-4. [pmid: 17153549].
Rychnovsky JD. Postpartum fatigue in the active-duty military woman. J Obstet Gynecol Neonatal Nurs. 2007;36(1):38-46. [pmid: 17238945].
Saenz P, Cerda M, Diaz JL, et al. Psychological stress of parents of preterm infants enrolled in an early discharge programme from the neonatal intensive care unit: a prospective randomised trial. Arch Dis Child Fetal Neonatal Ed. 2009;94(2):F98-F104. [pmid: 18635681].
Sagami A, Kayama M, Senoo E. The relationship between postpartum depression and abusive parenting behavior of Japanese mothers: a survey of mothers with a child less than one year old. Bull Menninger Clin. 2004;68(2):174-87. [pmid: 15262619].
Sato Y, Kato T, Kakee N. A six-month follow-up study of maternal anxiety and depressive symptoms among Japanese. J Epidemiol. 2008;18(2):84-7. [pmid: 18403858].
Satoh A, Kitamiya C, Kudoh H, et al. Factors associated with late post-partum depression in Japan. Jpn J Nurs Sci. 2009;6(1):27-36. [pmid: 19566637].
Scharfe E. Cause or consequence?: Exploring causal links between attachment and depression. Journal of Social and Clinical Psychology. 2007;26(9):1048-1064.
Schmidt RM, Wiemann CM, Rickert VI, et al. Moderate to severe depressive symptoms among adolescent mothers followed four years postpartum. J Adolesc Health. 2006;38(6):712-8. [pmid: 16730600].
Segre LS, O’Hara MW, Arndt S, et al. The prevalence of postpartum depression: the relative significance of three social status indices. Soc Psychiatry Psychiatr Epidemiol. 2007;42(4):316-21. [pmid: 17370048].
Segre LS, O’Hara MW, Brock RL, et al. Depression screening of perinatal women by the Des Moines Healthy Start Project: program description and evaluation. Psychiatr Serv. 2012;63(3):250-5. [pmid: 22388530].
Seimyr L, Edhborg M, Lundh W, et al. In the shadow of maternal depressed mood: experiences of parenthood during the first year after childbirth. J Psychosom Obstet Gynaecol. 2004;25(1):23-34. [pmid: 15376402].
Seimyr L, Welles-Nystrom B, Nissen E. A history of mental health problems may predict maternal distress in women postpartum. Midwifery. 2012. Jan. 18. [Epub ahead of print]. [pmid: 22265225].
Seto M, Cornelius MD, Goldschmidt L, et al. Long-term effects of chronic depressive symptoms among low-income childrearing mothers. Matern Child Health J. 2005;9(3):263-71. [pmid: 16075191].
Setse R, Grogan R, Pham L, et al. Longitudinal study of depressive symptoms and health-related quality of life during pregnancy and after delivery: the Health Status in Pregnancy (HIP) study. Matern Child Health J. 2009;13(5):577-87. [pmid: 18931832].
Sharan H, Kaplan B, Weizer N, et al. Early screening of postpartum depression using the Edinburgh Postnatal Depression Scale. International Journal of Risk & Safety in Medicine. 2006;18(4):213-218.
Sharp HM, Bramwell R. An empirical evaluation of a psychoanalytic theory of mothering orientation: Implications for the antenatal prediction of postnatal depression. Journal of Reproductive and Infant Psychology. 2004;22(2):71-89.
Sheard C, Cox S, Oates M, et al. Impact of a multiple, IVF birth on post-partum mental health: a composite analysis. Hum Reprod. 2007;22(7):2058-65. [pmid: 17545565].
Shelton NJ, Herrick KG. Comparison of scoring methods and thresholds of the General Health Questionnaire-12 with the Edinburgh Postnatal Depression Scale in English women. Public Health. 2009;123(12):789-93. [pmid: 19922968].
Shields N, Reid M, Cheyne H, et al. Impact of midwife-managed care in the postnatal period: An exploration of psychosocial outcomes. Journal of Reproductive and Infant Psychology. 1997;15(2):91-108.
Sibolboro Mezzacappa E, Endicott J. Parity mediates the association between infant feeding method and maternal depressive symptoms in the postpartum. Arch Womens Ment Health. 2007;10(6):259-66. [pmid: 18040595].
Silverman ME, Loudon H. Antenatal reports of pre-pregnancy abuse is associated with symptoms of depression in the postpartum period. Arch Womens Ment Health. 2010;13(5):411-5. [pmid: 20386940].
Sit D, Seltman H, Wisner KL. Seasonal effects on depression risk and suicidal symptoms in postpartum women. Depress Anxiety. 2011;28(5):400-5. [pmid: 21381158].
Skouteris H, Wertheim EH, Rallis S, et al. Depression and anxiety through pregnancy and the early postpartum: an examination of prospective relationships. J Affect Disord. 2009;113(3):303-8. [pmid: 18614240].
Small R, Lumley J, Donohue L, et al. Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. 2000;321(7268):1043-7. [pmid: 11053173].
Small R, Lumley J, Yelland J, et al. The performance of the Edinburgh Postnatal Depression Scale in English speaking and non-English speaking populations in Australia. Soc Psychiatry Psychiatr Epidemiol. 2007;42(1):70-8. [pmid: 17102922].
Smith LE, Howard KS. Continuity of paternal social support and depressive symptoms among new mothers. J Fam Psychol. 2008;22(5):763-73. [pmid: 18855512].
Soderquist J, Wijma B, Thorbert G, et al. Risk factors in pregnancy for post-traumatic stress and depression after childbirth. BJOG. 2009;116(5):672-80. [pmid: 19220236].
Solberg O, Dale MT, Holmstrom H, et al. Long-term symptoms of depression and anxiety in mothers of infants with congenital heart defects. J Pediatr Psychol. 2011;36(2):179-87. [pmid: 20558484].
Stadlmayr W, Amsler F, Lemola S, et al. Memory of childbirth in the second year: the long-term effect of a negative birth experience and its modulation by the perceived intranatal relationship with caregivers. J Psychosom Obstet Gynaecol. 2006;27(4):211-24. [pmid: 17225622].
Stamp GE, Williams AS, Crowther CA. Evaluation of antenatal and postnatal support to overcome postnatal depression: a randomized, controlled trial. Birth. 1995;22(3):138-43. [pmid: 7575861].
Stamp GE, Williams AS, Crowther CA. Predicting postnatal depression among pregnant women. Birth. 1996;23(4):218-23. [pmid: 9086958].
Stein G, Van den Akker A. The retrospective diagnosis of postnatal depression by questionnaire. J Psychosom Res. 1992;36(1):67-75. [pmid: 1538351].
Stowe ZN, Hostetter AL, Newport DJ. The onset of postpartum depression: Implications for clinical screening in obstetrical and primary care. Am J Obstet Gynecol. 2005;192(2):522-6. [pmid: 15695997].
Stramrood CA, Wessel I, Doornbos B, et al. Posttraumatic stress disorder following preeclampsia and PPROM: a prospective study with 15 months follow-up. Reprod Sci. 2011;18(7):645-53. [pmid: 21421892].
Stuart S, Couser G, Schilder K, et al. Postpartum anxiety and depression: onset and comorbidity in a community sample. J Nerv Ment Dis. 1998;186(7):420-4. [pmid: 9680043].
Sugawara M, Sakamoto S, Kitamura T, et al. Structure of depressive symptoms in pregnancy and the postpartum period. J Affect Disord. 1999;54(1–2):161-9. [pmid: 10403159].
Sumner LA, Wong L, Schetter CD, et al. Predictors of posttraumatic stress disorder symptoms among low-income Latinas during pregnancy and postpartum. Psychological Trauma: Theory, Research, Practice, and Policy. 2012;4(2):196-203.
Surkan PJ, Peterson KE, Hughes MD, et al. The role of social networks and support in postpartum women’s depression: a multiethnic urban sample. Matern Child Health J. 2006;10(4):375-83. [pmid: 16404681].
Sutter-Dallay AL, Cosnefroy O, Glatigny-Dallay E, et al. Evolution of perinatal depressive symptoms from pregnancy to two years postpartum in a low-risk sample: The MATQUID cohort. Journal of Affective Disorders. 2012;139(1):23-29. [pmid: 22410506].
Sutter-Dallay AL, Giaconne-Marcesche V, Glatigny-Dallay E, et al. Women with anxiety disorders during pregnancy are at increased risk of intense postnatal depressive symptoms: a prospective survey of the MATQUID cohort. Eur Psychiatry. 2004;19(8):459-63. [pmid: 15589703].
Sutter-Dallay AL, Murray L, Dequae-Merchadou L, et al. A prospective longitudinal study of the impact of early postnatal vs. chronic maternal depressive symptoms on child development. Eur Psychiatry. 2011;26(8):484-9. [pmid: 20621453].
Sword W, Landy CK, Thabane L, et al. Is mode of delivery associated with postpartum depression at 6 weeks: a prospective cohort study. BJOG. 2011;118(8):966-77. [pmid: 21489126].
Sword W, Watt S, Krueger P. Postpartum health, service needs, and access to care experiences of immigrant and Canadian-born women. J Obstet Gynecol Neonatal Nurs. 2006;35(6):717-27. [pmid: 17105636].
Sylven SM, Papadopoulos FC, Mpazakidis V, et al. Newborn gender as a predictor of postpartum mood disturbances in a sample of Swedish women. Arch Womens Ment Health. 2011;14(3):195-201. [pmid: 21311924].
Sylven SM, Papadopoulos FC, Olovsson M, et al. Seasonality patterns in postpartum depression. Am J Obstet Gynecol. 2011;204(5):413 e1-6. [pmid: 21439544].
Tabuchi N, Shimada K. Maternal characteristics and feelings of distress resulting from the crying of high-risk infants. Japan Journal of Nursing Science. 2008;5(2):99-108.
Tatano Beck C, Gable RK, Sakala C, et al. Postpartum Depressive Symptomatology: Results from a Two-Stage US National Survey. Journal of Midwifery and Women’s Health. 2011;56(5):427-435.
Tees MT, Harville EW, Xiong X, et al. Hurricane Katrina-related maternal stress, maternal mental health, and early infant temperament. Matern Child Health J. 2010;14(4):511-8. [pmid: 19554438].
Tharner A, Luijk MP, van Ijzendoorn MH, et al. Maternal lifetime history of depression and depressive symptoms in the prenatal and early postnatal period do not predict infant-mother attachment quality in a large, population-based Dutch cohort study. Attach Hum Dev. 2012;14(1):63-81. [pmid: 22191607].
Thio IM, Oakley Browne MA, Coverdale JH, et al. Postnatal depressive symptoms go largely untreated: a probability study in urban New Zealand. Soc Psychiatry Psychiatr Epidemiol. 2006;41(10):814-8. [pmid: 16838090].
Thome M, Alder EM, Ramel A. A population-based study of exclusive breastfeeding in Icelandic women: is there a relationship with depressive symptoms and parenting stress?. Int J Nurs Stud. 2006;43(1):11-20. [pmid: 16326160].
Thompson JF, Roberts CL, Ellwood DA. Emotional and physical health outcomes after significant primary post-partum haemorrhage (PPH): a multicentre cohort study. Aust N Z J Obstet Gynaecol. 2011;51(4):365-71. [pmid: 21806578].
Tiwari A, Chan KL, Fong D, et al. The impact of psychological abuse by an intimate partner on the mental health of pregnant women. BJOG. 2008;115(3):377-84. [pmid: 18190375].
Tortajada S, Garcia-Gomez JM, Vicente J, et al. Prediction of postpartum depression using multilayer perceptrons and pruning. Methods Inf Med. 2009;48(3):291-8. [pmid: 19387507].
Tsai R, Schaffir J. Effect of depot medroxyprogesterone acetate on postpartum depression. Contraception. 2010;82(2):174-7. [pmid: 20654759].
Tucker JN, Grzywacz JG, Leng I, et al. Return to work, economic hardship, and women’s postpartum health. Women Health. 2010;50(7):618-38. [pmid: 21104566].
Tuohy A, McVey C. Experience of pregnancy and delivery as predictors of postpartum depression. Psychol Health Med. 2008;13(1):43-7. [pmid: 18066918].
Urquia ML, O’Campo PJ, Heaman MI, et al. Experiences of violence before and during pregnancy and adverse pregnancy outcomes: an analysis of the Canadian Maternity Experiences Survey. BMC Pregnancy Childbirth. 2011;11:42. [pmid: 21649909].
Urquia ML, O’Campo PJ, Heaman MI. Revisiting the immigrant paradox in reproductive health: The roles of duration of residence and ethnicity. Social Science &. Medicine. 2012;74(10):1610-1621. [pmid: 22464222].
v. Ballestrem CL, Strauss M, Kachele H.Contribution to the epidemiology of postnatal depression in Germany—implications for the utilization of treatment Arch Women Ment Health 2005 8 1 29 35 15868391
Valentine JM, Rodriguez MA, Lapeyrouse LM, et al. Recent intimate partner violence as a prenatal predictor of maternal depression in the first year postpartum among Latinas. Arch Womens Ment Health. 2011;14(2):135-43. [pmid: 21052749].
van Bussel JC, Spitz B, Demyttenaere K. Anxiety in pregnant and postpartum women. An exploratory study of the role of maternal orientations. J Affect Disord. 2009;114(1–3):232-42. [pmid: 18793805].
van Bussel JC, Spitz B, Demyttenaere K. Depressive symptomatology in pregnant and postpartum women. An exploratory study of the role of maternal antenatal orientations. Arch Womens Ment Health. 2009;12(3):155-66. [pmid: 19266251].
van Bussel JC, Spitz B, Demyttenaere K. Three self-report questionnaires of the early mother-to-infant bond: reliability and validity of the Dutch version of the MPAS, PBQ and MIBS. Arch Womens Ment Health. 2010;13(5):373-84. [pmid: 20127128].
van Bussel JC, Spitz B, Demyttenaere K. Women’s mental health before, during, and after pregnancy: a population-based controlled cohort study. Birth. 2006;33(4):297-302. [pmid: 17150068].
van de Pol G, van Brummen HJ, Bruinse HW, et al. Is there an association between depressive and urinary symptoms during and after pregnancy?. Int Urogynecol J Pelvic Floor Dysfunct. 2007;18(12):1409-15. [pmid: 17404679].
Van De Pol G, Van Brummen HJ, Bruinse HW, et al. Pregnancy-related pelvic girdle pain in the Netherlands. Acta Obstet Gynecol Scand. 2007;86(4):416-22. [pmid: 17486462].
Van Lieshout RJ, Cleverley K, Jenkins JM, et al. Assessing the measurement invariance of the Center for Epidemiologic Studies Depression Scale across immigrant and non-immigrant women in the postpartum period. Arch Womens Ment Health. 2011;14(5):413-23. [pmid: 21932024].
van Son MJM, Verkerk G, van der Hart O, et al. Prenatal depression, mode of delivery and perinatal dissociation as predictors of postpartum posttraumatic stress: An empirical study. Clinical Psychology and Psychotherapy. 2005;12(4):297-312.
Vanderbilt D, Bushley T, Young R, et al. Acute posttraumatic stress symptoms among urban mothers with newborns in the neonatal intensive care unit: a preliminary study. J Dev Behav Pediatr. 2009;30(1):50-6. [pmid: 19194322].
Vänskä M, Punamäki R-L, Tolvanen A, et al. Maternal pre- and postnatal mental health trajectories and child mental health and development: Prospective study in a normative and formerly infertile sample. International Journal of Behavioral Development. 2011;35(6):517-531.
Vik T, Grote V, Escribano J, et al. Infantile colic, prolonged crying and maternal postnatal depression. Acta Paediatr. 2009;98(8):1344-8. [pmid: 19432839].
Vilska S, Unkila-Kallio L, Punamaki RL, et al. Mental health of mothers and fathers of twins conceived via assisted reproduction treatment: a 1-year prospective study. Hum Reprod. 2009;24(2):367-77. [pmid: 19043082].
Vivilaki VG, Dafermos V, Kogevinas M, et al. The Edinburgh Postnatal Depression Scale: translation and validation for a Greek sample. BMC Public Health. 2009;9:329. [pmid: 19740443].
Wahn EH, Nissen E. Sociodemographic background, lifestyle and psychosocial conditions of Swedish teenage mothers and their perception of health and social support during pregnancy and childbirth. Scand J Public Health. 2008;36(4):415-23. [pmid: 18539696].
Walfisch A, Matok I, Sermer C, et al. Weight-depression association in a high-risk maternal population. Journal of Maternal-Fetal and Neonatal Medicine. 2012;25(7):1017-1020. [pmid: 21854131].
Watanabe M, Wada K, Sakata Y, et al. Maternity blues as predictor of postpartum depression: a prospective cohort study among Japanese women. J Psychosom Obstet Gynaecol. 2008;29(3):206-12. [pmid: 18608817].
Watkins S, Meltzer-Brody S, Zolnoun D, et al. Early breastfeeding experiences and postpartum depression. Obstet Gynecol. 2011;118(2 Pt 1):214-21. [pmid: 21734617].
Watson D, O’Hara MW, Simms LJ, et al. Development and validation of the Inventory of Depression and Anxiety Symptoms (IDAS). Psychol Assess. 2007;19(3):253-68. [pmid: 17845118].
Webb DA, Bloch JR, Coyne JC, et al. Postpartum physical symptoms in new mothers: their relationship to functional limitations and emotional well-being. Birth. 2008;35(3):179-87. [pmid: 18844643].
Webster J, Hall L, Somville T, et al. Prospective testing of the Brisbane Postnatal Depression Index. Birth. 2006;33(1):56-63. [pmid: 16499532].
Webster J, Linnane J, Roberts J, et al. IDentify, Educate and Alert (IDEA) trial: an intervention to reduce postnatal depression. BJOG. 2003;110(9):842-6. [pmid: 14511967].
Webster J, Linnane JW, Dibley LM, et al. Improving antenatal recognition of women at risk for postnatal depression. Aust N Z J Obstet Gynaecol. 2000;40(4):409-12. [pmid: 11194425].
Webster J, Nicholas C, Velacott C, et al. Quality of life and depression following childbirth: impact of social support. Midwifery. 2011;27(5):745-9. [pmid: 20880619].
Webster J, Nicholas C, Velacott C, et al. Validation of the WHOQOL-BREF among women following childbirth. Aust N Z J Obstet Gynaecol. 2010;50(2):132-7. [pmid: 20522068].
Webster J, Pritchard MA, Creedy D, et al. A simplified predictive index for the detection of women at risk for postnatal depression. Birth. 2003;30(2):101-8. [pmid: 12752167].
Wei G, Greaver LB, Marson SM, et al. Postpartum depression: racial differences and ethnic disparities in a tri-racial and bi-ethnic population. Matern Child Health J. 2008;12(6):699-707. [pmid: 17955356].
Weiss BD, Sheehan CP, Gushwa LL. Is low literacy a risk factor for symptoms of depression in postpartum women?. J Reprod Med. 2009;54(9):563-8. [pmid: 19947034].
Weiss ME, Ryan P, Lokken L. Validity and reliability of the Perceived Readiness for Discharge After Birth Scale. J Obstet Gynecol Neonatal Nurs. 2006;35(1):34-45. [pmid: 16466351].
Wenzel A, Haugen EN, Jackson LC, et al. Anxiety symptoms and disorders at eight weeks postpartum. J Anxiety Disord. 2005;19(3):295-311. [pmid: 15686858].
Whisman MA, Davila J, Goodman SH. Relationship adjustment, depression, and anxiety during pregnancy and the postpartum period. J Fam Psychol. 2011;25(3):375-83. [pmid: 21553959].
Wiklund I, Edman G, Andolf E. Cesarean section on maternal request: reasons for the request, self-estimated health, expectations, experience of birth and signs of depression among first-time mothers. Acta Obstet Gynecol Scand. 2007;86(4):451-6. [pmid: 17486467].
Wiley CC, Burke GS, Gill PA, et al. Pediatricians’ views of postpartum depression: a self-administered survey. Arch Womens Ment Health. 2004;7(4):231-6. [pmid: 15480860].
Woolhouse H, Gartland D, Hegarty K, et al. Depressive symptoms and intimate partner violence in the 12 months after childbirth: a prospective pregnancy cohort study. BJOG. 2012;119(3):315-23. [pmid: 22145631].
Wright CM, Parkinson KN, Drewett RF. The influence of maternal socioeconomic and emotional factors on infant weight gain and weight faltering (failure to thrive): data from a prospective birth cohort. Arch Dis Child. 2006;91(4):312-7. [pmid: 16397011].
Yawn BP, Pace W, Wollan PC, et al. Concordance of Edinburgh Postnatal Depression Scale (EPDS) and Patient Health Questionnaire (PHQ-9) to assess increased risk of depression among postpartum women. J Am Board Fam Med. 2009;22(5):483-91. [pmid: 19734393].
Yelland J, Sutherland G, Brown SJ. Postpartum anxiety, depression and social health: findings from a population-based survey of Australian women. BMC Public Health. 2010;10:771. [pmid: 21167078].
Yim IS, Glynn LM, Dunkel-Schetter C, et al. Risk of postpartum depressive symptoms with elevated corticotropin-releasing hormone in human pregnancy. Arch Gen Psychiatry. 2009;66(2):162-9. [pmid: 19188538].
Yim IS, Glynn LM, Schetter CD, et al. Prenatal beta-endorphin as an early predictor of postpartum depressive symptoms in euthymic women. J Affect Disord. 2010;125(1–3):128-33. [pmid: 20051292].
Youn JH, Jeong IS. Predictive validity of the postpartum depression predictors inventory-revised. Asian Nursing Research. 2011;5(4):210-215.
Zajicek-Farber ML. Postnatal depression and infant health practices among high-risk women. Journal of Child and Family Studies. 2009;18(2):236-245.
Zelkowitz P, Saucier JF, Wang T, et al. Stability and change in depressive symptoms from pregnancy to two months postpartum in childbearing immigrant women. Arch Womens Ment Health. 2008;11(1):1-11. [pmid: 18270652].
Zelkowitz P, Schinazi J, Katofsky L, et al. Factors associated with depression in pregnant immigrant women. Transcult Psychiatry. 2004;41(4):445-64. [pmid: 15709645].

## Published Prior to January 1, 2004

Ballard CG, Davis R, Cullen PC, et al. Prevalence of postnatal psychiatric morbidity in mothers and fathers. Br J Psychiatry. 1994;164(6):782-8. [pmid: 7952984].
Barnett B, Matthey S, Gyaneshwar R. Screening for postnatal depression in women of non-English speaking background. Arch Womens Ment Health. 1999;2(2):67-74.
Beck CT, Gable RK. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. 2001;50(4):242-50. [pmid: 11480533].
Beck CT, Gable RK. Further validation of the Postpartum Depression Screening Scale. Nurs Res. 2001;50(3):155-64. [pmid: 11393637].
Berle JO, Aarre TF, Mykletun A, et al. Screening for postnatal depression Validation of the Norwegian version of the Edinburgh Postnatal Depression Scale, and assessment of risk factors for postnatal depression. J Affect Disord. 2003;76(1–3):151-6. [pmid: 12943945].
Boyce P, Stubbs J, Todd A. The Edinburgh Postnatal Depression Scale: validation for an Australian sample. Aust N Z J Psychiatry. 1993;27(3):472-6. [pmid: 8250792].
Brugha TS, Wheatley S, Taub NA, et al. Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273-81. [pmid: 11097068].
Campbell SB, Cohn JF. Prevalence and correlates of postpartum depression in first-time mothers. J Abnorm Psychol. 1991;100(4):594-9. [pmid: 1757673].
Chabrol H, Teissedre F, Saint-Jean M, et al. Prevention and treatment of post-partum depression: a controlled randomized study on women at risk. Psychol Med. 2002;32(6):1039-47. [pmid: 12214785].
Cooper PJ, Campbell EA, Day A, et al. Non-psychotic psychiatric disorder after childbirth. A prospective study of prevalence, incidence, course and nature. Br J Psychiatry. 1988;152:799-806. [pmid: 3167466].
Cox JL, Murray D, Chapman G. A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. 1993;163:27-31. [pmid: 8353695].
Elliott SA, Leverton TJ, Sanjack M, et al. Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 2000;39(Pt 3):223-41. [pmid: 11033746].
Garcia-Esteve L, Ascaso C, Ojuel J, et al. Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. 2003;75(1):71-6. [pmid: 12781353].
Georgiopoulos AM, Bryan TL, Wollan P, et al. Routine screening for postpartum depression. J Fam Pract. 2001;50(2):117-22. [pmid: 11219558].
Gotlib IH, Whiffen VE, Mount JH, et al. Prevalence rates and demographic characteristics associated with depression in pregnancy and the postpartum. J Consult Clin Psychol. 1989;57(2):269-74. [pmid: 2785127].
Harris B, Huckle P, Thomas R, et al. The use of rating scales to identify post-natal depression. Br J Psychiatry. 1989;154:813-7. [pmid: 2597888].
Hobfoll SE, Ritter C, Lavin J, et al. Depression prevalence and incidence among inner-city pregnant and postpartum women. J Consult Clin Psychol. 1995;63(3):445-53. [pmid: 7608357].
Kitamura T, Shima S, Sugawara M, et al. Temporal variation of validity of self-rating questionnaires: repeated use of the General Health Questionnaire and Zung’s Self-rating Depression Scale among women during antenatal and postnatal periods. Acta Psychiatr Scand. 1994;90(6):446-50. [pmid: 7892778].
Kitamura T, Sugawara M, Shima S, et al. Temporal variation of validity of self-rating questionnaires: improved validity of repeated use of Zung’s Self-Rating Depression Scale among women during the perinatal period. J Psychosom Obstet Gynaecol. 1999;20(2):112-7. [pmid: 10422043].
Kumar R, Robson KM. A prospective study of emotional disorders in childbearing women. Br J Psychiatry. 1984;144:35-47. [pmid: 6692075].
Lee D, Yip A, Chiu H, et al. A psychiatric epidemiological study of postpartum Chinese women. Am J Psychiatry. 2001;158(2):220-6. [pmid: 11156804].
Lee DT, Yip AS, Chiu HF, et al. Screening for postnatal depression: are specific instruments mandatory?. J Affect Disord. 2001;63(1–3):233-8. [pmid: 11246101].
Lee DT, Yip AS, Chiu HF, et al. Screening for postnatal depression using the double-test strategy. Psychosom Med. 2000;62(2):258-63. [pmid: 10772406].
Leverton TJ, Elliott SA. Is the EPDS a magic wand?: 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the present state examination. J Reprod Infant Psyc. 2000;18(4):279-96.
Lucas A, Pizarro E, Granada ML, et al. Postpartum thyroid dysfunction and postpartum depression: are they two linked disorders?. Clin Endocrinol (Oxf). 2001;55(6):809-14. [pmid: 11895224].
Matthey S, Barnett B, Howie P, et al. Diagnosing postpartum depression in mothers and fathers: whatever happened to anxiety?. J Affect Disord. 2003;74(2):139-47. [pmid: 12706515].
Matthey S, Barnett B, Kavanagh DJ, et al. Validation of the Edinburgh Postnatal Depression Scale for men, and comparison of item endorsement with their partners. J Affect Disord. 2001;64(2–3):175-84. [pmid: 11313084].
Murray L, Carothers AD. The validation of the Edinburgh Post-natal Depression Scale on a community sample. Br J Psychiatry. 1990;157:288-90. [pmid: 2224383].
Nott PN, Cutts S. Validation of the 30-item General Health Questionnaire in postpartum women. Psychol Med. 1982;12(2):409-13. [pmid: 7100363].
O’hara MW, Zekoski EM, Philipps LH, et al. Controlled prospective study of postpartum mood disorders: comparison of childbearing and nonchildbearing women. J Abnorm Psychol. 1990;99(1):3-15. [pmid: 2307763].
Posner NA, Unterman RR, Williams KN, et al. Screening for postpartum depression. An antepartum questionnaire. J Reprod Med. 1997;42(4):207-15. [pmid: 9131493].
Whiffen VE. Screening for postpartum depression: a methodological note. J Clin Psychol. 1988;44(3):367-71. [pmid: 3384962].
Whiffen VE. Vulnerability of postpartum depression: a prospective multivariate study. J Abnorm Psychol. 1988;97(4):467-74. [pmid: 3204233].
Wickberg B, Hwang CP. Counselling of postnatal depression: a controlled study on a population based Swedish sample. J Affect Disord. 1996;39(3):209-16. [pmid: 8856425].
Yonkers KA, Ramin SM, Rush AJ, et al. Onset and persistence of postpartum depression in an inner-city maternal health clinic system. Am J Psychiatry. 2001;158(11):1856-63. [pmid: 11691692].