# Included Studies

Below is a list of all included studies in alphabetical order. Inset citations marked with an asterisk did not individually meet criteria for inclusion but were considered for supplemental information (e.g., methods data pertinent to an included study) for the articles they follow. Related articles (representing the same studies) are indicated with lettered superscripts.

Akincigil A, Munch S, Niemczyk KC. Predictors of maternal depression in the first year postpartum: marital status and mediating role of relationship quality. Soc Work Health Care. 2010;49(3):227-44. [pmid: 20229395].
*. Reichman NE, Teitler JO, Garfinkel I, et al. Fragile Families: sample and design. Child Youth Serv Rev Child Youth Serv Rev. 2001;23(4–5):303-26.
Andersson L, Sundstrom-Poromaa I, Wulff M, et al. Depression and anxiety during pregnancy and six months postpartum: a follow-up study. Acta Obstet Gynecol Scand. 2006;85(8):937-44. [pmid: 16862471].
Austin MP, Colton J, Priest S, et al. The Antenatal Risk Questionnaire (ANRQ): Acceptability and use for psychosocial risk assessment in the maternity setting. Women Birth. 2011. [pmid: 21764399].
Austin MP, Hadzi-Pavlovic D, Priest SR, et al. Depressive and anxiety disorders in the postpartum period: how prevalent are they and can we improve their detection?. Arch Women Ment Health. 2010;13(5):395-401. [pmid: 20232218].
Barnes J, Senior R, Macpherson K. The utility of volunteer home-visiting support to prevent maternal depression in the first year of life. Child Care Health Dev. 2009;35(6):807-16. [pmid: 19719770].
*. Barnes J, MacPherson K, Senior R. The impact on parenting and the home environment of early support to mothers and new babies. J Child Serv. 2006;1:4-20.
a. Beck CT, Froman RD, Bernal H. Acculturation level and postpartum depression in Hispanic mothers. MCN. Am J Matern Child Nurs. 2005;30(5):299-304. [pmid: 16132006].
*. Beck CT, Gable RK. Postpartum Depression Screening Scale: Spanish Version. Nurs Res. 2003;52:296-306. [pmid: 14501544].
a. Beck CT, Gable RK. Screening performance of the postpartum depression screening scale—Spanish version. J Transcult Nurs. 2005;16(4):331-8. [pmid: 16160195].
Bloch M, Rotenberg N, Koren D, et al. Risk factors associated with the development of postpartum mood disorders. J Affect Disord. 2005;88(1):9-18. [pmid: 15979150].
Boyce P, Hickey A. Psychosocial risk factors to major depression after childbirth. Soc Psychiatry Psychiatr Epidemiol. 2005;40(8):605-12. [pmid: 16096700].
Burton A, Patel S, Kaminsky L, et al. Depression in pregnancy: time of screening and access to psychiatric care. J Matern Fetal Neonatal Med. 2011;24(11):1321-4. [pmid: 21261444].
Chaudron LH, Szilagyi PG, Tang W, et al. Accuracy of depression screening tools for identifying postpartum depression among urban mothers. Pediatrics. 2010;125(3):e609-17. [pmid: 20156899].
b. Chee CY, Chong YS, Ng TP, et al. The association between maternal depression and frequent non-routine visits to the infant’s doctor—a cohort study. J Affect Disord. 2008;107(1–3):247-53. [pmid: 17869346].
b. Chee CY, Lee DT, Chong YS, et al. Confinement and other psychosocial factors in perinatal depression: a transcultural study in Singapore. J Affect Disord. 2005;89(1–3):157-66. [pmid: 16257451].
Clarke PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. 2008;40(1):113-25. [pmid: 18459275].
Crotty F, Sheehan J. Prevalence and detection of postnatal depression in an Irish community sample. Ir J Psychol Med. 2004;21(4):117-21.
Csatordai S, Kozinszky Z, Devosa I, et al. Validation of the Leverton Questionnaire as a screening tool for postnatal depression in Hungary. Gen Hosp Psychiatry. 2009;31(1):56-66. [pmid: 19134511].
Edmondson OJ, Psychogiou L, Vlachos H, et al. Depression in fathers in the postnatal period: assessment of the Edinburgh Postnatal Depression Scale as a screening measure. J Affect Disord. 2010;125(1–3):365-8. [pmid: 20163873].
Ekeroma AJ, Ikenasio-Thorpe B, Weeks S, et al. Validation of the EdinburghPostnatal Depression Scale (EPDS) as a screening tool for postnatal depression in Samoan and Tongan women living in New Zealand. N Z Med J. 2012;125(1355):41-9. [pmid: 22722214].
c. Felice E, Saliba J, Grech V, et al. Prevalence rates and psychosocial characteristics associated with depression in pregnancy and postpartum in Maltese women. J Affect Disord. 2004;82(2):297-301. [pmid: 15488261].
c. Felice E, Saliba J, Grech V, et al. Validation of the Maltese version of the EdinburghPostnatal Depression Scale. Arch Women Ment Health. 2006;9(2):75-80. [pmid: 16172837].
Flynn HA, O’mahen HA, Massey L, et al. The impact of a brief obstetrics clinic-based intervention on treatment use for perinatal depression. J Womens Health (Larchmt). 2006;15(10):1195-204. [pmid: 17199460].
Garcia-Esteve L, Navarro P, Ascaso C, et al. Family caregiver role and premenstrual syndrome as associated factors for postnatal depression. Arch Women Ment Health. 2008;11(3):193-200. [pmid: 18506575].
d. Gjerdingen D, Crow S, Mcgovern P, et al. Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. 2009;7(1):63-70. [pmid: 19139451].
d. Gjerdingen D, Mcgovern P, Center B. Problems with a diagnostic depression interview in a postpartum depression trial. J Am Board Fam Med. 2011;24(2):187-93. [pmid: 21383219].
Glavin K, Smith L, Sorum R, et al. Redesigned community postpartum care to prevent and treat postpartum depression in women—a one-year follow-up study. J Clin Nurs. 2010;19(21–22):3051-62. [pmid: 20726926].
Goodman JH, Tyer-Viola L. Detection, treatment, and referral of perinatal depression and anxiety by obstetrical providers. J Womens Health (Larchmt). 2010;19(3):477-90. [pmid: 20156110].
Hamdan A, Tamim H. Psychosocial risk and protective factors for postpartum depression in the United Arab Emirates. Arch Women Ment Health. 2011;14(2):125-33. [pmid: 21063891].
Howard LM, Flach C, Mehay A, et al. The prevalence of suicidal ideation identified by the Edinburgh Postnatal Depression Scale in postpartum women in primary care: findings from the RESPOND trial. BMC Pregnancy Childbirth. 2011;11:57. [pmid: 21812968].
Jardri R, Pelta J, Maron M, et al. Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. 2006;93(1–3):169-76. [pmid: 16644021].
Ji S, Long Q, Newport DJ, et al. Validity of depression rating scales during pregnancy and the postpartum period: impact of trimester and parity. J Psychiatr Res. 2011;45(2):213-9. [pmid: 20542520].
Kersting A, Kroker K, Steinhard J, et al. Complicated grief after traumatic loss: A 14-month follow up study. Eur Arch Psychiatry Clin Neurosci. 2007;257(8):437-43. [pmid: 17629729].
Leung SS, Leung C, Lam TH, et al. Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292-301. [pmid: 20884642].
Mann R, Adamson J, Gilbody SM. Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. 2012;184(8):E424-30. [pmid: 22451686].
e. Mauri M, Oppo A, Borri C, et al. SUICIDALITY in the perinatal period: comparison of two self-report instruments. Results from PND-ReScU. Arch Women Ment Health. 2012;15(1):39-47. [pmid: 22215284].
e. Mauri M, Oppo A, Montagnani MS, et al. Beyond “postpartum depressions”: specific anxiety diagnoses during pregnancy predict different outcomes: results from PND-ReScU. J Affect Disord. 2010;127(1–3):177-84. [pmid: 20554326].
Morrell CJ, Slade P, Warner R, et al. Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: Pragmatic cluster randomised trial in primary care. BMJ. 2009;338(7689):276-9.
Navarro P, Ascaso C, Garcia-Esteve L, et al. Postnatal psychiatric morbidity: a validation study of the GHQ-12 and the EPDS as screening tools. Gen Hosp Psychiatry. 2007;29(1):1-7. [pmid: 17189737].
Pereira AT, Bos S, Marques M, et al. The Portuguese version of the postpartum depression screening scale. J Psychosom Obstet Gynaecol. 2010;31(2):90-100. [pmid: 20443658].
Rowan P, Greisinger A, Brehm B, et al. Outcomes from implementing systematic antepartum depression screening in obstetrics. Arch Women Ment Health. 2012;15(2):115-20. [pmid: 22382279].
Siu BWM, Leung SSL, Ip P, et al. Antenatal risk factors for postnatal depression: A prospective study of chinese women at maternal and child health centres. BMC Psychiatry. 2012;12(22).
Turner K, Piazzini A, Franza A, et al. Epilepsy and postpartum depression. Epilepsia. 2009;50(Suppl 1):24-7. [pmid: 19125843].
*. Turner K, Piazzini A, Franza A, et al. Postpartum depression in women with epilepsy versus women without epilepsy. Epilepsy Behav. 2006;9:293-7. [pmid: 16861045].
Verkerk GJ, Denollet J, Van Heck GL, et al. Personality factors as determinants of depression in postpartum women: a prospective 1-year follow-up study. Psychosom Med. 2005;67(4):632-7. [pmid: 16046379].
Yawn BP, Dietrich AJ, Wollan P, et al. TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Ann Fam Med. 2012;10(4):320-9. [pmid: 22778120].
Yonkers KA, Smith MV, Lin H, et al. Depression screening of perinatal women: an evaluation of the healthy start depression initiative. Psychiatr Serv. 2009;60(3):322-8. [pmid: 19252044].
Zlotnick C, Miller IW, Pearlstein T, et al. A preventive intervention for pregnant women on public assistance at risk for postpartum depression. J Psychiatry. 2006;163(8):1443-5. [pmid: 16877662].