# Data Abstraction Elements

## Study Characteristics

- Study Identifiers
  ○ Study Name or Acronym
  ○ Last name of first author
  ○ Publication year
- Additional Articles Used in This Abstraction
- Study Dates
  ○ Enrollment start (Mon and YYYY)
  ○ Enrollment end (Mon and YYYY)
  ○ Follow-up end (Mon and YYYY)
- Study Sites
  ○ Single Center, Multicenter, Unclear/Not reported
  ○ Number of sites
- Geographic Location (Select all that apply)
  ○ US, Canada, UK, Europe, S. America, C. America, Asia, Africa, Australia/NZ, Unclear/Not reported, Other (specify)
- Study Design
  ○ Prospective RCT
  ○ Prospective cohort
  ○ Retrospective cohort
  ○ Case-control
  ○ Cross-sectional
  ○ Pre-post-intervention
  ○ Other (specify)
- Funding Source (Select all that apply)
  ○ Government, Industry, Non-government/non-industry, Unclear/Not reported, Other (specify)
- Setting (Select all that apply)
  ○ Prenatal care, Hospital, Birthing Center, Home, Short-term postpartum follow-up, Well-child visit, Unclear/Not reported, Other (specify)
- Provider (Select all that apply)
  ○ Obstetricians, Family practitioners, Nurse-midwives, Mental health professionals, Lactation consultants, Social workers, Behavioral health specialists, Unclear/Not reported, Other (specify)
- Enrollment Approach (Select all that apply)
  ○ Consecutive patients, Convenience sample (not explicitly consecutive), Unclear/Not reported, Other (specify)
- Study Inclusion and Exclusion Criteria
  ○ Copy/paste inclusion and exclusion criteria as reported
  ○ Is the study entirely composed of participants with any of the following characteristics/conditions? If all participants fall into more than one category, select all that apply.
    ■ Specific race or ethnicity (specify)
    ■ Specific socioeconomic category (specify)
    ■ Specific parity (specify)
    ■ Specific cultural consideration (specify)
    ■ History of mood disorders
    ■ All participants with normal perinatal outcome
    ■ All participants with preterm perinatal outcome
    ■ All participants with stillbirth perinatal outcome
    ■ History of intimate partner violence
    ■ None of the above
- Study Enrollment/Study Completion
  ○ Number of participants (N) assessed for eligibility
  ○ N eligible
  ○ N enrolled/included
  ○ N completed follow-up (most distal time point of the primary outcome)
  ○ N analyzed for primary outcome
- Key Question Applicability (Select all that apply)
  ○ KQ 1: KQ 1a, KQ 1b
  ○ KQ 2: KQ 2a, KQ 2b
  ○ KQ 3: KQ 3a, KQ 3b, KQ 3c
  ○ KQ 4
  ○ KQ 5
  ○ KQ 6
- Comments

Screening Intervention Characteristics – Record the following elements for participants in Group 1, Group 2, Group 3, and Group 4 (as applicable)

- Screening Instrument
  ○ Edinburgh Postnatal Depression Scale (EPDS)
  ○ Beck Depression Inventory (BDI-IA)
  ○ Beck Depression Inventory (BDI-II)
  ○ Center for Epidemiologic Studies Depression Scale (CES-D)
  ○ General Health Questionnaire (GHQ-D)
  ○ Postpartum Depression Screening Scale (PDSS)
  ○ Hamilton Rating Scale for Depression (HRSD)
  ○ Zung Self-Rating Depression Scale (Zung SDS)
  ○ Patient Health Questionnaire-9 (PHQ-9)
  ○ Primary Care Evaluation of Mental Disorders Patient Health Questionnaire (PRIME-MD PHQ)
  ○ Leverton Questionnaire (LQ)
  ○ Hospital Anxiety and Depression Scale (HADS)
  ○ Postpartum Depression Predictors Inventory-Revised (PDPI-R)
  ○ Montgomery Asberg Depression Rating Scale (MADRS)
  ○ Patient Health Questionnaire-2 (PHQ-2)
  ○ Bromley Postnatal Depression Scale (BPDS)
  ○ Generalized Contentment Scale (GCS)
  ○ Other (specify)
- Threshold for Positive Result
- Timing of Screening
  ○ Prenatal period
  ○ Perinatal (from admission for delivery to discharge)
  ○ Discharge to 8 weeks postpartum
  ○ >8 weeks to 12 months postpartum
- Setting
  ○ Prenatal care
  ○ Hospital
  ○ Birthing Center
  ○ Home
  ○ Short-term postpartum followup
  ○ Well-child visit
  ○ Unclear/Not reported
  ○ Other (specify)
- Provider
  ○ Obstetricians
  ○ Family practitioners
  ○ Nurse-midwives
  ○ Mental health professionals
  ○ Lactation consultants
  ○ Social workers
  ○ Behavioral health specialists
  ○ Unclear/Not reported
  ○ Other (specify)
- Intervention Descriptors
  ○ Describe the intervention received by participants in each group (Groups 1, 2, 3, and 4, as applicable).
- Diagnosis of Depression and Receipt of Services
  ○ N with a positive screening test
  ○ N referred for diagnostic evaluation
  ○ N who received a diagnostic evaluation
  ○ N with a true positive diagnosis
  ○ N with a diagnostic referral for treatment
  ○ N treated
- Specify the validated instrument used for diagnosis of depression

Baseline Population – Record the following elements for Total Population, Group 1, Group 2, Group 3, and Group 4 (as applicable)

- Number of participants in each group
- Gender
  ○ Female N
  ○ Male N
- Ethnicity
  ○ Hispanic or Latino
  ○ Not Hispanic or Latino
- Race
  ○ American Indian or Alaska Native
  ○ Asian
  ○ Black or African American
  ○ Native Hawaiian or other Pacific Islander
  ○ White
  ○ Multiracial
  ○ Other
- Age
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ Min age
  ○ Max age
  ○ 25% IQR
  ○ 75% IQR
  ○ Categorical (specify distribution)
- Education
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)
- Language – Record N and % for the following:
  ○ English
  ○ Spanish
  ○ Other language (specify)
- Immigration
  ○ Native-born
    ■ N
    ■ %
  ○ Immigrant
    ■ N
    ■ %
  ○ Describe immigrant population
- Income (specify units)
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)
- Socioeconomic Status (specify units)
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)
- Social Support (specify units)
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)
- Marital Status – Record N and % for the following:
  ○ Married/Domestic Partnership
  ○ Unmarried
  ○ Other (specify)
- Perinatal Outcomes – Record N and % for the following:
  ○ Normal
  ○ Preterm
  ○ Stillbirth
  ○ Other (specify)
- Parity
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)
- History of Mood Disorders
  ○ N
  ○ %
- History of Intimate Partner Violence
  ○ N
  ○ %
- Breastfeeding
  ○ Yes: N, %
  ○ No: N, %
- Breastfeeding Duration
  ○ Mean
  ○ Median
  ○ Standard Deviation
  ○ Standard Error
  ○ IQR
  ○ Categorical (specify distribution)

## Patient-Centered Outcomes

- Select the outcome reported on this form:
  ○ Receipt of appropriate diagnostic and treatment services for symptoms of depression
  ○ Scores on validated measures of maternal well-being and parenting
  ○ Breastfeeding
  ○ Scores on validated diagnostic instruments for depression
  ○ Health-related quality of life, based on validated measures
  ○ Maternal suicidal/infanticidal behaviors
  ○ Scores on validated instruments of infant health and development
  ○ Maternal health system resource utilization, including number of visits and estimates of total and attributable costs
  ○ Infant health system resource utilization, including number of visits and estimates of total and attributable costs
  ○ Paternal outcomes, including scores on validated mental health instruments, health-related quality of life, and health system resource utilization
  ○ Scores on validated measures of stigmatization
  ○ Composite (report only if composed entirely of outcomes listed above)
  ○ No patient-centered outcomes of interest reported
- Additional details to describe outcome measure
- Time points to be abstracted (check all that apply)
  ○ Delivery
  ○ Discharge to 8 weeks postpartum
  ○ Close to 6 months
  ○ Close to 1 year
  ○ Most distal time point after one year
- For each time point, record the following elements, as applicable:
  ○ Specify actual timing of outcome (include units)
  ○ Group: 1, 2, 3, 4
  ○ N Analyzed (enter UNK if unknown)
  ○ Unadjusted Result
    ■ Mean
    ■ Median
    ■ Mean within group change
    ■ Mean between group change
    ■ Number of patients with outcome
    ■ % of patients with outcome
    ■ Events/denominator
    ■ Odds ratio
    ■ Hazard ratio
    ■ Relative risk
    ■ Other (specify)
  ○ Unadjusted Result Variability
    ■ Standard Error (SE)
    ■ Standard Deviation (SD)
    ■ IQR
    ■ 95% CI
    ■ Other % CI (specify)
    ■ Other (specify)
  ○ Unadjusted Result, p-value between groups
  ○ Unadjusted Result, Reference group (for comparison between groups)
  ○ Adjusted Result
    ■ Mean
    ■ Median
    ■ Mean within group change
    ■ Mean between group change
    ■ Number of patients with outcome
    ■ % of patients with outcome
    ■ Events/denominator
    ■ Odds ratio
    ■ Hazard ratio
    ■ Relative risk
    ■ Other (specify)
  ○ Adjusted Result Variability
    ■ Standard Error (SE)
    ■ Standard Deviation (SD)
    ■ IQR
    ■ 95% CI
    ■ Other % CI (specify)
    ■ Other (specify)
  ○ Adjusted Result, p-value between groups
  ○ Adjusted Result, Reference group (for comparison between groups)
  ○ If adjusted data is recorded, indicate the adjustments applied
- Does the study report any subgroup analyses for this outcome? (Yes/No)
  ○ If Yes, describe the subgroup analyses and summarize results
- Comments

## Screening Instrument Performance

- Screening Test 1
  ○ Edinburgh Postnatal Depression Scale (EPDS)
  ○ Beck Depression Inventory (BDI or BDI-IA)
  ○ Beck Depression Inventory (BDI-II)
  ○ Center for Epidemiologic Studies Depression Scale (CES-D)
  ○ General Health Questionnaire (GHQ-D)
  ○ Postpartum Depression Screening Scale (PDSS)
  ○ Hamilton Rating Scale for Depression (HRSD)
  ○ Zung Self-Rating Depression Scale (Zung SDS)
  ○ Patient Health Questionnaire-9 (PHQ-9)
  ○ Primary Care Evaluation of Mental Disorders Patient Health Questionnaire (PRIME-MD PHQ)
  ○ Leverton Questionnaire (LQ)
  ○ Hospital Anxiety and Depression Scale (HADS)
  ○ Postpartum Depression Predictors Inventory-Revised (PDPI-R)
  ○ Montgomery Asberg Depression Rating Scale (MADRS)
  ○ Patient Health Questionnaire-2 (PHQ-2)
  ○ Bromley Postnatal Depression Scale (BPDS)
  ○ Generalized Contentment Scale (GCS)
  ○ Other (specify)
- Screening Test 1 Positive Threshold
- Screening Test 2
  ○ Edinburgh Postnatal Depression Scale (EPDS)
  ○ Beck Depression Inventory (BDI-IA)
  ○ Beck Depression Inventory (BDI-II)
  ○ Center for Epidemiologic Studies Depression Scale (CES-D)
  ○ General Health Questionnaire (GHQ-D)
  ○ Postpartum Depression Screening Scale (PDSS)
  ○ Hamilton Rating Scale for Depression (HRSD)
  ○ Zung Self-Rating Depression Scale (Zung SDS)
  ○ Patient Health Questionnaire-9 (PHQ-9)
  ○ Primary Care Evaluation of Mental Disorders Patient Health Questionnaire (PRIME-MD PHQ)
  ○ Leverton Questionnaire (LQ)
  ○ Hospital Anxiety and Depression Scale (HADS)
  ○ Postpartum Depression Predictors Inventory-Revised (PDPI-R)
  ○ Montgomery Asberg Depression Rating Scale (MADRS)
  ○ Patient Health Questionnaire-2 (PHQ-2)
  ○ Bromley Postnatal Depression Scale (BPDS)
  ○ Generalized Contentment Scale (GCS)
  ○ Other (specify)
  ○ None
- Screening Test 2 Positive Threshold
- Diagnostic Test
  ○ DSM-IV-TR criteria
  ○ Research Diagnostic Criteria (RDC)
  ○ Bedford College Checklist
  ○ International Classification of Diseases (ICD)
  ○ Structured Clinical Interview for Depression (SCID)
  ○ Diagnostic Interview Schedule (DIS)
  ○ Schedule for Affective Disorders and Schizophrenia (SADS)
  ○ Goldberg's Standardized Psychiatric Interview (SPI)
  ○ Other (specify)
- Diagnostic Test Positive Threshold
- Briefly describe the definition of postpartum depression used for each screening tool.
- List any other comparisons reported between different thresholds.
- Does this data represent a predictive model or algorithm? (Yes/No)
  ○ If Yes:
    ■ Describe the model/algorithm.
    ■ Capture the data for the model/algorithm in the tables below or following text box.
- Sensitivity/Specificity Data – Record the following elements for Total Population, Group 1, Group 2, Group 3, and Group 4 (as applicable)
  ○ Participant Data
    ■ Number of participants who received screening test 1
    ■ Number of participants who refused screening test 1
    ■ Number of participants with positive screening test 1
    ■ Number of participants with negative screening test 1
    ■ Number of participants who received screening test 2
    ■ Number of participants who refused screening test 2
    ■ Number of participants with positive screening test 2
    ■ Number of participants with negative screening test 2
    ■ Number of participants who received the diagnostic test
    ■ Number of participants who refused the diagnostic test
    ■ Disease prevalence (N of participants)
    ■ Disease prevalence (% of participants)
  ○ Screening Tool Results (recorded separately for screening tool 1 and screening tool 2)
    ■ True positive (N)
    ■ True negative (N)
    ■ False positive (N)
    ■ False negative (N)
    ■ Indeterminate or technically inadequate results (N)
    ■ Sensitivity (%)
    ■ Sensitivity (Standard deviation)
    ■ Sensitivity (Confidence interval range)
      - 95% CI
      - Other (specify)
    ■ Specificity (%)
    ■ Specificity (Standard deviation)
    ■ Specificity (Confidence interval range)
      - 95% CI
      - Other (specify)
    ■ Positive predictive value (%)
    ■ Positive predictive value (Standard deviation)
    ■ Positive predictive value (Confidence interval range)
      - 95% CI
      - Other (specify)
    ■ Negative predictive value (%)
    ■ Negative predictive value (Standard deviation)
    ■ Negative predictive value (Confidence interval range)
      - 95% CI
      - Other (specify)
  ○ Enter any pertinent information that cannot be captured in the tables above.
- Additional Questions
  ○ Were both the screening test and diagnostic test done on all subjects? (Yes, No, or Unclear/Not reported)
  ○ What was the time interval between the screening test and the diagnostic test?
  ○ Was the screening test interpreted in a blinded fashion without knowledge of results of other diagnostic tests or clinical history and risk factors? (Yes, No, or Unclear/Not reported)
  ○ Was the diagnostic test interpreted in a blinded fashion without knowledge of results of other diagnostic tests or clinical history and risk factors? (Yes, No, or Unclear/Not reported)
  ○ Describe any paternal outcomes reported.

## Quality

- Did the study present clinical outcomes? (Yes/No)
  ○ If Yes, select the study type: RCT, Cohort or Pre-post, Case-control, Cross sectional
  ○ If RCT, select Yes/No/Unclear for each of the following questions:
    ■ Selection Bias
      - Was the allocation sequence generated adequately (e.g., random number table, computer-generated randomization)?
      - Was the allocation of treatment adequately concealed (e.g., pharmacy-controlled randomization or use of sequentially numbered sealed envelopes)?
      - Were participants analyzed within the groups they were originally assigned to?
      - Does the design or analysis control account for important confounding and modifying variables through matching, stratification, multivariable analysis, or other approaches?
    ■ Performance Bias
      - Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
      - Did the study maintain fidelity to the intervention protocol?
    ■ Attrition Bias
      - If attrition (overall or differential nonresponse, dropout, loss to follow-up, or exclusion of participants) was a concern, were missing data handled appropriately (e.g., intention-to-treat analysis and imputation)?
    ■ Detection Bias
      - In prospective studies, was the length of follow-up different between the groups, or in case-control studies, was the time period between the intervention/exposure and outcome different for cases and controls?
      - Were the outcome assessors blinded to the intervention or exposure status of participants?
      - Were interventions/exposures assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were outcomes assessed/defined using valid and reliable measures, implemented consistently across all study participants?
    ■ Reporting Bias
      - Were the potential outcomes prespecified by the researchers? Are all prespecified outcomes reported?
  ○ If Cohort or Pre-post, select Yes/No/Unclear for each of the following questions:
    ■ Selection Bias
      - Were participants analyzed within the groups they were originally assigned to?
      - Did the study apply inclusion/exclusion criteria uniformly to all comparison groups?
      - Did the strategy for recruiting participants into the study differ across study groups?
      - Does the design or analysis control account for important confounding and modifying variables through matching, stratification, multivariable analysis, or other approaches?
    ■ Performance Bias
      - Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
      - Did the study maintain fidelity to the intervention protocol?
    ■ Attrition Bias
      - If attrition (overall or differential nonresponse, dropout, loss to follow-up, or exclusion of participants) was a concern, were missing data handled appropriately (e.g., intention-to-treat analysis and imputation)?
    ■ Detection Bias
      - In prospective studies, was the length of follow-up different between the groups, or in case-control studies, was the time period between the intervention/exposure and outcome different for cases and controls?
      - Were the outcome assessors blinded to the intervention or exposure status of participants?
      - Were interventions/exposures assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were outcomes assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were confounding variables assessed using valid and reliable measures, implemented consistently across all study participants?
    ■ Reporting Bias
      - Were the potential outcomes prespecified by the researchers? Are all prespecified outcomes reported?
  ○ If Case-control, select Yes/No/Unclear for each of the following questions:
    ■ Selection Bias
      - Were cases and controls selected appropriately (e.g., appropriate diagnostic criteria or definitions, equal application of exclusion criteria to case and controls, sampling not influenced by exposure status)
      - Does the design or analysis control account for important confounding and modifying variables through matching, stratification, multivariable analysis, or other approaches?
    ■ Performance Bias
      - Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
      - Did the study maintain fidelity to the intervention protocol?
    ■ Attrition Bias
      - If attrition (overall or differential nonresponse, dropout, loss to follow-up, or exclusion of participants) was a concern, were missing data handled appropriately (e.g., intention-to-treat analysis and imputation)?
    ■ Detection Bias
      - In prospective studies, was the length of follow-up different between the groups, or in case-control studies, was the time period between the intervention/exposure and outcome different for cases and controls?
      - Were the outcome assessors blinded to the intervention or exposure status of participants?
      - Were interventions/exposures assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were outcomes assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were confounding variables assessed using valid and reliable measures, implemented consistently across all study participants?
    ■ Reporting Bias
      - Were the potential outcomes prespecified by the researchers? Are all prespecified outcomes reported?
  ○ If Cross-sectional, select Yes/No/Unclear for each of the following questions:
    ■ Selection Bias
      - Did the study apply inclusion/exclusion criteria uniformly to all comparison groups?
      - Does the design or analysis control account for important confounding and modifying variables through matching, stratification, multivariable analysis, or other approaches?
    ■ Performance Bias
      - Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
    ■ Attrition Bias
      - If attrition (overall or differential nonresponse, dropout, loss to follow-up, or exclusion of participants) was a concern, were missing data handled appropriately (e.g., intention-to-treat analysis and imputation)?
    ■ Detection Bias
      - Were the outcome assessors blinded to the intervention or exposure status of participants?
      - Were interventions/exposures assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were outcomes assessed/defined using valid and reliable measures, implemented consistently across all study participants?
      - Were confounding variables assessed using valid and reliable measures, implemented consistently across all study participants?
    ■ Reporting Bias
      - Were the potential outcomes prespecified by the researchers? Are all prespecified outcomes reported?
  ○ Other Bias
    ■ If applicable, describe any other concerns that may impact risk of bias.
  ○ Overall Study Rating (Good/Fair/Poor)
    ■ Good (low risk of bias). These studies have the least bias, and the results are considered valid. These studies adhere to the commonly held concepts of high quality, including the following: a clear description of the population, setting, approaches, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytical methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
    ■ Fair. These studies are susceptible to some bias, but not enough to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
    ■ Poor (high risk of bias). These studies have significant flaws that may have invalidated the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.
    ■ If the study is rated as “Fair” or “Poor,” provide rationale.
- Did the study present diagnostic data? (Yes/No)
- If Yes, indicate Yes/No/Unclear for each of the following questions:
  ○ Signaling questions
    ■ Patient Selection
      - Was a consecutive or random sample of patients enrolled?
      - Was a case-control design avoided?
      - Did the study avoid inappropriate exclusions?
    ■ Index Test
      - Were the index test results interpreted without knowledge of the results of the reference standard?
      - If a threshold was used, was it pre-specified?
    ■ Reference Standard
      - Is the reference standard likely to correctly classify the target condition?
      - Were the reference standard results interpreted without knowledge of the results of the index test?
    ■ Flow & Timing
      - Was there an appropriate interval between index test(s) and reference standard?
      - Did all patients receive a reference standard?
      - Did all patients receive the same reference standard?
      - Were all patients included in the analysis?
  ○ Risk of bias
    ■ Patient Selection
      - Could the selection of patients have introduced bias?
    ■ Index Test
      - Could the conduct or interpretation of the index test have introduced bias?
    ■ Reference Standard
      - Could the reference standard, its conduct or its interpretation have introduced bias?
    ■ Flow & Timing
      - Could the patient flow have introduced bias?
  ○ Concerns regarding applicability
    ■ Patient Selection
      - Are there concerns that the included patients do not match the review question?
    ■ Index Test
      - Are there concerns that the index test, its conduct, or interpretation differ from the review question?
    ■ Reference Standard
      - Are there concerns that the target condition as defined by the reference standard does not match the review question?
- Overall study rating
  ○ High risk of bias/Low risk of bias/Unclear
- Comments

Applicability – Use the PICOS format to identify specific issues, if any, which may limit the applicability of the study to this review.

- Population (P)
  ○ Narrow eligibility criteria and exclusion of those with comorbidities
  ○ Large differences between demographics of study population and community patients
  ○ Narrow or unrepresentative severity, stage of illness, or comorbidities
  ○ Run-in period with high-exclusion rate for non-adherence or side effects
  ○ Event rates much higher or lower than observed in population-based studies
- Intervention (I)
  ○ Doses or schedules not reflected in current practice
  ○ Intensity and delivery of behavioral interventions that may not be feasible for routine use
  ○ Monitoring practices or visit frequency not used in typical practice
  ○ Older versions of an intervention no longer in common use
  ○ Co-interventions that are likely to modify effectiveness of therapy
  ○ Highly selected intervention team or level of training/proficiency not widely available
- Comparator (C)
  ○ Inadequate comparison therapy
  ○ Use of substandard alternative therapy
- Outcomes (O)
  ○ Composite outcomes that mix outcomes of difference significance
  ○ Short-term or surrogate outcomes
- Setting (S)
  ○ Standards of care differ markedly from setting of interest
  ○ Specialty population or level of care differs from that seen in community
- Comments