# Exact Search Strings

## PubMed^®^ Search Strategy (July 24, 2012)

Set # | Terms
#1 | “Maternal Health Services”[Mesh] OR “Pregnancy”[Mesh] OR “Pregnant Women”[Mesh] OR Puerperal Disorders[Mesh] OR prenatal[tiab] OR perinatal[tiab] OR postnatal[tiab] OR pregnancy[tiab] OR pregnant[tiab] OR postpartum[tiab] OR post-partum[tiab]
#2 | Depression[Mesh] OR Depressive Disorder[Mesh] OR depression[tiab]
#3 | #1 AND #2
#4 | postpartum period/psychology[mesh] OR depression, postpartum[mesh]
#5 | #3 OR #4
#6 | postpartum depression/diagnosis[mesh] OR mass screening[mesh] OR questionnaires[mesh] OR Interviews as Topic[Mesh] OR Psychometrics[Mesh] OR Psychiatric Status Rating Scales[Mesh] OR questionnaire[tiab] OR questionnaires[tiab] OR screening[tiab] OR screen[tiab] OR scale[tiab] OR instrument[tiab] OR instruments[tiab] OR EPDS[tiab] OR “Edinburgh postnatal depression”[tiab] OR BDI[tiab] OR “beck depression inventory”[tiab] OR PDSS[tiab] OR “Postpartum Depression Screening Scale”[tiab] OR BPDS[tiab] OR “Bromley Postnatal Depression Scale”[tiab] OR LQ[tiab] OR “Leverton Questionnaire”[tiab] OR CES-D[tiab] OR “Center for Epidemiologic Studies Depression Scale”[tiab] OR HADS[tiab] OR “Hospital Anxiety and Depression Scale”[tiab] OR PHQ-9[tiab] OR “Patient Health Questionnaire-9”[tiab] OR “Zung SDS”[tiab] OR “Zung Self-Rating Depression Scale”[tiab] OR HRSD[tiab] OR “Hamilton Rating Scale for Depression”[tiab] OR PDPI-R[tiab] OR “Postpartum Depression Predictors Inventory-Revised”[tiab] OR GHQ-D[tiab] OR “General Health Questionnaire”[tiab] OR MADRS[tiab] OR “Montgomery Asberg Depression Rating Scale”[tiab] OR “generalized contentment scale”[tiab] OR “patient health questionnaire-2”[tiab] OR “phq-2”[tiab] OR “primary care evaluation of mental disorders patient health questionnaire”[tiab] OR “prime-md phq”[tiab]
#7 | #5 AND #6
#8 | #7 NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh])
#9 | #8 Limits: English, 2004 - present

## PsycINFO^®^ Search Strategy (July 24, 2012)

Set # | Terms
S1 | ((DE “Prenatal Care”) OR (DE “Pregnancy” OR DE “Adolescent Pregnancy”)) OR (DE “Birth” OR DE “Natural Childbirth” OR DE “Premature Birth”) OR TI ( prenatal OR perinatal OR postnatal OR pregnancy OR pregnant OR postpartum OR post-partum ) OR AB ( prenatal OR perinatal OR postnatal OR pregnancy OR pregnant OR postpartum OR post-partum )
S2 | (DE “Depression (Emotion)”) OR (DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Postpartum Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression”) OR TI depression OR AB depression
S3 | S1 AND S2
S4 | DE “Postpartum Depression” OR DE “Postpartum Psychosis”
S5 | S3 OR S4
S6 | DE “Screening” OR DE “Screening Tests” OR DE “Psychological Screening Inventory” OR DE “Rating Scales” OR DE “Inventories” OR DE “Psychological Assessment” OR DE “Psychodiagnosis” OR DE “Psychodiagnostic Interview” OR DE “Questionnaires” OR DE “General Health Questionnaire” OR ((DE “Beck Depression Inventory”) OR (DE “Zungs Self Rating Depression Scale”)) OR TI ( questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR EPDS OR “Edinburgh postnatal depression” OR BDI OR “beck depression inventory” OR PDSS OR “Postpartum Depression Screening Scale” OR BPDS OR “Bromley Postnatal Depression Scale” OR LQ OR “Leverton Questionnaire” OR CES-D OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR “Patient Health Questionnaire-9” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR HRSD OR “Hamilton Rating Scale for Depression” OR PDPI-R OR “Postpartum Depression Predictors Inventory-Revised” OR GHQ-D OR “General Health Questionnaire” OR MADRS OR “Montgomery Asberg Depression Rating Scale” ) OR AB ( questionnaire OR questionnaires OR screening OR screen OR scale OR instrument OR instruments OR EPDS OR “Edinburgh postnatal depression” OR BDI OR “beck depression inventory” OR PDSS OR “Postpartum Depression Screening Scale” OR BPDS OR “Bromley Postnatal Depression Scale” OR LQ OR “Leverton Questionnaire” OR CES-D OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR “Patient Health Questionnaire-9” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR HRSD OR “Hamilton Rating Scale for Depression” OR PDPI-R OR “Postpartum Depression Predictors Inventory-Revised” OR GHQ-D OR “General Health Questionnaire” OR MADRS OR “Montgomery Asberg Depression Rating Scale” OR “generalized contentment scale” OR “patient health questionnaire-2” OR “phq-2” OR “primary care evaluation of mental disorders patient health questionnaire” OR “prime-md phq” )
S7 | S5 AND S6
S8 | S7 Limits: Document Type: Abstract Collection, Bibliography, Chapter, Column/Opinion, Comment/Reply, Dissertation, Editorial, Encyclopedia Entry, Erratum/Correction, Letter, Obituary, Publication Information, Reprint, Review-Book, Review-Media, Review-Software & Other
S9 | S7 NOT S8
S10 | S9, Limits: - Publication Year from: 2004-; Publication Type: All Journals; Language: English; Population Group: Human

## Embase^®^ Search Strategy (July 24, 2012)

Platform: Embase.com

Set # | Terms
#1 | ‘obstetric care’/exp OR ‘pregnancy’/exp OR ‘puerperal disorder’/exp OR prenatal:ab,ti OR perinatal:ab,ti OR postnatal:ab,ti OR pregnancy:ab,ti OR pregnant:ab,ti OR postpartum:ab,ti OR post-partum:ab,ti
#2 | ‘depression’/exp OR depression:ab,ti
#3 | #1 AND #2
#4 | ‘puerperal depression’/exp
#5 | #3 OR #4
#6 | ‘puerperal depression’/exp/dm_di OR ‘screening’/exp OR ‘questionnaire’/exp OR ‘interview’/exp OR ‘Edinburgh Postnatal Depression Scale’/exp OR ‘Beck Depression Inventory’/exp OR ‘Center for Epidemiological Studies Depression Scale’/exp OR ‘Hospital Anxiety and Depression Scale’/exp OR ‘General Health Questionnaire’/exp OR ‘Montgomery Asberg Depression Rating Scale’/exp OR ‘psychometry’/exp OR ‘psychological rating scale’/exp OR questionnaire:ab,ti OR questionnaires:ab,ti OR screening:ab,ti OR screen:ab,ti OR scale:ab,ti OR instrument:ab,ti OR instruments:ab,ti OR EPDS:ab,ti OR “Edinburgh postnatal depression”:ab,ti OR BDI:ab,ti OR “beck depression inventory”:ab,ti OR PDSS:ab,ti OR “Postpartum Depression Screening Scale”:ab,ti OR BPDS:ab,ti OR “Bromley Postnatal Depression Scale”:ab,ti OR LQ:ab,ti OR “Leverton Questionnaire”:ab,ti OR “CES D”:ab,ti OR “Center for Epidemiologic Studies Depression Scale”:ab,ti OR HADS:ab,ti OR “Hospital Anxiety and Depression Scale”:ab,ti OR PHQ-9:ab,ti OR “Patient Health Questionnaire 9”:ab,ti OR “Zung SDS”:ab,ti OR “Zung Self Rating Depression Scale”:ab,ti OR HRSD:ab,ti OR “Hamilton Rating Scale for Depression”:ab,ti OR PDPI-R:ab,ti OR “Postpartum Depression Predictors Inventory Revised”:ab,ti OR “GHQ D”:ab,ti OR “General Health Questionnaire”:ab,ti OR MADRS:ab,ti OR “Montgomery Asberg Depression Rating Scale”:ab,ti OR “generalized contentment scale”:ab,ti OR “patient health questionnaire 2”:ab,ti OR “phq 2”:ab,ti OR “primary care evaluation of mental disorders patient health questionnaire”:ab,ti OR “prime md phq”:ab,ti
#7 | #5 AND #6
#8 | #7 AND [embase]/lim NOT [medline]/lim
#9 | #8 NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#10 | #9 AND [humans]/lim AND [english]/lim, 2004 - present

## Cochrane Search Strategy (July 24, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

Set # | Terms
#1 | MeSH descriptor Maternal Health Services explode all trees OR MeSH descriptor Pregnancy explode all trees OR MeSH descriptor Pregnant Women explode all trees OR MeSH descriptor Puerperal Disorders explode all trees OR prenatal:ti,ab OR perinatal:ti,ab OR postnatal:ti,ab OR pregnancy:ti,ab OR pregnant:ti,ab OR postpartum:ti,ab OR post-partum:ti,ab
#2 | MeSH descriptor Depression explode all trees OR MeSH descriptor Depressive Disorder explode all trees OR depression:ti,ab
#3 | #1 AND #2
#4 | MeSH descriptor Postpartum Period explode all trees with qualifier: PX OR MeSH descriptor Depression, Postpartum explode all trees
#5 | #3 OR #4
#6 | MeSH descriptor Depression, Postpartum explode all trees with qualifier: DI OR MeSH descriptor Mass Screening explode all trees OR MeSH descriptor Questionnaires explode all trees OR MeSH descriptor Interviews as Topic explode all trees OR MeSH descriptor Psychometrics explode all trees OR MeSH descriptor Psychiatric Status Rating Scales explode all trees OR questionnaire:ti,ab OR questionnaires:ti,ab OR screening:ti,ab OR screen:ti,ab OR scale:ti,ab OR instrument:ti,ab OR instruments:ti,ab OR EPDS:ti,ab OR “Edinburgh postnatal depression”:ti,ab OR BDI:ti,ab OR “beck depression inventory”:ti,ab OR PDSS:ti,ab OR “Postpartum Depression Screening Scale”:ti,ab OR BPDS:ti,ab OR “Bromley Postnatal Depression Scale”:ti,ab OR LQ:ti,ab OR “Leverton Questionnaire”:ti,ab OR CES-D:ti,ab OR “Center for Epidemiologic Studies Depression Scale”:ti,ab OR HADS:ti,ab OR “Hospital Anxiety and Depression Scale”:ti,ab OR PHQ-9:ti,ab OR “Patient Health Questionnaire-9”:ti,ab OR “Zung SDS”:ti,ab OR “Zung Self-Rating Depression Scale”:ti,ab OR HRSD:ti,ab OR “Hamilton Rating Scale for Depression”:ti,ab OR PDPI-R:ti,ab OR “Postpartum Depression Predictors Inventory-Revised”:ti,ab OR GHQ-D:ti,ab OR “General Health Questionnaire”:ti,ab OR MADRS:ti,ab OR “Montgomery Asburg Depression Rating Scale”:ti,ab OR “generalized contentment scale”:ti,ab OR “patient health questionnaire-2”:ti,ab OR “phq-2”:ti,ab OR “primary care evaluation of mental disorders patient health questionnaire”:ti,ab OR “prime-md phq”:ti,ab
#7 | #5 AND #6
#8 | #7, limit to Cochrane Database of Systematic Reviews, 2004 - present

## Grey Literature Searches

### ProQuest COS Conference Papers Index (July 24, 2012)

Set # | Terms
#1 | all(“Maternal Health Services” OR Puerperal OR prenatal OR perinatal OR postnatal OR pregnancy OR pregnant OR postpartum OR post-partum)
#2 | All(Depression)
#3 | #1 AND #2
#4 | all(diagnosis OR questionnaires OR Interviews OR Psychometrics OR questionnaire OR screening OR screen OR scale OR instrument OR instruments OR EPDS OR “Edinburgh postnatal depression” OR BDI OR “beck depression inventory” OR PDSS OR “Postpartum Depression Screening Scale” OR BPDS OR “Bromley Postnatal Depression Scale” OR LQ OR “Leverton Questionnaire” OR CES-D OR “Center for Epidemiologic Studies Depression Scale” OR HADS OR “Hospital Anxiety and Depression Scale” OR PHQ-9 OR “Patient Health Questionnaire-9” OR “Zung SDS” OR “Zung Self-Rating Depression Scale” OR HRSD OR “Hamilton Rating Scale for Depression” OR PDPI-R OR “Postpartum Depression Predictors Inventory-Revised” OR GHQ-D OR “General Health Questionnaire” OR MADRS OR “Montgomery Asberg Depression Rating Scale” OR “generalized contentment scale” OR “patient health questionnaire-2” OR “phq-2” OR “primary care evaluation of mental disorders patient health questionnaire” OR “prime-md phq” )
#5 | #3 AND #4
#6 | #5, 2004 - present

### ClinicalTrials.gov (August 22, 2012)

Search strategy: postpartum depression [ALL-FIELDS]

Total number of results: 117

### WHO: International Clinical Trials Registry Platform Search Portal (August 22, 2012)

Search strategy: postpartum depression (standard search)

Total number of results: 93 records for 92 trials