# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BDI: Beck Depression Inventory
BDI-1A: Beck Depression Inventory-1A
BDI-II: Beck Depression Inventory-II
BPDS: Bromley Postnatal Depression Scale
BSID: Bayley Scales of Infant Development
CDSR: Cochrane Database of Systematic Reviews
CER: Comparative Effectiveness Review
CES-D: Center for Epidemiologic Studies Depression Scale
CI: confidence interval
DIS: Diagnostic Interview Schedule
DSM-IV-TR: Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, 5th Edition
EPC: Evidence-based Practice Center
EPDS: Edinburgh Postnatal Depression Scale
GHQ-D: General Health Questionnaire
GHQ-12: 12-Item General Health Questionnaire
HADS: Hospital Anxiety and Depression Scale
HRSD: Hamilton Rating Scale for Depression
HRSD-17: 17-Item Hamilton Rating Scale for Depression
HRSD-21: 21-Item Hamilton Rating Scale for Depression
ICD: International Classification of Diseases
ICTRP: International Clinical Trials Registry Platform
ISMI: Internalized Stigma of Mental Illness
KQ: Key Question
LQ: Leverton Questionnaire
MADRS: Montgomery Asberg Depression Rating Scale
MOODS-SR: Mood Spectrum Self-Report
NPV: negative predictive value
OR: odds ratio
PDPI-R: Postpartum Depression Predictors Inventory-Revised
PDSS: Postpartum Depression Screening Scale
PHQ-2: 2-Item Patient Health Questionnaire
PHQ-9: 9-Item Patient Health Questionnaire
PICOTS: Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest
PP-E: early postpartum period
PP-L: late postpartum period
PPV: positive predictive value
PRIME-MD CEG: Primary Care Evaluation of Mental Disorders Clinical Evaluation Guide
PRIME-MD PHQ: Primary Care Evaluation of Mental Disorders Patient Health Questionnaire
PRIME-MD PQ: Primary Care Evaluation of Mental Disorders Patient Questionnaire
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PSI: Parenting Stress Index
PSI-SF: Parenting Stress Index-Short Form
QALY: quality-adjusted life year
QUADAS-2: QUality Assessment of Diagnostic Accuracy Studies-2
RCT: randomized controlled trial
RDC: Research Diagnostic Criteria
ROC: receiver operating characteristic
RR: relative risk
SADS: Schedule for Affective Disorders and Schizophrenia
SCAN: Schedules for Clinical Assessment in Neuropsychiatry
SCID: Structured Clinical Interview for Depression
SF-36: Medical Outcomes Study 36-Item Short-Form Health Survey
SPI: Goldberg’s Standardized Psychiatric Interview
TEP: Technical Expert Panel
TOO: Task Order Officer
UK: United Kingdom
USPSTF: U.S. Preventive Services Task Force
WHO: World Health Organization
Zung SDS: Zung Self-Rating Depression Scale