# Results

## Introduction

In what follows, we begin by presenting the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each KQ, we begin by listing the key points of the findings, followed by a brief description of included studies, followed by a more detailed synthesis of the evidence. The detailed syntheses are organized by intervention and primary outcomes: cardiovascular risk factor, functional status or health-related quality of life, adverse effects and cardiovascular mortality. We conducted quantitative analyses (i.e., meta-analyses) where possible, as described in the Methods chapter. Results of these analyses are presented graphically in the form of forest plots. A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews yielded 5769 citations, 756 of which were duplicate citations. Manual searching identified 213 additional citations, for a total of 5226 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 179 full-text articles were retrieved and screened. Of these, 139 were excluded at the full-text screening stage, leaving 40 articles (representing 35 unique studies) for data abstraction. Note that many articles/studies were relevant to more than one KQ. The information request strategy described in the Methods chapter (contacts to pharmaceutical manufacturers) did not result in any additional data for consideration.

Figure 2 Literature flow diagram

KQ = Key Question

This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed®, Embase®, and the Cochrane Database of Systematic Reviews yielded 5769 citations, 756 of which were duplicate citations. Manual searching identified 213 additional citations, for a total of 5226 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 179 full-text articles were retrieved and screened. Of these, 139 were excluded at the full-text screening stage, leaving 40 articles (representing 35 unique studies) for data abstraction. Note that many articles/studies were relevant to more than one KQ. The information request strategy described in the Methods chapter (contacts to pharmaceutical manufacturers) did not result in any additional data for consideration.

Appendix D provides a detailed listing of included articles. Appendix E provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

## Description of Included Studies

Overall, we included 35 studies, some of which were relevant to more than one KQ: 32 studies were relevant to KQ 1, 7 to KQ 2, 15 to KQ 3, and 3 to KQ 4. Studies were conducted in Europe (23%); Asia (14%); the United States (37%); Australia/New Zealand (6%); and South America (6%); or multiple continents (14%). Sixty-three percent of included studies enrolled individuals with schizophrenia or schizoaffective disorder, eleven percent recruited individuals with schizophrenia, schizoaffective disorder, or bipolar disorder, twenty percent recruited patients either taking antipsychotics or with an unspecified SMI diagnosis, and only six percent recruited individuals with bipolar disorder. The vast majority of studies were specifically designed to control weight (80%); only one study was designed to target diabetes management, and no studies were designed to target dyslipidemia. Table F-1 in Appendix F details the study characteristics for the 35 included studies.

### Treatment Network Map

Figure 3 maps the direct comparisons between treatments evaluated in this report. The drugs, treatment indications, and major mechanisms of action are summarized in Table 5. The most common comparisons were between behavioral interventions and control (26% of comparisons), followed by neurologics (13%), and psychotropics or antihistamines compared with control (10% for each comparison). Relatively few studies compared two active interventions. No studies evaluated standard medications for hyperlipidemia (e.g., HMG-CoA reductase inhibitors) or orlistat (a Food and Drug Administration [FDA]-approved medication for weight control), and only a few studies evaluated hypoglycemic medication.

Figure 3 Treatment network describing the number of comparisons for each intervention (35 trials)^a^ a Because some trials had more than two arms, there are more comparisons than trials.

D1 = Psychotropics (aripiprazole, atomoxetine, fluoxetine, ramelteon).

D2 = Neurologics (amantadine, topiramate, zonisamide).

D3=Metformin.

D4 = Antihistamines (nizatidine).

D5 = Nutritionals (carnitine).

D6 = Antipsychotic switching (from oral olanzapine to aripiprazole, olanzapine long-acting injection, olanzapine orally disintegrating).

This network maps depicts the direct comparisons between treatments evaluated in this report. The most common comparisons were between behavioral interventions and control with 10 comparisons, followed by neurologics and metformin with 5 comparisons each. Psychotropics, antipsychotic switching and antihistamines each had 4 comparisons compared to control. There were two comparisons between multimodal interventions and control, and one comparisons between the nutritional carnitine and control. Relatively few studies compared two active interventions: one study compared metformin to neurologics, one compared behavioral intervention to metformin, one compared a multimodal intervention with a behavioral intervention, and one compared a behavioral intervention plus metformin with metformin alone.

Table 5 Drugs evaluated

Drug | FDA Indications | Major Mechanism of Action
Psychotropics
Atomoxetine | Attention deficit hyperactivity disorder | Selectively inhibits norepinephrine reuptake
Fluoxetine | Major depressive disorder Bipolar disorder Obsessive compulsive disorder Panic disorder Bulimia nervosa | Selectively inhibits serotonin reuptake
Aripiprazole | Schizophrenia Bipolar disorder-manic/mixed Major depressive disorder (adjunctive treatment) | Partially agonizes dopamine D2 and serotonin 5-HT1A receptors; antagonizes serotonin at 5-HT2A receptors
Olanzapine | Schizophrenia Bipolar disorder-depressive Bipolar disorder-manic/mixed Major depressive disorder-treatment resistant | Antagonizes dopamine, serotonin 5-HT2, and other receptors
Quetiapine | Schizophrenia Bipolar disorder-depressive Bipolar disorder-manic Major depressive disorder (adjunctive treatment) | Antagonizes dopamine, serotonin 5-HT2, and other receptors
Ramelteon | Insomnia | Melatonin receptor agonist
Neurologics
Amantadine | Influenza Extrapyramidal disorders Parkinsonism | Potentiate CNS dopaminergic response; inhibits viral replication
Topiramate | Seizure disorders Migraine prophylaxis | Exact mechanism unknown; blocks sodium channels, increases GABA, antagonizes kainite
Zonisamide | Partial seizures | Exact mechanism unknown; blocks sodium channels and T-type calcium channels, mild carbonic anhydrase inhibiting effects; some augmentation of dopaminergic and serotonergic transmission
Other Drugs
Metformin | Diabetes mellitus Polycystic ovary syndrome | Decreases hepatic glucose production and intestinal glucose absorption; increases insulin sensitivity
Nizatidine | Duodenal or gastric ulcer treatment Gastroesophageal reflux | Selectively antagonizes histamine H2 receptors
Carnitine | Nutritional (no FDA indication) | Lipid metabolism, lots of studies for many other disease

CNS = central nervous system; FDA = Food and Drug Administration; GABA = gamma-aminobutyric acid

### Drugs Evaluated

Table 5 lists the drugs evaluated in the included studies and their FDA indications and mechanism of action.

Of the 35 studies, 10 (29%) were judged to be of good quality, 21 (60%) of fair quality, and 4 (11%) of poor quality. Considering individual components of study design and conduct, the strengths were comparable groups at baseline and valid outcome measures. However, 71 percent of studies had inadequate or unclear specification of allocation sequence and concealment, 74 percent had inadequate or unclear specification of protocols for blinding, and 34 percent had high rates of differential attrition. Sixty-six percent of studies were supported at least in part by industry.

### Efficacy–Effectiveness Scale

We also categorized studies using an efficacy–effectiveness scale (Appendix B). Studies that have more effectiveness characteristics may be more likely to yield intervention effects that more closely mirror outcomes seen in usual practice. No study was categorized as an effectiveness study. Of the 35 studies, 21 were categorized as efficacy and 14 as mixed efficacy–effectiveness. As shown in Figure 4, the minority of studies were categorized as effectiveness on each of the eight dimensions examined.

Figure 4 Proportion of studies rated as effectiveness studies on each efficacy–effectiveness dimension

ITT = intention to treat

Figure 4 shows that of the 35 studies, 21 were categorized as efficacy and 14 as mixed efficacy–effectiveness. The minority of studies were categorized as effectiveness on each of the eight domains examined.

Further details are provided in the relevant KQ Results sections that follow and in Appendix F, which reports details of the characteristics of each included study, including geographical location, clinical setting, study population, intervention(s), comparator(s), and quality rating.

As described in the Methods chapter, we searched ClinicalTrials.gov to identify completed but unpublished studies as a mechanism for ascertaining publication bias. Our search yielded 1417 citations. A single reviewer identified 73 of these as potentially relevant; 48 of these had been completed at least 1 year prior to our search of the published literature. Of these 48, 18 were published and 4 are among our included studies; 30 had no identified published literature. A total of 25 studies were not completed at least 1 year prior to our search of the published literature. Twenty-four of these are ongoing (10 applicable to KQ 1; 2 applicable to KQ 2; 2 applicable to KQ 3; 3 applicable to KQ 4; 6 applicable to multiple KQs) and 1 was terminated. In summary, our search of ClinicalTrials.gov found evidence for completed but unpublished studies relevant to our KQs.

## Key Question 1 Effectiveness of Weight-Management Interventions

KQ 1: What is the effectiveness of weight-management behavioral interventions (e.g., behavioral counseling, health education), peer or family support interventions, pharmacological treatments (e.g., orlistat, topiramate), antipsychotic medication–switching to an antipsychotic with a low or neutral impact on weight, or their combination on weight control and related physical health outcomes (e.g., health-related quality of life, mortality) when compared with each other or with usual care (or other control) among adults with serious mental illness (SMI) who are overweight, obese, or taking antipsychotics?

### Key Points

- Of the 32 studies identified, most were specifically designed to control weight gain for individuals with SMI.
- Behavioral interventions were found in a meta-analysis to have a significant advantage over control conditions. We found moderate strength of evidence (SOE) that behavioral interventions are associated with small decreases in weight (about 3 kg) compared with controls.
- Switching to or adding adjunctive aripiprazole, adding the anticonvulsant medications topiramate and zonisamide, or adding metformin yielded small to moderate weight loss (low SOE).
- There was no advantage in favor of nizatidine compared with placebo for the management of weight gain among patients with SMI (low SOE).
- No studies evaluated the weight loss medication orlistat in this population.
- Few studies reported effects on physical functioning or health-related quality of life, and no studies reported all-cause mortality.

### Detailed Synthesis

We identified 32 RCTs encompassing 3473 patients that assessed the effects of weight-management strategies among adults with SMI.88–119 In total, 22 studies targeted weight control,89–91,93–100,102–104,106,107,109,110,112–114,117,119 6 obesity prevention,88,101,111,115,118,119 3 antipsychotic metabolic effects,92,108,116 and 1 diabetes management.105 All identified studies were published from 2003 forward, reflecting the recent clinical interest in weight control among individuals with SMI. Ten trials assessed behavioral intervention strategies compared with control;88,93,94,97,99,103–105,113,114 16 assessed pharmacological strategies compared with placebo;89–92,96,98,100,109–112,115–119 4 assessed antipsychotic-switching strategies;95,102,106,108 and 1 four-arm trial assessed metformin alone, lifestyle intervention alone, metformin plus lifestyle intervention, or placebo.107 Of the 32 trials that reported on weight control, 7 are included in KQ 2 (diabetes control), 14 are included in KQ 3 (dyslipidemia control), and none is included in KQ 4 (multicondition interventions).

#### Study Characteristics

Table 6 summarizes the study characteristics of the 32 included studies. Most studies (n=19) were rated fair quality, with 9 studies rated good quality and 4 poor quality. Common reasons for reduced study quality were inadequate or unclear specification of the following: allocation sequence and concealment, protocols for blinding of assessments, reported conflicts of interest. We identified no studies rated as effectiveness trials, 20 as efficacy trials, and 12 as mixed efficacy–effectiveness trials. The most common reasons that studies were coded as efficacy trials were because they were conducted in a highly specialized setting, had only short-term followup (<6 months), had inadequate or unspecified sample sizes, or focused on intermediate health outcomes rather than clinically important outcomes. Twelve studies were conducted exclusively with U.S.-based populations. Most studies (n=25) were conducted in outpatient mental health settings. Twenty-one studies received at least partial funding support from industry sponsors.

Table 6 Study characteristics for KQ 1: Weight-management interventions

Characteristic | Details
Studies: N (patients)^a^ | 32 studies (3473 patients)
Mean age of sample: Median (range) | 35.5 (25.6 to 53.1)
Sex: N patients (%)
Female | 1353 (39%)
Male | 1764 (51%)
NR | 356 (10%)
Race: N patients (%)
White | 1568 (45%)
Nonwhite | 859 (25%)
NR | 1055 (30%)
Baseline weight (kg): Median (range) | 81.1 (54.0 to 101.83)
Setting: N studies (%)
Mental health | 25 (78%)
General medical | 1 (3%)
Community | 2 (6%)
Integrated mental health-medical | 0 (0%)
Not reported | 4 (13%)
Study quality: N studies (%)^b^
Good | 9 studies (28%)
Fair | 19 studies (59%)
Poor | 4 studies (13%)
Efficacy–effectiveness rating: N studies (%)
Efficacy (0–2) | 20 studies (63%)
Mixed (3–5) | 12 studies (37%)
Effectiveness (6–7) | 0 studies (0%)
Comparisons: N studies (patients randomized)
Drug vs. placebo/control | 16 studies (1047 patients)
Antipsychotic vs. antipsychotic switching | 4 studies (1520 patients)
Behavioral vs. control | 10 studies (662 patients)
Drug vs. behavioral vs. both vs. placebo/control | 1 study (128 patients)
Drug vs. drug vs. placebo/control | 1 study (199 patients)

kg = kilogram; KQ = Key Question; N = number; NR = not reported

a The number of patients with demographic data reported is fewer than the number randomized.

b Quality ratings in the table are reported on the basis of how studies were conducted in relation to laboratory-based physical health outcomes. Ratings were also applied on the basis of patient-reported outcomes. Only one quality rating differed on the basis of physical versus patient-reported outcomes103 and was rated as fair on laboratory-based physical health outcomes and poor on patient-reported outcomes.

Of the 3,484 participants across the 32 included studies, most were male and white. Of note, 15 studies did not report race/ethnicity data, and 3 studies did not provide information on the sex of the randomized samples. Twenty-one studies recruited patients with schizophrenia/schizoaffective disorder, three recruited patients with schizophrenia/schizoaffective disorder or bipolar disorder, two recruited participants with bipolar disorder only, and six did not specify psychiatric illness but defined the sample as having SMI or taking antipsychotics. Only 10 studies stated that they recruited participants who were classified as obese or overweight at baseline.

#### Meta-Analysis and Qualitative Review

We classified studies and organized findings by the following intervention categories: (1) behavioral interventions, (2) peer or family support interventions, (3) pharmacological treatments (psychotropic agents [e.g., atomoxetine, aripiprazole, fluoxetine], neurologic agents [e.g., topiramate, amantadine, zonisamide], metformin, nizatidine, and carnitine), and (4) antipsychotic-switching interventions.

We had sufficient studies to perform four meta-analyses. The other comparisons were synthesized qualitatively. Below, we focus on the weight control outcomes and, when reported, adverse effects (i.e., discontinuation due to adverse effects, significant worsening of psychiatric symptoms), and health-related quality of life. While mortality was an outcome of interest, no study reported on this outcome. Details for HbA1c are in the Results section of KQ 2, and details for lipids are in KQ 3.

##### Effect of Behavioral Interventions on Weight Control

Eleven studies, 3 rated good quality,88,104,107 6 fair, 93,94,99,103,105,113 and 2 poor,97,114 measured the impact of behavioral interventions on weight control among individuals with SMI. As expected, most patients also were on antipsychotics or mood stabilizers at baseline and continued these medications throughout the intervention. The median baseline weight across these studies was 83.9 kg (range, 64.6 to 101.8 kg). The number of treatment sessions ranged from 4 to 24 and the treatment duration ranged from 8 weeks to 6 months. Six of these studies were classified as more intensive behavioral strategies, operationalized as at least six contacts over 12 weeks, a written manual of counseling protocol, and skills-based versus education-based intervention content. Interventions were adapted for SMI populations by streamlining content to focus on key points, delivery of intervention content by mental health personnel, and use of specific behavior change strategies (e.g., goal setting, modeling, healthy food sampling), and incorporating psychoeducation about SMI. Control conditions consisted of waitlist, no intervention, and usual care plus information. These control group conditions were combined in the meta-analysis, as participants in waitlist and no intervention conditions were allowed to continue receiving usual care. Selected details of each intervention are in Table 7.

Table 7 Details of behavioral interventions

Citation | Planned Contacts | Written Manual? | Strategies Used
Alvarez-Jimenez, 2006^88^ | 10 to 14 weekly or twice-weekly individual therapy sessions over 3 months | Yes | Education about diet and physical activity Problem solving Goal setting Motivational techniques Self-monitoring Activity scheduling Personalized or tailored written communications
Brar, 2005^93^ | 20 behavioral therapy sessions, twice weekly for 6 weeks followed by weekly for 8 weeks | Yes | Education about diet and physical activity Self-monitoring Cognitive and behavioral approaches to reduce overeating
Brown, 2011^94^ | 12 weekly individual visits followed by monthly individual visits and weekly phone calls for the following 3 months | Yes | Education about diet and physical activity Problem solving Goal setting Activity scheduling Strategies to enhance social support Meal replacements
Evans, 2005^97^ | 6 individual nutrition education sessions over 3 months | No | Education about diet and physical activity Goal setting
Gillhoff, 2010^99^ | Weekly fitness training, 7 psychotherapeutic/educational sessions, and 4 cooking and nutrition classes over the course of 5 months. | No | Patient psychoeducation about bipolar disorders Education about diet and physical activity Goal setting Motivational techniques Activity scheduling Stress management techniques
Khazaal, 2007^113^ | 12 weekly CBT-based group sessions over 6 months | Yes | Education about diet and physical activity Psychoeducation about links between weight gain and antipsychotic drugs Self-monitoring Meal tastings
Kwon, 2006^103^ | 8 individual sessions of CBT weight management counseling over 3 months | No | Education about diet and physical activity Problem-solving skills Goal setting Self-monitoring Activity scheduling
Littrell, 2003^104^ | 16 weekly 1-hour classes over 4 months | Yes | Education about diet and physical activity Goal setting Self-monitoring Activity scheduling Strategies to enhance social support
Mauri, 2008^114^ | 5 to 7 psychoeducational groups over 4 months | No | Education about diet and physical activity Goal setting Self-monitoring Personalized or tailored written communications Education on controlling stimuli to overeat
McKibbin, 2006^105^ | 24 weekly 90-minute group classes over 6 months | Yes | Education about diet and physical activity Diabetes education Self-monitoring Reinforcements (i.e., raffle tickets for small health-related prizes) Behavioral modeling Skills practice
Wu, 2008^107^ | 4 psychoeducational session and 7 sessions with an exercise physiologist (during the first week only) and consultation with a dietitian (frequency not stated) over 3 months | No | Education about diet and physical activity Education about monitoring adherence with family member/caregiver Goal setting Self-monitoring Activity scheduling Personalized or tailored written communications Homework assignments

CBT = cognitive behavioral therapy

Of these 11 studies, one assessed weight control only as a change in BMI and could not be combined with the other studies that assessed weight control as a change in kilograms or pounds;105 this study is discussed in detail in the KQ 2 section. In brief, the study found that participants in the behavioral intervention group experienced greater improvements in BMI from baseline to 12-month followup compared with usual care (approximately −1 vs. +0.05 BMI points, p<0.01).

Figure 5 shows the forest plot of the meta-analysis examining the effect of behavioral interventions compared with control on weight gain, which included the remaining 10 studies (735 participants).88,93,94,97,99,103,104,107,113,114 In these studies, the behavioral intervention led to a mean difference of −3.13 kg (95% CI, −4.21 to −2.05), an effect of small magnitude (approximately 4% reduction in body weight over baseline). In an exploratory subgroup analysis by intervention intensity, high-intensity behavioral intervention resulted in a mean difference of −2.43 kg compared with control (CI, −4.23 to −0.62). There was some evidence of moderate heterogeneity (Q-value=10.428, df=4, p=0.034; I^2^=61.643). Low-intensity behavioral intervention resulted in a mean difference of −3.53 kg weight compared with control (CI, −4.88 to −2.17). There was some evidence of low heterogeneity as assessed by the I^2^ value of 34.925 but no evidence of heterogeneity as assessed by the Q-value of 6.147 for 4 degrees of freedom (p=0.188). There was no significant difference between low- and high-intensity behavioral interventions (chi-square=0.91, df=1, p=0.34). Analyses were repeated excluding the two studies rated as poor quality.97,114 These exclusions had a minor effect on the odds ratio estimates for all studies combined (−3.10 kg; CI, −4.65 to −1.54).

Figure 5 Forest plot of meta-analysis of effect of behavioral interventions on weight

CI = confidence interval

This figure shows the forest plot of the meta-analysis examining the effect of behavioral interventions compared with control on weight gain, which included the remaining 10 studies (735 participants). In these studies, the combined estimate for behavioral intervention was a weight loss of −3.13 kg (95% CI, −4.21 to −2.05), an effect of small magnitude (approximately 4% reduction in body weight over baseline). In an exploratory subgroup analysis by intervention intensity, high-intensity behavioral intervention resulted in −2.43 kg weight loss compared with control (CI, −4.23 to −0.62). Low-intensity behavioral intervention resulted in −3.53 kg weight loss compared with control (CI, −4.88 to −2.17). There was no significant difference between low- and high-intensity behavioral interventions (chi-square=0.91, df=1, p=0.34). Analyses were repeated excluding the two studies rated as poor quality. These exclusions had a minor effect on the odds ratio estimates for all studies combined (−3.10 kg; CI, −4.65 to −1.54).

For the studies that reported adverse effects, none reported significant differences between conditions in serious adverse effects as defined by the study protocol, and only three studies93,105,107 reported discontinuations due to serious or nonserious adverse effects and found no difference between groups. One study reported health-related quality of life,103 assessing physical health status with the World Health Organization-Quality of Life Brief Version instrument, and found no significant differences between behavioral weight management and control. Funnel plots for publication bias did not demonstrate evidence of publication bias.

##### Effect of Peer or Family Support Interventions on Weight Control

We identified no eligible studies for this category of intervention for KQ 1.

##### Effect of Pharmacological Treatments on Weight Control

###### Psychotropic Agents

Four studies, 1 rated good quality98 and 3 fair,91,92,109 assessed the impact of psychotropic agents atomoxetine,91 fluoxetine,109 aripiprazole,98 and ramelteon92 on weight control among second-generation antipsychotic-treated individuals with schizophrenia. Although each medication is classified as psychotropic, the mechanisms of action vary. Thus, we did not perform a meta-analysis; instead, key findings are synthesized qualitatively.

Across included studies, participants treated with psychotropic agents experienced variable levels of weight control on the four medications. For participants who lost weight, effects were modest (range, −0.15 to −2.53 kg), which translates into less than 3 percent change in body weight from baseline (median baseline weight, 81.5 kg; range, 80.5 to 102.2 kg). Only one study demonstrated significant weight loss; this study was also the only one that reported discontinuation due to side effects and health-related quality of life outcomes.98

A good-quality study98 assessed weight gain in clozapine-treated outpatients with schizophrenia (207 patients). First, patients on a fixed dose of clozapine (200 to 900 mg/day) were randomized to an adjunctive flexible dose of aripiprazole (5 to 15 mg/day) or clozapine plus placebo. After 16 weeks, patients who completed the 16-week double blind phase could enter a 12-week open-label extension phase. All patients received 5 to 15 mg per day of aripiprazole and flexible dosing of clozapine. At 16 weeks, adjunctive aripiprazole significantly decreased weight compared with placebo control (−2.53 vs. −0.38 kg, p<0.001). A total of 180 participants entered the 12-week open-label phase in which everyone received adjunctive aripiprazole. Participants originally randomized to adjunctive aripiprazole continued to lose weight and, at the end, experienced a mean change in weight of −3.26 kg from baseline weight. Those who had originally received placebo had a −1.88 kg mean weight loss over the 12-week open-label phase. Treatment with adjunctive aripiprazole did not differentially impact health-related quality of life compared with placebo control as measured by the Subjective Well Being Under Neuroleptics scale (p=0.20). Only one participant in the placebo arm and five in the aripiprazole arm discontinued the trial due to adverse effects. However, 0 out of 99 patients in the placebo group and 10 out of 108 patients in the aripiprazole group experienced a serious adverse effect.

In another study rated fair quality,91 37 olanzapine- or clozapine-treated individuals with schizophrenia were randomized to 24 weeks of either atomoxetine or placebo. Atomoxetine was titrated from 40 mg per day to 120 mg per day, which is above the normal recommended dosage. All participants also received a diet and exercise program that consisted of 10 weeks of a Weight Watchers program and exercise sessions three times per week. Participants could receive tokens for compliance with exercise and diet programs; tokens could be used to acquire prizes at the end of the study. Both atomoxetine and placebo groups lost weight; however, results were modest and not significant (−1.7 kg vs. −2.1 kg, p=0.82). Adherence to the exercise and diet program was low; only nine participants who completed the study also adhered to the program. However, these nine participants lost more weight (range, −15.9 to −4.5 kg).

In a fair-quality study of olanzapine-treated schizophrenic patients,109 patients who had gained at least 3 percent over baseline weight were randomized to a double-blind 4-month treatment of placebo or fluoxetine (20 to 60 mg/day). During the olanzapine-only phase, two patients were hospitalized for worsening of psychiatric symptoms, and one died for causes deemed unrelated to the study. Fifty-one patients started on olanzapine and 31 met weight-gain criteria for randomization to fluoxetine or placebo with continued treatment on olanzapine. Both groups gained weight. The fluoxetine-treated patients did not gain less weight than the placebo controls (p=0.3).

In a small, double-blind, 8-week trial rated fair quality,92 20 participants with schizophrenia were randomized to adjunctive ramelteon (8 mg/day) or placebo. All patients entered the study on second-generation antipsychotics and were maintained on these during the trial. Patients on ramelteon did not experience significant weight loss compared with placebo control (−0.84 vs. −0.15, p=0.28).

###### Neurologic Agents

Four studies, 1 rated good quality,115 2 fair,112,119 and 1 poor,100 assessed the effects of neurologic agents topiramate, amantadine, or zonisamide on weight control among individuals with SMI treated with olanzapine. One study was conducted with women only.112 Two were conducted with participants with schizophrenia,100,119 one with an SMI population on olanzapine,112 and one with a mixed population of people with psychotic or bipolar disorder.115 Three studies assessed anticonvulsant medications topiramate112,119 and zonisamide115 versus placebo control on the effects of olanzapine-induced weight gain; these studies were able to be combined in a meta-analysis (Figure 6). Results for the amantadine placebo-controlled trial are summarized qualitatively.

Figure 6 Forest plot of meta-analysis of effect of anticonvulsant medications topiramate and zonisamide on weight

CI = confidence interval

This figure shows the forest plot of the meta-analysis examining the effect of anticonvulsant medications compared with placebo control on olanzapine-induced weight gain, which included 3 studies (158 participants) (median baseline weight, 86.6 kg; range, 54.0 to 95.6 kg). The analysis demonstrated statistically significant difference in efficacy between topiramate and zonisamide versus placebo control on weight gain of −5.11 kg (95% CI, −9.48 to −0.74), a clinically significant weight loss of a small effect (percentage of body weight lost from baseline range, 4% to 11%).

Figure 6 shows the forest plot of the meta-analysis examining the effect of anticonvulsant medications compared with placebo control on olanzapine-induced weight gain, which included 3 studies (158 participants) (median baseline weight, 86.6 kg; range, 54.0 to 95.6 kg). The analysis demonstrated statistically significant difference in efficacy between topiramate and zonisamide versus placebo control on weight gain of −5.11 kg (95% CI, −9.48 to −0.74), a clinically significant weight loss of a small effect (approximately 6% reduction in body weight over baseline compared with median baseline weight). There was no evidence of heterogeneity (Q-value=0.332, df =2, p=0.733; I^2^=0.000).

Results of the single amantadine study mirror these findings.100 This 12-week study of amantadine versus placebo among 21 SMI patients who had gained at least 5 pounds on olanzapine also found significant but small improvements with adjunctive amantadine (−0.7 vs. +1.24 kg/m^2^).

One study112 reported on health-related quality of life; participants taking olanzapine and randomized to adjunctive topiramate had significant improvements on seven of eight scales of SF-36 compared with adjunctive placebo control. Two studies reported on discontinuation from the studies for adverse effects.100,115 One patient randomized to amantadine withdrew from the study due to significant worsening of psychosis.100 Ten participants in the placebo-controlled study of zonisamide115 withdrew from the study for adverse effects (five in placebo group and five in zonisamide group). Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

###### Metformin

Five studies, two rated good quality,107,118 two fair,116,117 and one poor,101 assessed the effects of metformin on weight control for individuals with SMI. All studies were conducted with participants with schizophrenia; three trials were conducted solely with first-psychotic-episode participants.107,117,118 All patients were stable on antipsychotics at baseline and continued use of baseline antipsychotics during the trial. Four of these studies107,116–118 assessed metformin versus placebo control; these studies were able to be combined in a meta-analysis (Figure 7). The final study101 compared three different treatment algorithms; results of this trial are summarized qualitatively.

Figure 7 Forest plot of meta-analysis of effect of metformin on weight

CI = confidence interval

This figure shows the forest plot of the meta-analysis examining the effect of metformin compared with placebo control on weight gain that included 332 participants. The analysis demonstrated statistically significant difference in efficacy between metformin versus placebo on weight gain of −4.13 kg (95% CI, −6.58 to −1.68), a clinically significant difference of a small effect (percentage of body weight lost from baseline range, 5% to 6%).

Figure 7 shows the forest plot of the meta-analysis examining the effect of metformin compared with placebo control on weight gain that included 332 participants (median baseline weight, 64.7 kg; range, 64.8 to 79.4 kg). The analysis demonstrated statistically significant difference in efficacy between metformin versus placebo on weight gain of −4.13 kg (95% CI, −6.58 to −1.68), a clinically significant difference of a small effect (percentage of body weight lost from baseline range, 5% to 6%). There was evidence of extreme heterogeneity (Q-value=32,318, 3 df, p < 0.001; I^2^=90.717).

In a poor-quality study, Hoffmann et al.101 randomly assigned 199 nondiabetic outpatients with schizophrenia or schizoaffective disorder to 1 of 3 conditions for 22 weeks: (1) olanzapine only, (2) olanzapine plus 200 mg/day amantadine with possible switches to 1000 to 1500 mg/day metformin and then switches to 100 to 400 mg/day zonisamide (treatment algorithm A), or (3) olanzapine plus 1000 to 1500 mg/day metformin with possible switches to 200 mg/day amantadine and then switches to 100 to 400 mg/day zonisamide (treatment algorithm B). Forty-two percent of participants of algorithm A and 35 percent of algorithm B switched to second treatment. The estimated time to switching to second treatment for 25 percent of the sample was 42 days for algorithm A and 66 days for algorithm B. A combined treatment group of both algorithm A and algorithm B did not differ significantly from the olanzapine-only group at 22-week followup (results not reported, p=0.065). However, patients treated with algorithm B compared with olanzapine-only resulted in significantly less weight gain (0.65 vs. 2.76 kg, p=0.04), though the magnitude of the effect was small. Ten subjects continued the study despite serious adverse effects (1 in algorithm A group, 4 in algorithm B group, and 5 in olanzapine only group).

None of these studies reported on health-related quality of life. Four of these studies101,107,117,118 reported on discontinuation from the studies for adverse effects. Among the trials that compared metformin with placebo, no significant differences between conditions were reported across three studies.107,117,118 In total, 14 participants discontinued the drug due to adverse effects (8 in algorithm A group, 4 in algorithm B group, and 2 in olanzapine only group); only three of these, all in the algorithm A group, were considered serious adverse effects.101 Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

###### Nizatidine

Four studies, one rated good quality89 and three fair,90,110,111 assessed the effects of nizatidine, a histamine2 (H2)-receptor antagonist, on antipsychotic-induced weight gain among people with schizophrenia. One studied assessed weight gain among quetiapine-treated patients90 while the remaining studies focused on weight gain among olanzapine-treated patients.89,110,111 Three studies tested nizatidine at recommended therapeutic doses of 300 mg/day;90,110,111 one study assessed nizatidine at twice the recommended daily dose.89 Below, we focus on the weight and adverse effects outcomes of these studies.

Figure 8 shows the forest plot of the meta-analysis examining the effect of nizatidine compared with placebo control on antipsychotic-induced weight gain, which included 4 studies (286 participants). The estimated effect shows that nizatidine resulted in a −0.49 kg weight gain compared with placebo that was not statically significant (95% CI, −1.26 to 0.27). There was no evidence of heterogeneity (Q-value =3.030, df=3, p=0.387). However, the I^2^ value displayed high heterogeneity (I^2^ =0.98). Only one study reported discontinuation due to adverse events; Assuncao et al.89 reported three patients discontinued the study due to adverse effects (two in the nizatidine treated group). No studies reported on health-related quality of life outcomes. Because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

Figure 8 Forest plot of meta-analysis of effect of nizatidine on weight

CI = confidence interval

This figure shows the forest plot of the meta-analysis examining the effect of nizatidine compared with placebo control on antipsychotic-induced weight gain, which included 4 studies (286 participants). The estimated effect shows that nizatidine resulted in a −0.49 kg weight gain compared with placebo that was not statically significant (95% CI, −1.26 to 0.27).

###### Carnitine

One good-quality study96 assessed the effects of 15 mg/kg daily carnitine, a nutritional supplement, compared with placebo among 60 bipolar patients taking sodium valproate for 26 weeks. All study participants also were on energy-restricted, lowfat diets (−500 kcal/day from usual consumption). There is no recommended dose of carnitine; dosages vary and several doses have been studied in scientific research (50 to 100 mg/kg/day, 2 to 6 grams daily, 990 mg two to three times per day). Carnitine had no significant effect on mean weight loss in the study compared with placebo (−1.9 kg vs. −0.9 kg, p=0.38). No other outcomes of interest were reported.

##### Effect of Antipsychotic-Switching Interventions on Weight Control

Four studies, one rated good quality102 and three fair,95,106,108 assessed the effects of antipsychotic-switching strategies on weight control. Patients in all studies began on olanzapine, with the control group maintained on olanzapine. The intervention in two studies involved switching to a different form of olanzapine (an orally disintegrating tablet102 or a long-acting injection108) and in the other two studies, switching to a different antipsychotic medication, quetiapine95 or aripiprazole.106 Meta-analysis was not completed on these four studies due to the heterogeneity of switching strategies. Only one study reported on health-related quality of life outcomes. Results are summarized qualitatively.

Neither study that examined switching to a different form of olanzapine102,108 showed significant effects on weight control. In a good-quality study of a 16-week trial with SMI patients (n=149) that involved switching from 5 to 20 mg of standard olanzapine tablets (SOT) to 5 to 20 mg orally disintegrating olanzapine (ODO) tablets,102 there was no difference between SOT or ODO groups for mean weight gain (+2.08 vs. +1.42, p=0.39). Results for health-related quality of life as measured by the Subjective Well-being Under Neuroleptics Scale showed no significant change from baseline to followup between groups (p=0.16). Two patients in each group discontinued treatment due to adverse effects. Two patients in the ODO group experienced a serious adverse effect.

Another fair-quality study assessed switching from 10 to 20 mg of oral olanzapine to a long-acting intramuscular injection of olanzapine (150 mg/2 weeks, 405 mg/4 weeks or 300 mg/2 weeks) in a 24-week trial of 921 patients with schizophrenia.108 Patients taking both formulations of olanzapine experienced statistically significant increases in weight compared with baseline (+1.3 [injection] vs. +1.3 [oral]). However, there were no between-group differences (p=0.34). A total of 57 patients discontinued use due to adverse effects, but there were no differences between groups (p-value NR).

The studies that examined switching from olanzapine to a different antipsychotic medication95,106 had mixed results. In a fair-quality study, 133 overweight patients with schizophrenia were either switched to 300 to 800 mg/day of quetiapine or continued on 7.5 to 20 mg/day olanzapine.95 Treatment continued for 24 weeks. Mean weight change between olanzapine and quetiapine were not significant (+0.99 vs. −0.82, p=0.089). Significantly more subjects in the olanzapine group completed 24 weeks of treatment than the quetiapine group (70.3% vs. 43. 1%, p=0.002). Discontinuation due to psychiatric adverse effects was higher in the quetiapine-treated group (p=0.003). However, no significant differences were observed for nonpsychiatric discontinuations (p-value NR). There were no significant differences in hospitalization rates (7.69% in the quetiapine group vs. 1.47% in the olanzapine group, p-value not reported). No other serious adverse events were reported.

In a fair-quality study, 173 patients with schizophrenia either stayed on 10 to 20 mg of olanzapine or switched to 10 to 30mg of aripiprazole in a 16-week trial.106 Patients who switched to aripiprazole experienced significantly more weight loss than those remaining on olanzapine (−1.84 vs. +1.31 kg, p=0.001), a difference of small magnitude between groups. A total of 15 participants discontinued treatment due to adverse effects (7 aripiprazole-treated, 8 olanzapine-treated). Six participants treated with aripiprazole experienced a serious adverse effect compared with nine in the olanzapine-treated group (p-value NR). Another study, described in KQ 4, evaluated switching to aripiprazole as part of a multicomponent intervention.120 This study found that patients who switched to aripiprazole lost more weight than those who stayed on their current antipsychotic medication. (See KQ 4 section for more details.)

### Summary of Key Question 1

Overall, only 9 of the 32 trials identified as relevant for KQ 1 were of good quality. Thus, the majority of studies had important design or reporting deficits. Most trials were specifically designed to control weight gain for individuals with SMI. Other studies targeted diabetes management or antipsychotic metabolic effects but also reported effects on weight management. The 32 trials assessed the impact of a wide variety of pharmacological and behavioral strategies on weight among individuals with SMI. However, most of the pharmacological strategies assessed in the included interventions were used in treatment of individuals with mental illnesses; no studies evaluated the weight loss medication orlistat in this population. The behavioral interventions, anticonvulsant agents topiramate and zonisamide, and metformin were associated with greater weight loss than controls (for behavioral interventions) or placebo (for pharmacological agents), but the effects were modest. Using adjunctive aripiprazole or switching to aripiprazole also showed promise. Again, the magnitude of effects was small. Discontinuation due to adverse effects and worsening of psychiatric symptoms were not consistently reported. Few studies reported effects on physical functioning or health-related quality of life, and no studies reported cardiovascular mortality.

## Key Question 2 Effectiveness of Diabetes-Management Interventions

KQ 2: What is the effectiveness of diabetes-management behavioral interventions (e.g., behavioral counseling, health education), peer or family support interventions, pharmacological treatments (e.g., rosiglitazone, metformin), antipsychotic medication–switching to an antipsychotic with a low or neutral impact on glucose level, or their combination on glucose-level control and related physical health outcomes (e.g., health-related quality of life, mortality) when compared with each other or with usual care (or other control) among adults with SMI who have diabetes or are taking antipsychotics?

### Key Points

- Overall, we found insufficient evidence to support any strategy to control glucose. Of the seven studies identified, only one evaluated an intervention specifically designed to target glucose control in individuals with SMI who have diabetes. Two additional studies evaluated interventions targeting nondiabetic individuals who had or were at risk for poor glycemic control. Four studies evaluated interventions targeting weight, with glycemic control as a secondary outcome.
- The interventions represented in these seven studies were ramelteon, antipsychotic switching, metformin, amantadine, and behavioral interventions.
- Just two of the trials found significant advantages for the intervention in controlling HbA1c, with both of these studies involving the use of metformin. Improvements in HbA1c were small.
- Health-related quality of life and serious adverse events were inconsistently reported in the seven trials. Only one study reported effects on physical functioning or health-related quality of life, and no studies reported cardiovascular mortality.

### Detailed Synthesis

Of the seven studies identified as relevant to KQ 2 (681 participants),92,95,99,101,102,105,116 only one study105 tested an intervention intended specifically for individuals with diabetes mellitus. Two studies92,116 targeted antipsychotic-induced metabolic risks, including glycemic control as measured by HbA1c, and four studies95,99,101,102 targeted weight, with HbA1c as a secondary outcome. Of the seven trials that reported on HbA1c, all were included in KQ 1 (weight control), 6 were included in KQ 3 (lipid control), and none were included in KQ 4 (multicondition interventions). All identified studies were published from 2006 forward, reflecting the recent clinical interest in glycemic control among people with SMI.

#### Study Characteristics

Table 8 summarizes the study characteristics of the seven included studies. Of these, one study was rated good quality,102 five fair,92,95,99,105,116 and one poor.101 Common reasons for reduced study quality were inadequate reporting of randomization and concealment and recruiting procedures, lack of clarity about blinding of outcome assessors, and some difficulties implementing the study protocols as intended.

Table 8 Study characteristics for KQ 2: Diabetes-management interventions

Characteristic | Details
Studies: N (patients)^a^ | 7 studies (681 patients)
Mean baseline HbA1c: Median (range) | 5.6 (5.4 to 7.0)
Mean age of sample: Median (range) | 44.0 (38.5 to 54.0)
Sex: N patients (%)
Female | 197 patients (29%)
Male | 278 patients (42%)
NR | 194 patients (29%)
Race: N patients (%)
White | 222 patients (35%)
Nonwhite | 233 patients (37%)
NR | 183 patients (28%)
Setting: N studies (%)
Mental health | 4 studies (57%)
General medical | 0 study (0%)
Community | 2 studies (29%)
Integrated mental health-medical | 0 studies (0%)
Not reported | 1 study (14%)
Study quality: N studies (%)^b^
Good | 1 study (14%)
Fair | 5 studies (71%)
Poor | 1 study (14%)
Efficacy–effectiveness rating: N studies (%)
Efficacy (0–2) | 4 studies (57%)
Mixed (3–5) | 3 studies (43%)
Effectiveness (6–7) | 0 studies (0%)
Comparisons: N studies (patients randomized)
Drug vs. placebo/control | 2 studies (81 patients)
Antipsychotic switching vs. antipsychotic stay | 2 studies (282 patients)
Behavioral vs. control | 2 studies (114 patients)
Drug vs. drug vs. placebo/control | 1 study (199 patients)

N = number; NR = not reported

a The number of patients with demographic data reported is fewer than the number randomized.

b Quality ratings in the table are reported on the basis of how studies were conducted in relation to laboratory-based physical health outcomes. Ratings were also applied on the basis of patient-reported outcomes. Raters were the same as for laboratory-based outcomes except that two studies92,99 did not report patient-reported outcomes.

We identified no effectiveness studies, four efficacy studies,92,99,105,116 and three studies assessed in the mixed range on the efficacy–effectiveness continuum.95,101,102 Three studies were conducted exclusively with U.S.-based populations, one was conducted in Europe, and three were conducted in multiple countries. Indicative of care patterns for this population, most studies were conducted in outpatient mental health settings. Trials were funded by private industries (n=4), government (n=1), or a combination of industry and government sources (n=2).

The intervention strategies assessed in these seven studies were the psychotropic medication ramelteon (one study92), antipsychotic switching (two studies95,102), metformin (two studies101,116), and behavioral interventions (two studies99,105). All five studies that primarily employed medications as the intervention strategy92,95,101,102,116 required participants to be on antipsychotic medications at baseline. Of the two behavioral interventions, one required use of a defined group of mood stabilizers (including some antipsychotic medications, some anticonvulsant mood stabilizers, and lithium)99 and one had no requirement for entry based on medication use.105

A total of 681 participants were randomized in the seven studies, ranging from 20 to 199 participants. Most patients were middle-aged and white. Two studies representing 29.0 percent of the overall participants for KQ 2 95,116 did not report sex. In the five studies that reported sex, males outnumbered females 59 to 41 percent. Five studies recruited individuals with schizophrenia or schizoaffective disorder,92,95,101,105,116 one included individuals with bipolar disorder,99 and one included individuals with any of these three diagnoses or another related psychotic disorder.102 Only one study recruited patients with a diagnosis of diabetes.105 In this study, the mean A1c was 7.0 at baseline, indicating fair glycemic control. Across all included studies, median baseline HbA1c was 5.6 (range, 5.4 to 7.0).

#### Qualitative Review

HbA1c is the most consistently reported measure of glycemic control in these studies and is a widely accepted and reliable measure; therefore, we used it as the outcome measure for glycemic control for this evidence synthesis. There was an insufficient number of studies to conduct meta-analyses on the effects of any of the intervention classes by HbA1c. Results are summarized qualitatively. We focus on the HbA1c outcomes and, when reported, adverse effects (i.e. discontinuation due to adverse events, significant worsening of psychiatric symptoms). While health-related quality of life and mortality were outcomes of interest, only one study reported on health-related quality of life, and no studies reported on mortality. Details for weight and lipids can be found in KQ 1 and KQ 3, respectively. Also, because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias.

##### Effect of Behavioral Interventions on Diabetes Control

Two studies evaluated behavioral interventions, one specifically designed to target diabetes105 and one with the primary target of weight with glycemic control measured as a secondary outcome.99 Intervention components are summarized in KQ 1.

McKibbin et al.105 conducted a fair-quality, randomized 6-month trial of a lifestyle intervention in older individuals (mean age=54.0) with schizophrenia and diabetes mellitus compared with modestly enhanced usual care as the control group (provision of three American Diabetes Association brochures and treatment by a primary care provider alone) (n=64). Consistent with diabetes, mean HbA1c levels were elevated at baseline (HbA1c=7.4 in the intervention group, 6.7 in the usual care group). Though the intervention was not fully described in the paper, elements of it were tailored to the SMI population, including having the intervention delivered by mental health professionals and delivered to groups of individuals who all had a diagnosis of schizophrenia. Though a completers analysis showed that mean HbA1c decreased in the intervention group to 6.9 and increased in the usual care group to 6.8, between-group differences were not significant (p=0.44). There were no differences in overall rates of study discontinuation. Specific reasons for discontinuation were reported for 7 of the 64 participants who did not complete the study. Of these, three would be considered serious adverse effects (inpatient hospitalization, n=2; death prior to study commencement, n=1; psychiatric decompensation, n=1). Based on mean Positive and Negative Syndrome Scale (PANSS) scores, there was no significant worsening of psychiatric symptoms among the study groups.

Gillhoff et al.99 conducted a fair-quality randomized 5-month trial of a multicondition lifestyle intervention in individuals with bipolar disorder compared with a waitlist control group (n=50). The intervention was tailored to the SMI population in that the lifestyle and nutrition components (but not the fitness component) were delivered by mental health professionals. Additionally, the lifestyle component provided information about bipolar disorder. The total population mean baseline HbA1c was 5.5, with negligible between-group differences. Mean HbA1c changed minimally (0.1 or less) in the two groups at study completion and at 6-month followup, with a nonsignificant time by intervention term in a multivariate analysis (p-value not reported). Discontinuation due to adverse events and serious adverse events were not reported. Measures of psychiatric symptoms worsening were not reported.

##### Effect of Peer or Family Support Interventions on Diabetes Control

We identified no eligible studies for this category of intervention for KQ 2.

##### Effect of Pharmacological Treatments on Diabetes Control

###### Ramelteon

Only one study assessed the effects of a psychotropic agent on HbA1c.92 In this fair-quality study, individuals with schizophrenia (n=20) were randomized to an 8-week trial of the MT1 and MT2 melatonin-selective antagonist ramelteon compared with placebo control. Mean HbA1c changed negligibly at 8 weeks, with no significant between-group difference in mean change at study end between ramelteon and placebo control (5.74 to 5.82 vs. 5.45 to 5.45, baseline to followup, p=0.61). Five participants (two in the ramelteon group and two in the placebo group) out of the 25 initially randomized withdrew consent before the Week 4 assessment. Reasons for discontinuation were not reported. No serious adverse effects were reported.

###### Metformin

Two studies evaluated interventions utilizing metformin, one with the primary target of metabolic control,116 including glycemic control, and one with the primary target of obesity prevention101 with glycemic control measured as a secondary outcome.

Carrizo et al.116 conducted a fair-quality 14-week trial (61 participants) of extended release metformin in nondiabetic individuals receiving clozapine (94% with a diagnosis of schizophrenia) compared with placebo alone. The total population mean baseline HbA1c was 5.4, with negligible between-group differences. Mean HbA1c was increased modestly in both groups (+0.13 for metformin, +0.23 for placebo), though significantly less so in the metformin group (p=0.04). All 30 participants in the placebo group completed the study. No participant discontinued the study due to adverse effects, and no serious adverse effects were reported.

Hoffmann et al.101 conducted a poor-quality 22-week trial of two treatment algorithms that included both metformin and amantadine added to olanzapine compared with olanzapine alone in nondiabetic individuals with schizophrenia or schizoaffective disorder for prevention of weight gain (199 participants). Baseline HcA1c values were not reported. Treatment algorithm A consisted of 200 mg amantadine with possible switches to 1000 to 1500 mg metformin and then switches to 100 to 400 mg zonisamide. Treatment algorithm B was 1000 to 1500 mg metformin, with possible switches to 200 mg amantadine and then switches to 100 to 400 mg zonisamide. A combined-treatment group of both algorithm A and algorithm B did not differ significantly from the olanzapine-only group at 22-week followup for HbA1c (results not reported, p=0.278). Mean change in HbA1c for the algorithm A arm was negligibly higher (+0.01) at followup than in the olanzapine-only group (p=0.976). However, patients treated with algorithm B (beginning with metformin, with possible switches to amantadine, and then to zonisamide) demonstrated a statistically significant (−0.03 vs. +0.09, p=0.049) improvement in mean changes compared with the olanzapine-only group in HbA1c values at followup, though the magnitude of the effect was small. In total, 14 participants discontinued the study due to adverse effects (8 in algorithm A group, 4 in algorithm B group, and 2 in olanzapine-only group); only three of these, all in algorithm A groups, were considered serious adverse effects. Ten participants continued the study despite serious adverse effects (1 in algorithm A group, 4 in algorithm B group, and 5 in olanzapine-only group). There was no significant worsening of psychiatric symptoms among the study groups for Brief Psychiatric Rating Scale and Clinical Global Impression-Severity (CGI-S) scores.

##### Effect of Antipsychotic-Switching Interventions on Diabetes Control

Two studies evaluated antipsychotic-switching strategies.95,102 The primary outcome for these studies was weight management, with glycemic control measured as a secondary outcome. Patients in both studies began on olanzapine, and the control condition consisted of staying on olanzapine. The intervention involved switching to either quetiapine95 or orally disintegrating olanzapine.102 Neither study reported significant changes in HbA1c. Details are reported below. A third study, described in KQ 4, evaluated switching to aripiprazole as part of a multicomponent intervention. This study found no effect on HbA1c.

Deberdt et al.95 conducted a fair-quality 24-week trial of switching from olanzapine (baseline dose of 7.5 to 20 mg/day) to quetiapine (300 to 800 mg/day) in overweight or obese individuals with schizophrenia or schizoaffective disorder compared with staying on olanzapine (n=133). The total population mean baseline HbA1c was 5.9. Final mean modal daily doses for patients switching to quetiapine (n=68) and staying on olanzapine (n=65) were 16.9 mg and 439.7 mg, respectively. Patients who switched to quetiapine did not have significantly different changes in their HbA1c levels than those who remained on olanzapine (+0.07 and −0.03, p=0.318) in the last-outcome-carried-forward analysis. Significantly more patients in the olanzapine group completed 24 weeks of treatment than in the quetiapine group (70.3% vs. 43.1%, p=0.002).

Adverse effects leading to study discontinuation were classified as psychiatric adverse events and nonpsychiatric adverse events. Discontinuations due to psychiatric adverse events were more frequent in the quetiapine group than the olanzapine group (p=0.031). No significant differences were demonstrated for discontinuations due to nonpsychiatric adverse events or due to lack of efficacy, though a significant difference favoring olanzapine was demonstrated for the combination of discontinuations due to psychiatric adverse events or lack of efficacy. There were no significant differences in hospitalization rates (7.69% in the quetiapine group vs. 1.47% in the olanzapine group, p-value not reported). No other serious adverse events were reported. Based on mean PANSS scores, neither study arm demonstrated worsening of psychiatric symptoms.

Karagianis et al.102 conducted a good-quality 16-week trial of switching from standard olanzapine tablets to orally disintegrating olanzapine in individuals with schizophrenia, schizoaffective disorder, bipolar disorder, or another related psychotic disorder who had gained significant weight (defined as 5 kg or more or an increase of 1 kg/m^2^ in BMI) while on standard olanzapine tablets for 4 to 52 weeks compared with remaining on standard olanzapine tablets (n=149). The total population mean baseline HbA1c was 5.5, with negligible between-group differences. The final mean daily dose in the standard olanzapine tablets group (n=65) was 14.90 mg. Final mean daily dose in the orally disintegrating olanzapine group (n=84) was 14.33 mg. Patients who switched to orally disintegrating olanzapine did not have significantly different changes in their HbA1c levels from those who remained on olanzapine (+0.0 and +0.0, p=0.83). Results for health-related quality of life as measured by the Subjective Well-being Under Neuroleptics Scale showed no significant change from baseline to followup between groups (p=0.16). Two patients in each group discontinued treatment due to adverse effects. Two patients in the orally disintegrating olanzapine group experienced serious adverse effects, with one being hospitalized for dizziness and one attempting suicide. There was no significant worsening of psychiatric symptoms between groups as measured by the CGI-S scale.

### Summary of Key Question 2

Only one of the seven studies relevant to KQ 2 tested an intervention specifically intended to improve glucose control in individuals with diabetes and SMI.105 Of the other six studies, two had HbA1c as among the primary outcomes,92,116 and four focused more specifically on weight, with HbA1c measured as a secondary outcome.95,99,101,102 Overall, just two of the trials found significant advantages for the intervention in controlling HbA1c, with both of these studies involving the use of metformin. Carrizo et al.116 demonstrated that metformin in nondiabetic individuals receiving clozapine led to significantly less increase in HbA1c during the 14-week study. Hoffmann et al.101 showed that a treatment algorithm, beginning with metformin and possible switches to amantadine and then to zonisamide, demonstrated a statistically significant improvement in mean changes in HbA1c when added to olanzapine treatment in nondiabetic individuals compared with those receiving only olanzapine over 22 weeks. In both of these instances, mean advantages for the interventions were modest (−0.10 to −0.12). Behavioral interventions,99,105 antipsychotic switching,95,102 and the psychotropic drug ramelteon92 resulted in no significant differences in HbA1c control in individuals with SMI. Outcomes regarding weight and lipids are summarized in KQ 1 and KQ 3, respectively. In brief, health-related quality of life and serious adverse events were inconsistently reported in the seven trials. Health-related quality of life was reported in only one of the trials with no significant effect demonstrated. No trials reported on mortality.

## Key Question 3 Effectiveness of Dyslipidemia-Management Interventions

KQ 3: What is the effectiveness of dyslipidemia-management behavioral interventions (e.g., behavioral counseling, health education), peer or family support interventions, pharmacological treatments (e.g., statins), antipsychotic medication–switching to an antipsychotic with a low or neutral impact on lipid levels, or their combination on lipid-level control and related physical health outcomes (e.g., health-related quality of life, mortality) when compared with each other or with usual care (or other control) among adults with SMI who have dyslipidemia or are taking antipsychotics?

### Key Points

- Lipid levels have not been a primary target for interventions studied in individuals with SMI. While 15 RCTs reported lipid levels as a secondary outcome (the studies included in this section), no studies evaluated an intervention specifically designed to target lipid levels in individuals with SMI who have or are at risk for dyslipidemia. Hence, the strength of evidence for each intervention examined in KQ 3 is insufficient.
- Interventions known to be effective for managing dyslipidemia, such as medications (e.g., HMG-CoA reductase inhibitors) or dietary interventions, have not been studied in SMI populations. It seems that such interventions should be considered for clinical use, but direct evidence in SMI populations is lacking.
- Behavioral interventions were found in a meta-analysis to have no advantage over usual care for managing low-density lipoprotein (LDL) levels, but this analysis consisted of three small, 3- to 12-month studies aimed primarily at either weight or diabetes management.
- Small improvements in lipids were seen in one study of ramelteon, one study of topiramate, and one study that used a sequenced medication algorithm of amantadine, metformin, and zonisamide.
- Lipid levels improved modestly in two studies of aripiprazole—one that added aripiprazole to chronic clozapine and one that switched patients from olanzapine to aripiprazole. Switching from oral to injectable olanzapine increased LDL cholesterol.

### Detailed Synthesis

We identified no articles reporting on trials in which the intervention was designed to target lipid levels. Specifically, no study evaluated HMG-CoA reductase inhibitors (statins), niacin, fibrates, or low-fat diets. However, 15 of the eligible studies, involving 2322 patients, reported on total cholesterol (n=12) or LDL cholesterol (n=14) as a secondary outcome.89,91,92,95,98–102,105,106,108,114,115,119 All of these trials were published from 2005 forward, with reported recruitment dates spanning from 2001 to 2010. The primary outcomes of interest were weight (n=12), glucose control (n=1), and all-purpose metabolic effects (n=2). Of the 15 trials that reported on lipid levels, all 15 were included in KQ 1 (weight), 7 were included in KQ 2 (glucose control), and none were included in KQ 4 (multicondition interventions). Detailed analyses of the outcomes for weight control (KQ 1) and glucose control (KQ 2) are presented in other sections of the Results chapter. The experimental intervention was psychotropic medication in three trials, antipsychotic switching in four trials, behavioral interventions in three trials, neurological agents in three trials, an antihistamine in one trial, and a neurological agent or a biguanide in one trial (this trial was the only one with three arms instead of two).

Common inclusion criteria were a diagnosis of schizophrenia (n=12), taking an antipsychotic medication (n=10), and being overweight or obese (n=7). Common exclusion criteria were active substance abuse (n=7), being pregnant or breastfeeding (n=8), being on non-study approved medication (n=8), and having a chronic medical condition (n=12). The number of participants randomized ranged from 21 to 1065, and the number who completed studies ranged from 18 to 677.

Trials received funding from private industries (n=13) and government (n=4). Five of the 15 studies were conducted in multiple countries, with patients coming from the United States in 8 studies, Europe in 5 studies, Asia in 2 studies, South America in 1 study, and Africa in 1 study. Six studies were conducted at a single study site, and 4 studies contained 19 or more study sites. One study contained 112 study centers across 26 countries.108 This study contained 44 percent of the overall number of patients across the 15 studies, with samples from the 6 largest studies95,98,101,102,106,108 accounting for 81 percent of the total sample size for KQ 3.

#### Study Characteristics

Table 9 shows the study characteristics for KQ 3. The majority of patients were male, white, and middle-aged. The vast majority were classified as having schizophrenia or schizoaffective disorder (92%), with 6 percent having bipolar disorder and less than 2 percent classified as having serious mental illness not further specified. None of the studies reported on whether patients were diagnosed with hyperlipidemia. Average baseline total cholesterol and LDL levels for most studies were in a clinically acceptable range. Patients in the large majority of studies were reported as taking a second-generation antipsychotic medication. Studies were conducted primarily in outpatient mental health settings and most commonly examined medication compared with placebo. Nine studies lasted 2 to 4 months, four studies lasted 5 to 6 months, and two studies lasted 11 to 12 months. Most studies were rated fair quality, with common reasons for reduced study quality being insufficient details provided about the study, inadequate blinding, and conducting analyses only on treatment completers. There was a relatively even split between trials that were characterized as efficacy studies and those characterized as a mixed efficacy–effectiveness.

Table 9 Study characteristics for KQ 3: Dyslipidemia-management interventions

Characteristic | Details
Studies: N (patients)^a^ | 15 studies (2322 patients)
Mean age of sample: Median (range) | 39.0 (31.1 to 54.0)
Sex: N patients (%)
Female | 810 patients (35%)
Male | 1379 patients (59%)
NR | 133 patients (6%)
Race: N patients (%)
White | 1408 patients (61%)
Nonwhite | 603 patients (26%)
NR | 299 patients (13%)
Mean lipid levels: Median (range)
Total cholesterol | 198 mg/dl (133 mg/dl to 212 mg/dl)
LDL | 120 mg/dl (72 mg/dl to 138 mg/dl)
Setting: N studies (%)
Mental health outpatient | 9 studies (60%)
Outpatient setting not otherwise specified | 2 studies (13%)
Community | 1 study (7%)
NR | 3 studies (20%)
Study quality: N studies (%)^b^
Good | 4 studies (27%)
Fair | 8 studies (53%)
Poor | 3 studies (20%)
Efficacy–effectiveness rating: N studies (%)
Efficacy (0–2) | 8 studies (53%)
Mixed (3–5) | 7 studies (47%)
Effectiveness (6–7) | 0 studies (0%)
Comparisons: N studies (patients)
Drug vs. placebo/control | 7 studies (447 patients)
Behavioral vs. control | 3 studies (156 patients)
Antipsychotic switching vs. antipsychotic stay | 4 studies (1520 patients)
Drug vs. drug vs. placebo control | 1 study (199 patients)

LDL = low-density lipoprotein; N = number; NR = not reported

a The number of patients with demographic data reported is fewer than the number randomized.

b Quality ratings in the table are reported on the basis of how studies were conducted in relation to physical health outcomes. Ratings were also applied on the basis of psychiatric outcomes. Quality ratings did not differ for any studies on the basis of physical versus psychiatric outcomes.

#### Meta-Analysis and Qualitative Review

There was a sufficient number of studies with cohesive intervention strategies to conduct a meta-analysis only for the effect of behavioral interventions on lipid levels. Results for the other effects are summarized qualitatively.

##### Effect of Behavioral Interventions on Lipid Control

Figure 9 shows the forest plot of the meta-analysis examining the effect of behavioral interventions on LDL levels, which included two fair-quality studies99,105 and one poor-quality study114 (156 patients). Two of the behavioral interventions focused on weight management, and one focused on diabetes management. All interventions included components that focused on physical activity and exercise as well as on diet and nutrition. Interventions were adapted for SMI populations by simplifying content to focus on key points (e.g., introducing only one or two topics per session) and by employing concrete behavioral change strategies (e.g., food diaries, pedometers). The number of planned contacts ranged from 7 to 24 sessions, and duration of followup ranged from 3 to 12 months. Control conditions consisted of waitlist, no intervention, and usual care plus information (see Table 7 in KQ 1 section for details). These control group conditions were combined in the meta-analysis, as participants in waitlist and no intervention conditions were allowed to continue receiving usual care.

Figure 9 Forest plot of meta-analysis of effect of behavioral interventions on LDL levels

CI = confidence interval; LDL = low-density lipoprotein

This figure shows the forest plot of the meta-analysis examining the effect of behavioral interventions on low-density lipoprotein (LDL) levels, which included three studies. Pooled results demonstrated no statistically significant difference in efficacy between behavioral interventions and control for managing LDL levels (mean difference, 1.91 mg/dl; 95% CI, −6.06 to 9.88).

The analysis revealed no statistically significant difference in efficacy between behavioral interventions and control for managing LDL levels (mean difference, 1.91 mg/dl; 95% CI, −6.06 to 9.88), with no evidence of heterogeneity (Cochran Q=0.07, df=2, p=0.96; I^2^=0%). Again, because formal statistical techniques for publication bias are not effective with small numbers of studies, we did not conduct analyses for publication bias. Only one of the three studies on behavioral interventions reported on adverse effects as defined in our study protocol,114 which reported that no drug-related severe adverse effects were observed. None of the studies reported on health-related quality of life.

Only two of the behavioral intervention studies reported on total cholesterol. In a 5-month multimodal lifestyle intervention that consisted of 11 group sessions and weekly fitness training for bipolar disorder patients (n=50), no significant differences were found between those in the lifestyle intervention group and those in a waiting control group.99 In a 3-month psychoeducational program for weight control in patients who experienced weight gain on olanzapine (n=33), there were no significant differences in total cholesterol between those in the psychoeducational program and those receiving no intervention.114

##### Effect of Peer or Family Support Interventions on Lipid Control

We identified no eligible studies for this category of intervention for KQ 3.

##### Effect of Pharmacological Treatments on Lipid Control

###### Psychotropic Agents

A total of one good-quality98 and two fair-quality91,92 studies examined the effect of psychotropic medications on lipids (321 patients). Two of these studies recorded data on total cholesterol and all three studies on LDL. Study medications were ramelteon, aripiprazole, and atomoxetine, and the comparator in each study was placebo. The study durations ranged from 2 to 6 months.

Although ramelteon, aripiprazole, and atomoxetine all can be classified as psychotropic medications, we did not conduct a meta-analysis on the studies using these medications because their mechanisms of action vary substantially. Indeed, when examined qualitatively, results were mixed. The 24-week study of overweight schizophrenia patients (n=37) taking olanzapine or clozapine who were randomized to atomoxetine or placebo did not measure total cholesterol levels and found no difference between groups on change in LDL levels.91 However, two of the studies did find significant change between groups. The small 8-week pilot trial on ramelteon (n=25) found that stable outpatients with schizophrenia were significantly more likely to experience a decrease in total cholesterol (−9.79 mg/dl loss vs. 3.84 mg/dl gain, p=.03) when taking ramelteon than placebo.92 Change in LDL levels displayed the same pattern, but group differences were not significant in this small study. Groups did not significantly differ on changes in psychiatric symptoms over the course of this study. In a 16-week trial of aripiprazole versus placebo among 207 schizophrenia patients who had experienced weight gain while taking clozapine,98 those in the aripiprazole group had greater percentage reductions in their total cholesterol levels (−6.9% vs. −1.2%, p=.002) and LDL levels (−10.3% vs. 0.0%, p=.003). Psychiatric symptoms improved more in the aripiprazole group over the course of this study (p=.037).

Of the three studies examining the effect on lipid levels of adding medication, none found significant changes between groups on psychiatric symptoms, and only one reported on health-related quality of life or on serious adverse effects as defined by the study protocol.98 This study found no significant differences between patients taking aripiprazole as an adjunctive medication to clozapine and patients taking placebo and clozapine on a measure of subjective well-being, but the study did find 0 out of 99 patients in the placebo group and 10 out of 108 patients in the aripiprazole group to experience a serious adverse effect.

###### Neurological Agents

The effect of neurological agents on lipids was examined in one good-quality,115 one fair-quality,119 and two poor-quality100,101 trials. Three of these studies employed a two-arm design (135 patients),100,115,119 and one study used a three-arm design (199 patients).101 In all two-arm studies, the control condition was placebo. Study medications were amantadine, topiramate, and zonisamide (the three-arm study also involved metformin), and study durations ranged from 3 to 5 months. We were unable to complete meta-analysis on these studies due to heterogeneous study designs and unreported lipid outcome data (one study100 stated only that results for lipids were not significant).

Results were mixed in the three two-arm studies that examined neurological agents compared with placebo. A 12-week study of amantadine versus placebo among 21 patients who had gained at least 5 pounds on olanzapine found no differences between groups on total cholesterol or LDL levels.100 In a 12-week study of 72 first-episode schizophrenia patients randomized to either olanzapine plus topiramate or olanzapine plus placebo,119 patients taking topiramate were significantly less likely than those in the placebo group to experience a rise in LDL levels (0.34 mg% rise vs. 10.53 mg% rise, p=.009). Finally, a 16-week study of zonisamide versus placebo in 42 patients beginning olanzapine for bipolar disorder or schizophrenia found no significant differences between groups on total cholesterol or LDL levels.115 None of these three studies reported on health-related quality of life or serious adverse effects.

The three-arm, 22-week study101 examined two different medication treatment-switching algorithms for prevention of weight gain compared with no medication in 199 patients with schizophrenia or schizoaffective disorder who were all taking olanzapine. The algorithms using amantadine, metformin, and zonisamide were significantly more effective at preventing increases in total cholesterol than olanzapine treatment alone (0.18 mg/dl gain and −1.44 mg/dl loss on algorithms vs. 6.49 mg/dl gain on olanzapine alone). The algorithms had a less pronounced and nonsignificant effect for LDL. Health-related quality of life was not measured. Thirteen patients experienced a serious adverse effect, and a total of 14 patients discontinued the study due to a serious or nonserious adverse effect (group differences not tested).

###### Nizatidine

A 12-week, good-quality study that examined the efficacy of nizatidine versus placebo for weight management in 54 patients with schizophrenia taking olanzapine found no statistically significant differences between groups with respect to the intervention’s effect on lipid levels.89 The study did not measure health-related quality of life. There was no significant difference between groups with respect to adverse effects, with one patient in the nizatidine group and two patients in the placebo group discontinuing due to an adverse effect.

##### Effect of Antipsychotic-Switching Interventions on Lipid Control

There was a total of one good-quality102 and three fair-quality95,106,108 studies (1376 patients) that examined the effect of switching antipsychotic medications on lipids. Patients in all studies began on olanzapine, and in all studies the control condition consisted of staying on olanzapine. The intervention in two studies involved switching to a different form of olanzapine (an orally disintegrating tablet or a long-acting injection) and in the other two studies involved switching to a different antipsychotic medication (quetiapine or aripiprazole). Study durations ranged from 4 to 6 months. Meta-analysis was not completed on these four studies due to the heterogeneity of switching strategies.

There were mixed results in the two studies that examined switching to a different form of olanzapine.102,108 In the 16-week trial of 149 patients with SMI that involved switching from standard olanzapine tablets to orally disintegrating olanzapine tablets,102 there was no difference between groups with respect to lipid levels. This study found no difference between groups on a measure of subjective well-being. Serious adverse effects were experienced by two patients in the orally disintegrating olanzapine group and none in the standard olanzapine tablet group.

In the 24-week trial of 921 patients with schizophrenia that involved switching from oral olanzapine to a long-acting injection of olanzapine,108 patients continuing oral olanzapine experienced a significantly greater decrease in LDL levels than did patients in the long-acting injection group (−6.4 mg/dl loss vs. −1.5 mg/dl loss, p=.039). The groups did not differ on total cholesterol. This study did not measure health-related quality of life. Serious adverse effects were reported in 42 patients, and 57 patients discontinued due to adverse effects, but the authors report that there was no statistically significant difference between groups for adverse effects.

The studies that examined switching from olanzapine to a different antipsychotic medication95,106 also had mixed results. In the 24-week study of 133 overweight patients with schizophrenia that examined switching from olanzapine to quetiapine,95 those who switched to quetiapine did not have significantly different changes in their total cholesterol or LDL levels than those who remained on olanzapine. This study did not report on health-related quality of life or serious adverse effects as defined by study protocol. While the study found no difference between groups on treatment-emergent adverse events, discontinuation was significantly higher in the quetiapine group (56.9% discontinued vs. 29.4%, p=.002). In the 16-week trial of 173 patients with schizophrenia who either stayed on olanzapine or switched to aripiprazole,106 those who switched to aripiprazole had a significantly greater percentage decrease in total cholesterol (−9.5% vs. −3.3%, p=.005) and a nonsignificantly greater percentage decrease in LDL (−11.2% vs. −4.7%, p=.072). This study did not report on health-related quality of life but did find that six aripiprazole-treated patients experienced a serious adverse effect and seven discontinued, compared with nine olanzapine-treated patients who experienced a serious adverse effect and eight who discontinued.

### Summary of Key Question 3

None of the 15 studies in KQ 3 contained an intervention specifically intended to target lipid levels. Instead, the primary outcomes of interest were weight in 12 of the studies, glucose control in 1 study, and all-purpose metabolic effects in 2 studies. Total cholesterol was measured in 12 studies and LDL in 14 studies. Overall, 6 of the 15 trials found significant changes between study groups on lipid levels. The interventions in these studies included ramelteon,92 topiramate,119 medication treatment algorithms,101 and aripiprazole.98,106 In all instances, intervention effects resulted in a 5-percent or less difference in lipid values compared with control (placebo or stay on original medication). Also, one study testing a long-acting injection of olanzapine found that participants receiving the injection were less likely than those remaining on oral olanzapine to experience a decrease in LDL.108 Since all studies were evaluating lipids as a secondary outcome and are summarized in KQ 1, the details regarding other health outcomes are summarized in that section. In brief, health-related quality of life and serious adverse effects were infrequently reported in the 15 trials. Health-related quality of life was reported in only 2 of the 15 trials. Serious adverse effects were reported in four studies, and adverse effects leading to treatment discontinuation were reported in seven studies.

## Key Question 4 Effectiveness of Multicondition Lifestyle Interventions

KQ 4: What is the effectiveness of multicondition lifestyle interventions (e.g., combinations of smoking cessation, physical activity, and nutrition counseling with or without medication management) on cardiovascular risk factors and related physical health outcomes (e.g., health-related quality of life, mortality) among adults with SMI who have cardiovascular disease, elevated cardiovascular risk (e.g., hypertension), or are taking antipsychotics?

### Key Points

- Only three studies evaluated lifestyle interventions. Lifestyle interventions consisted primarily of dietary and exercise components. One study offered additional provisions such as heart rate monitors and financial subsidies to support the exercise component.
- One study reported small to moderate beneficial effects on body mass index (BMI), weight, and cholesterol:
  ○ This good-quality study showed benefit in switching from olanzapine, quetiapine, or risperidone to aripiprazole in the context of a manualized, behaviorally oriented diet and exercise program.
  ○ The effects of the behavioral component of the lifestyle intervention in this study are unknown, since both the intervention and comparison arm received the behavioral component.
- Two studies reported significant benefits of multicondition lifestyle interventions for self-reported health-related quality of life.
- Studies included in KQ 4 varied substantially on methodological rigor and quality variables.
- Overall, the evidence is insufficient to estimate the effects of multicondition lifestyle interventions.

### Detailed Synthesis

Studies relevant to KQ 4 evaluated multicondition lifestyle interventions (e.g., combinations of behavioral and medication management, broadly conceived behavioral interventions) for more than one CVD risk factor (e.g., metabolic syndrome) or health condition. We identified 3 studies involving 286 patients that assessed the effects of lifestyle interventions on CVD risk factors and related physical health outcomes among adults with SMI.120–122 Two of these studies evaluated broadly conceived behavioral interventions, and one evaluated the combination of antipsychotic switching in combination with a behavioral intervention. No study addressed multiple conditions associated with CVD risk such as obesity, diabetes mellitus, and hypertension.

#### Study Characteristics

Table 10 shows the study characteristics for KQ 4. The diagnostic samples identified by these studies included schizophrenia-only120 and SMI (i.e., psychotic and mood disorders).121,122 Two studies were conducted in the United States120,122 and one in Europe.121 One study120 was conducted in several clinical research centers, while one121 was conducted in supported housing facilities. The third study122 reported that recruitment was conducted at a large mental health facility’s inpatient and outpatient programs and surrounding community treatment centers, but the location of intervention delivery was unclear. Compared with studies included in the other KQs, these studies had less restrictive exclusion criteria. Thus, participants could have been included who had other comorbid physical conditions. The study by Stroup et al.120 was rated as a mixed efficacy–effectiveness study of good quality, Forsberg et al.121 as a mixed efficacy–effectiveness study of fair quality, and Skrinar et al.122 as an efficacy study of fair quality.

Table 10 Study characteristics for KQ 4: Multicondition lifestyle interventions

Characteristic | Details
Studies: N studies (patients)^a^ | 3 studies (286 patients)
Mean age of sample: Median (range) | 41.0 (41.0 to 37.8)
Sex: N patients (%)
Female | 114 patients (40%)
Male | 172 patients (60%)
NR | 0 patients (0%)
Race: N patients (%)
White | 123 patients (43%)
Nonwhite | 90 patients (31%)
NR | 73 patients (26%)
Setting: N studies (%)^b^
Mental health | 2 studies (67%)
General medical | 0 studies (0%)
Community | 2 studies (67%)
Integrated mental health-medical | 0 studies (0%)
Study quality: N studies (%)
Good | 1 study (33%)
Fair | 2 studies (67%)
Poor | 0 studies (0%)
Efficacy–effectiveness rating: N studies (%)
Efficacy (0–2) | 1 study (33%)
Mixed (3–5) | 2 studies (66%)
Effectiveness (6–7) | 0 studies (0%)
Comparisons: N studies (patients)
Drug + behavioral vs. drug | 1 study (215 patients)
Lifestyle intervention vs. control | 2 studies (71 patients)
Mean BMI (study range) | 3 studies (21.55 to 35)
Mean HbA1c% (study range) | 2 studies (4.16 to 6.0)
Mean systolic blood pressure | 1 study (133.9)
Mean total cholesterol | 1 study (217)
Mean non-HDL cholesterol | 1 study (173)
Current smoker: N studies; N patients (%) | 1 study; 19 of 41 patients (46%)
NR | 2 studies; 286 patients
Metabolic syndrome: N patients (%) | 1 study; 21 of 41 patients (51%)
NR | 2 studies; 286 patients

BMI = body mass index; HbA1c = hemoglobin A1c; HDL = high-density lipoprotein; N = number; NR = not reported

a The number of patients with demographic data reported is fewer than the number randomized.

b Stroup et al.120 selected participants from both mental health and community settings.

#### Qualitative Review

The three studies included in KQ 4 are described below qualitatively due to the variability in interventions and outcomes.

##### Effect of Multicondition Lifestyle Interventions on Cardiovascular Risk Factors

In a fair-quality mixed efficacy–effectiveness study by Forsberg et al.,121 46 participants were randomized to receive either a health intervention program or a non–health-related control program for 12 months. Demographic and outcome data were reported for the 41 participants who completed the study. Importantly, participants were recruited from supported housing facilities. The health intervention program, aimed at improving physical health, provided group dietary education, physical activity sessions, provision of a heart rate monitor, and a 50-percent financial subsidy that supported entrance at sports centers and equipment rental. Group sessions were 2 hours in duration and were held twice weekly for the entire 12-month study. The control group attended art classes held once weekly for 2 hours.

At baseline, rates of schizophrenia (intervention=17, control=6) and metabolic syndrome (intervention=16, control=5) were significantly higher in the resident intervention group compared with the resident control group. At followup, no significant differences between the active and control groups were reported for BMI, weight in kilograms, HbA1c percentage, systolic blood pressure, diastolic blood pressure, smoking cessation, or a composite CVD risk score at 13.5 months. There was a significant decrease in the number of individuals diagnosed with metabolic syndrome in the intervention group (from 13 to 10), while there was a nonsignificant increase in the number of individuals diagnosed with metabolic syndrome in the control group (from 4 to 6); however, these changes did not differ significantly between the intervention and control groups. This was true also for systolic blood pressure, which demonstrated a significant decrease from baseline to followup in the intervention group (from 139.0 to 124.9), but no between-group difference was observed. After the authors controlled for sex and age, a significant reduction in triglycerides was observed for participants over 40 years of age in both groups; between-group change was nonsignificant. A performance-based measure of physical functioning, the incremental shuttle walk test, was not affected by the intervention. Adverse effects were not reported. Quality issues included low attendance at group sessions, inability of the researchers to control whether participants in the comparison condition engaged in exercise or dieting while enrolled, no intent-to-treat analysis, and absence of a description of the antipsychotic medication status of study participants.

In a fair-quality efficacy study by Skrinar et al.,122 30 individuals with SMI were randomized to a healthy lifestyle group or to a waitlist control group for 12 weeks; outcome data were reported for the 20 participants who completed the study. Participants in this study were recruited from inpatient and outpatient units and from a community treatment facility. The healthy lifestyle intervention consisted of four exercise sessions each week and weekly health seminars covering a broad range of topics (e.g., healthy eating, weight management, stress relief) and intended to target weight gain and physical fitness. Participants in the control group were offered the exercise intervention following the initial 12-week study period and were informed that it was not necessary to limit physical activity. Both the lifestyle and control groups kept detailed logs of any exercise sessions.

There were no significant differences between groups at 12 weeks for BMI, weight, total cholesterol, glucose, or psychiatric symptom severity (as measured by the Symptom Checklist-90 score). Participants in the intervention group showed significantly greater increases in their subjective rating of general health as measured by the General Health factor of the SF-36 scale (intervention group mean difference, 13.64 vs. control group, −4.09, p=.01). Self-reported physical health and role limitations due to physical health also improved more in the intervention group, but the differences were not statistically significant. Adverse effects were not reported. Quality issues included low adherence rate (63%), small sample size, and lack of an intent-to-treat analysis. Study authors noted specific barriers to participation in the intervention (e.g., transportation, financial issues), which contributed to the low adherence rate—highlighting a common challenge of exercise interventions in the SMI population. They emphasized the positive impact of the intervention on perceived health-related well-being despite the lack of significant behavioral or metabolic changes.

In contrast to the other two studies, the third study by Stroup et al.120 was a large (n=215), good-quality, mixed efficacy–effectiveness trial (Comparison of Antipsychotics for Metabolic Problems) carried out between January 2007 and March 2010. This study examined the impact of switching from the antipsychotics olanzapine, quetiapine, or risperidone to aripiprazole (flexible dose) on weight and metabolic variables. All participants in the study took part in a manualized, behaviorally oriented diet and exercise program (once weekly visits for the first month, followed by once monthly visits thereafter) that was based on previous group protocols used with SMI populations.82,93 After the first 4 weeks, study personnel contacted participants with a telephone call to reinforce the behavioral treatment lessons between each of the monthly visits. Laboratory assessments were conducted every 4 weeks. The trial was carried out at 27 clinical research centers affiliated with the Schizophrenia Trials Network in the United States and was 24 weeks in duration. Participants were required to have a BMI greater than or equal to 27 and a non-HDL cholesterol greater than or equal to 130 mg/dl in order to be study eligible. The intervention arm of this study was intended to target metabolic risk factors for cardiovascular disease and included multiple outcomes of interest.

Overall, the results of this study supported switching to aripiprazole combined with a behavioral health-management program as a useful method for managing weight gain and metabolic problems in individuals with SMI and antipsychotic-related weight gain. Significant group effects were observed for BMI (mean difference, −1.1; p<.01), weight (mean difference, −2.9 kg; p<.01), total cholesterol (mean difference, −8.8 mg/dl; p=.02), and non-HDL cholesterol (mean difference, −9.4 mg/dl; p=.01). Stroup et al.120 also reported significant intervention effects for health-related quality of life as indicated by the 12-Item Short-Form Health Survey for physical health (mean difference, 3.7; p<.02) and the Impact of Weight on Quality of Life–Lite Questionnaire (mean difference, −9.5; p<.01), with an advantage on both of these measures for patients who switched to aripiprazole. Serious adverse effects occurred in 16.8 percent of the group who switched to aripiprazole and 13.1 percent of those remaining on their current antipsychotic treatment (p-value not reported). There were no significant group effects for psychiatric symptoms as measured by the CGI-S assessment.

The biggest limitation of this study was differential attrition, with 47.7 percent of participants who switched medication discontinuing the study for any reason compared with 27.4 percent of those who did not switch. The authors speculated that this was due to clinician detection of clinical worsening in the switch group, which was confirmed in a post-hoc analysis. This highlights the need for careful clinical monitoring following medication switching. Despite the high rate of attrition, we rated the study as good quality since the authors thoroughly examined and accounted for incomplete data, and the study rated high on many other aspects of quality (e.g., performance bias, detection bias). Unlike the other two studies included in KQ 4, this study detected significant differential effects on weight and metabolic variables between the study groups. Although this study is informative with regard to medication switching, it did not examine the specific effect of the behavioral intervention, which all participants received. Therefore, we cannot speculate on the impact of this aspect of the lifestyle intervention beyond the effects of the medication.

### Summary of Key Question 4

Only three published studies met inclusion criteria for KQ 4. The small number of RCTs and narrow range of interventions preclude drawing strong conclusions about the efficacy or effectiveness of multicondition lifestyle interventions on CVD risk factors or physical health outcomes for adults with SMI. Because these studies were highly inclusive of participants and outcomes (containing any study that targeted more than one condition), the specific physical parameters targeted were broad or at times loosely defined.

The behavioral component of the identified studies focused only on exercise and nutrition. One study also provided heart rate monitors and financial subsidies to support the physical activity component. No studies added components such as medication adherence, smoking cessation, or skills training (e.g., meal planning) that would have constituted a more comprehensive behavioral intervention. Further, no studies evaluated lifestyle interventions in combination with medications for weight loss (e.g., orlistat) or metabolic risk factors such as HMG-CoA reductase inhibitors for hyperlipidemia. The most important signal from these studies is that switching to aripiprazole—in combination with a structured behavioral intervention—is a promising strategy for minimizing adverse metabolic consequences of second-generation antipsychotics. However, the tradeoff may be a higher rate of worsening psychiatric status for the individual with SMI. Multicondition interventions demonstrated some promise for affecting health-related quality of life, as indicated by the effects of two of the three included studies.