# References

1 National Institute of Mental Health. Statistics. www.nimh.nih.gov/statistics/index.shtml. Accessed June 22, 2012.
2 National Institute of Mental Health. Statistics. Schizophrenias. www.nimh.nih.gov/statistics/1SCHIZ.shtml. Accessed June 22, 2012.
3 Epstein J, Barker P, Vorburger M, et al. Serious mental illness and its co-occurrence with substance use disorders, 2002. (DHHS Publication No SMA 04-3905, Analytic Series A-24). Rockville, MD. Substance Abuse and Mental Health Services Administration, Office of Applied Studies. www.samhsa.gov/data/CoD/CoD.pdf. Accessed June 22, 2012.
4 Chang C-K, Hayes R, Broadbent M, et al. All-cause mortality among people with serious mental illness (SMI), substance use disorders, and depressive disorders in southeast London: a cohort study. BMC Psychiatry. 2010;10(1):77. [pmid: 20920287].
5 Brown AS, Birthwhistle J. Excess mortality of mental illness. Br J Psychiatry. 1996;169(3):383-4. [pmid: 8879735].
6 Hsu JH, Chien IC, Lin CH, et al. Incidence of diabetes in patients with schizophrenia: a population-based study. Can J Psychiatry. 2011;56(1):19-26. [pmid: 21324239].
7 Dixon L, Weiden P, Delahanty J, et al. Prevalence and correlates of diabetes in national schizophrenia samples. Schizophr Bull. 2000;26(4):903-12. [pmid: 11087022].
8 van Winkel R, De Hert M, Van Eyck D, et al. Prevalence of diabetes and the metabolic syndrome in a sample of patients with bipolar disorder. Bipolar Disord. 2008;10(2):342-8. [pmid: 18271914].
9 Bresee LC, Majumdar SR, Patten SB, et al. Prevalence of cardiovascular risk factors and disease in people with schizophrenia: a population-based study. Schizophr Res. 2010;117(1):75-82. [pmid: 20080392].
10 Weiner M, Warren L, Fiedorowicz JG. Cardiovascular morbidity and mortality in bipolar disorder. Ann Clin Psychiatry. 2011;23(1):40-7. [pmid: 21318195].
11 Kilbourne AM, Morden NE, Austin K, et al. Excess heart-disease-related mortality in a national study of patients with mental disorders: identifying modifiable risk factors. Gen Hosp Psychiatry. 2009;31(6):555-63. [pmid: 19892214].
12 Miller BJ, Paschall CB 3rd, Svendsen DP. Mortality and medical comorbidity among patients with serious mental illness. Psychiatr Serv. 2006;57(10):1482-7. [pmid: 17035569].
13 Fagiolini A, Goracci A. The effects of undertreated chronic medical illnesses in patients with severe mental disorders. J Clin Psychiatry. Suppl 3. 2009;70:22-9. [pmid: 19570498].
14 Ryan MC, Collins P, Thakore JH. Impaired fasting glucose tolerance in first-episode, drug-naive patients with schizophrenia. Am J Psychiatry. 2003;160(2):284-9. [pmid: 12562574].
15 Kupfer DJ. The increasing medical burden in bipolar disorder. JAMA. 2005;293(20):2528-30. [pmid: 15914754].
16 McCreadie RG. Diet, smoking and cardiovascular risk in people with schizophrenia: descriptive study. Br J Psychiatry. 2003;183:534-9. [pmid: 14645025].
17 McElroy SL. Obesity in patients with severe mental illness: overview and management. J Clin Psychiatry. Suppl 3. 2009;70:12-21. [pmid: 19570497].
18 Fountoulakis KN, Siamouli M, Panagiotidis P, et al. Obesity and smoking in patients with schizophrenia and normal controls: a case-control study. Psychiatry Res. 2010;176(1):13-6. [pmid: 20079934].
19 Brown S, Birtwistle J, Roe L, et al. The unhealthy lifestyle of people with schizophrenia. Psychol Med. 1999;29(3):697-701. [pmid: 10405091].
20 Kilbourne AM, Rofey DL, McCarthy JF, et al. Nutrition and exercise behavior among patients with bipolar disorder. Bipolar Disord. 2007;9(5):443-52. [pmid: 17680914].
21 Newcomer JW. Metabolic considerations in the use of antipsychotic medications: a review of recent evidence. J Clin Psychiatry. Suppl 1. 2007;68:20-7. [pmid: 17286524].
22 Kendler KS, Gallagher TJ, Abelson JM, et al. Lifetime prevalence, demographic risk factors, and diagnostic validity of nonaffective psychosis as assessed in a US community sample. The National Comorbidity Survey. Arch Gen Psychiatry. 1996;53(11):1022-31. [pmid: 8911225].
23 Viron MJ, Stern TA. The impact of serious mental illness on health and healthcare. Psychosomatics. 2010;51(6):458-65. [pmid: 21051676].
24 Desai MM, Rosenheck RA, Druss BG, et al. Receipt of nutrition and exercise counseling among medical outpatients with psychiatric and substance use disorders. J Gen Intern Med. 2002;17(7):556-60. [pmid: 12133146].
25 Druss BG, Rosenheck RA, Desai MM, et al. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-36. [pmid: 11802085].
26 Green JL, Gazmararian JA, Rask KJ, et al. Quality of diabetes care for underserved patients with and without mental illness: site of care matters. Psychiatr Serv. 2010;61(12):1204-10. [pmid: 21123404].
27 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. 2005;165(22):2631-8. [pmid: 16344421].
28 Mitchell AJ, Lord O. Do deficits in cardiac care influence high mortality rates in schizophrenia? A systematic review and pooled analysis. J Psychopharmacol. 2010;24(4 Suppl):69-80. [pmid: 20923922].
29 McGuire J, Gelberg L, Blue-Howells J, et al. Access to primary care for homeless veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services. Administration and Policy in Mental Health. 2009;36(4):255-64. [pmid: 19280333].
30 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial. Arch Gen Psychiatry. 2001;58(9):861-8. [pmid: 11545670].
31 Warner CH, Morganstein J, Rachal J, et al. Perceptions and practices of graduates of combined family medicine-psychiatry residency programs: a nationwide survey. Acad Psychiatry. 2007;31(4):297-303. [pmid: 17626192].
32 Bradford DW, Kim MM, Braxton LE, et al. Access to medical care among persons with psychotic and major affective disorders. Psychiatr Serv. 2008;59(8):847-52. [pmid: 18678680].
33 Druss BG, Zhao L, von Esenwein SA, et al. The Health and Recovery Peer (HARP) Program: a peer-led intervention to improve medical self-management for persons with serious mental illness. Schizophr Res. 2010;118(1–3):264-70. [pmid: 20185272].
34 Peck MC, Scheffler RM. An analysis of the definitions of mental illness used in state parity laws. Psychiatr Serv. 2002;53(9):1089-95. [pmid: 12221306].
35 Tsoi DT, Porwal M, Webster AC. Interventions for smoking cessation and reduction in individuals with schizophrenia. Cochrane Database Syst Rev. 2010;(6):CD007253. [pmid: 20556777].
36 Tsoi DT, Porwal M, Webster AC. Efficacy and safety of bupropion for smoking cessation and reduction in schizophrenia: systematic review and meta-analysis. Br J Psychiatry. 2010;196(5):346-53. [pmid: 20435957].
37 Tosh G, Clifton A, Bachner M. General physical health advice for people with serious mental illness. Cochrane Database Syst Rev. 2011;2:CD008567. [pmid: 21328308].
38 Tosh G, Clifton A, Mala S, et al. Physical health care monitoring for people with serious mental illness. Cochrane Database Syst Rev. 2010;(3):CD008298. [pmid: 20238365].
39 Bradford DW, Slubicki MN, McDuffie JR, et al. Effects of care models to improve general medical outcomes for individuals with serious mental illness. VA-ESP Project #09-010. [In press.].
40 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed June 12, 2012.
41 Moher D, Liberati A, Tetzlaff J, et al. Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
42 Evidence-based Practice Center Systematic Review Protocol. Project Title: Strategies To Improve Cardiovascular Risk Factors in People With Serious Mental Illness: A Comparative Effectiveness Review. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=933&pageaction=displayproduct. Accessed June 22, 2012.
43 Agius M, Davis A, Gilhooley M, et al. What do large scale studies of medication in schizophrenia add to our management strategies?. Psychiatr Danub. 2010;22(2):323-8. [pmid: 20562774].
44 Allison DB, Mentore JL, Heo M, et al. Antipsychotic-induced weight gain: a comprehensive research synthesis. Am J Psychiatry. 1999;156(11):1686-96. [pmid: 10553730].
45 Alvarez-Jimenez M, Hetrick SE, Gonzalez-Blanch C, et al. Non-pharmacological management of antipsychotic-induced weight gain: systematic review and meta-analysis of randomised controlled trials. Br J Psychiatry. 2008;193(2):101-7. [pmid: 18669990].
46 Banham L, Gilbody S. Smoking cessation in severe mental illness: what works?. Addiction. 2010;105(7):1176-89. [pmid: 20491721].
47 Barkhof E, Meijer CJ, de Sonneville LM, et al. Interventions to improve adherence to antipsychotic medication in patients with schizophrenia-A review of the past decade. Eur Psychiatry. 2011. [pmid: 21561742].
48 Beynon S, Soares-Weiser K, Woolacott N, et al. Pharmacological interventions for the prevention of relapse in bipolar disorder: a systematic review of controlled trials. J Psychopharmacol. 2009;23(5):574-91. [pmid: 18635701].
49 Bradshaw T, Lovell K, Harris N. Healthy living interventions and schizophrenia: a systematic review. J Adv Nurs. 2005;49(6):634-54. [pmid: 15737224].
50 Bushe CJ, Bradley AJ, Doshi S, et al. Changes in weight and metabolic parameters during treatment with antipsychotics and metformin: do the data inform as to potential guideline development? A systematic review of clinical studies. Int J Clin Pract. 2009;63(12):1743-61. [pmid: 19840151].
51 Bushe CJ, Leonard BE. Blood glucose and schizophrenia: a systematic review of prospective randomized clinical trials. J Clin Psychiatry. 2007;68(11):1682-90. [pmid: 18052561].
52 Cabassa LJ, Ezell JM, Lewis-Fernandez R. Lifestyle interventions for adults with serious mental illness: a systematic literature review. Psychiatr Serv. 2010;61(8):774-82. [pmid: 20675835].
53 Citrome L, Holt RI, Walker DJ, et al. Weight gain and changes in metabolic variables following olanzapine treatment in schizophrenia and bipolar disorder. Clin Drug Investig. 2011;31(7):455-82. [pmid: 21495734].
54 Citrome L. A review of aripiprazole in the treatment of patients with schizophrenia or bipolar I disorder. Neuropsychiatr Dis Treat. 2006;2(4):427-43. [pmid: 19412492].
55 Ellinger LK, Ipema HJ, Stachnik JM. Efficacy of metformin and topiramate in prevention and treatment of second-generation antipsychotic-induced weight gain. Ann Pharmacother. 2010;44(4):668-79. [pmid: 20233913].
56 Faulkner G, Cohn T, Remington G. Interventions to reduce weight gain in schizophrenia. Cochrane Database Syst Rev. 2007;(1):CD005148. [pmid: 17253540].
57 Karagianis J, Hoffmann VP, Arranz B, et al. Orally disintegrating olanzapine and potential differences in treatment-emergent weight gain. Hum Psychopharmacol. 2008;23(4):275-81. [pmid: 18338426].
58 Komossa K, Rummel-Kluge C, Schmid F, et al. Quetiapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2010;(1):CD006625. [pmid: 20091600].
59 Komossa K, Rummel-Kluge C, Hunger H, et al. Sertindole versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2009;(2):CD006752. [pmid: 19370652].
60 Kreyenbuhl J, Buchanan RW, Dickerson FB, et al. The Schizophrenia Patient Outcomes Research Team (PORT): updated treatment recommendations 2009. Schizophr Bull. 2010;36(1):94-103. [pmid: 19955388].
61 Leucht S, Kissling W, Davis JM. Second-generation antipsychotics for schizophrenia: can we resolve the conflict?. Psychol Med. 2009;39(10):1591-602. [pmid: 19335931].
62 Lipkovich I, Jacobson JG, Caldwell C, et al. Early predictors of weight gain risk during treatment with olanzapine: analysis of pooled data from 58 clinical trials. Psychopharmacol Bull. 2009;42(4):23-39. [pmid: 20581791].
63 Mukundan A, Faulkner G, Cohn T, et al. Antipsychotic switching for people with schizophrenia who have neuroleptic-induced weight or metabolic problems. Cochrane Database Syst Rev. 2010;(12):CD006629. [pmid: 21154372].
64 Praharaj SK, Jana AK, Goyal N, et al. Metformin for olanzapine-induced weight gain: a systematic review and meta-analysis. Br J Clin Pharmacol. 2011;71(3):377-82. [pmid: 21284696].
65 Rege S. Antipsychotic induced weight gain in schizophrenia:mechanisms and management. Aust N Z J Psychiatry. 2008;42(5):369-81. [pmid: 18473255].
66 Rummel-Kluge C, Komossa K, Schwarz S, et al. Head-to-head comparisons of metabolic side effects of second generation antipsychotics in the treatment of schizophrenia: a systematic review and meta-analysis. Schizophr Res. 2010;123(2–3):225-33. [pmid: 20692814].
67 Lee YJ, Jeong JH. A systematic review of metformin to limit weight-gain with atypical antipsychotics. J Clin Pharm Ther. 2011;36(5):537-545. [pmid: 21418264].
68 Verhaeghe N, De Maeseneer J, Maes L, et al. Effectiveness and cost-effectiveness of lifestyle interventions on physical activity and eating habits in persons with severe mental disorders: A systematic review. Int J Behav Nutr Phys Act. 2011;8.
69 Bjorkhem-Bergman L, Asplund AB, Lindh JD. Metformin for weight reduction in nondiabetic patients on antipsychotic drugs: A systematic review and meta-analysis. J Psychopharmacol. 2011;25(3):299-305. [pmid: 20080925].
70 Alvarez-Jimenez M. Tackling the physical consequences of psychosis and its treatment. Early Interv Psychiatry. 2010;4:17.
71 Strassnig M, Ganguli R. Weight loss interventions for patients with schizophrenia. Clin Schizophr Relat Psychoses. 2007;1(1):43-53.
72 Chue P, Stip E, Remington G, et al. Switching atypical antipsychotics: A review. Acta Neuropsychiatrica. 2004;16(6):301-313.
73 Bushe C, Leonard B. Association between atypical antipsychotic agents and type 2 diabetes: Review of prospective clinical data. Br J Psychiatry. 2004;184(SUPPL 47):s87-s93.
74 Compton MT, Daumit GL, Druss BG. Cigarette smoking and overweight/obesity among individuals with serious mental illnesses: a preventive perspective. Harv Rev Psychiatry. 2006;14(4):212-22. [pmid: 16912007].
75 Faulkner G, Soundy AA, Lloyd K. Schizophrenia and weight management: a systematic review of interventions to control weight. Acta Psychiatr Scand. 2003;108(5):324-32. [pmid: 14531752].
76 Loh C, Meyer JM, Leckband SG. A comprehensive review of behavioral interventions for weight management in schizophrenia. Ann Clin Psychiatry. 2006;18(1):23-31. [pmid: 16517450].
77 Gabriele JM, Dubbert PM, Reeves RR. Efficacy of behavioural interventions in managing atypical antipsychotic weight gain. Obes Rev. 2009;10(4):442-55. [pmid: 19389059].
78 Newcomer JW, Haupt DW. The metabolic effects of antipsychotic medications. Can J Psychiatry. 2006;51(8):480-91. [pmid: 16933585].
79 Faulkner G, Cohn T, Remington G. Interventions to reduce weight gain in schizophrenia. Schizophr Bull. 2007;33(3):654-6. [pmid: 17449900].
80 Khan AY, Macaluso M, McHale RJ, et al. The adjunctive use of metformin to treat or prevent atypical antipsychotic-induced weight gain: a review. J Psychiatr Pract. 2010;16(5):289-96. [pmid: 20859106].
81 Zimmermann U, Kraus T, Himmerich H, et al. Epidemiology, implications and mechanisms underlying drug-induced weight gain in psychiatric patients. J Psychiatr Res. 2003;37(3):193-220. [pmid: 12650740].
82 Ganguli R. Behavioral therapy for weight loss in patients with schizophrenia. J Clin Psychiatry. Suppl 4. 2007;68:19-25. [pmid: 17539696].
83 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. 2006;59(10):1040-8. [pmid: 16980143].
84 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Statistics in Medicine. 2002;21(11):1539-58. [pmid: 12111919].
85 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
86 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
87 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
88 Alvarez-Jimenez M, Gonzalez-Blanch C, Vazquez-Barquero JL, et al. Attenuation of antipsychotic-induced weight gain with early behavioral intervention in drug-naive first-episode psychosis patients: A randomized controlled trial. J Clin Psychiatry. 2006;67(8):1253-60. [pmid: 16965204].
89 Assuncao SS, Ruschel SI, de Rosa LC, et al. Weight gain management in patients with schizophrenia during treatment with olanzapine in association with nizatidine. Rev Bras Psiquiatr. 2006;28(4):270-6. [pmid: 17242805].
90 Atmaca M, Kuloglu M, Tezcan E, et al. Nizatidine for the treatment of patients with quetiapine-induced weight gain. Hum Psychopharmacol. 2004;19(1):37-40. [pmid: 14716710].
91 Ball MP, Warren KR, Feldman S, et al. Placebo-controlled trial of atomoxetine for weight reduction in people with schizophrenia treated with clozapine or olanzapine. Clin Schizophr Relat Psychoses. 2011;5(1):17-25. [pmid: 21459735].
92 Borba CP, Fan X, Copeland PM, et al. Placebo-controlled pilot study of ramelteon for adiposity and lipids in patients with schizophrenia. J Clin Psychopharmacol. 2011;31(5):653-8. [pmid: 21869685].
93 Brar JS, Ganguli R, Pandina G, et al. Effects of behavioral therapy on weight loss in overweight and obese patients with schizophrenia or schizoaffective disorder. J Clin Psychiatry. 2005;66(2):205-12. [pmid: 15705006].
94 Brown C, Goetz J, Hamera E. Weight loss intervention for people with serious mental illness: a randomized controlled trial of the RENEW program. Psychiatr Serv. 2011;62(7):800-2. [pmid: 21724796].
95 Deberdt W, Lipkovich I, Heinloth AN, et al. Double-blind, randomized trial comparing efficacy and safety of continuing olanzapine versus switching to quetiapine in overweight or obese patients with schizophrenia or schizoaffective disorder. Ther Clin Risk Manag. 2008;4(4):713-20. [pmid: 19209252].
96 Elmslie JL, Porter RJ, Joyce PR, et al. Carnitine does not improve weight loss outcomes in valproate-treated bipolar patients consuming an energy-restricted, low-fat diet. Bipolar Disord. 2006;8(5 Pt 1):503-7. [pmid: 17042889].
97 Evans S, Newton R, Higgins S. Nutritional intervention to prevent weight gain in patients commenced on olanzapine: a randomized controlled trial. Aust N Z J Psychiatry. 2005;39(6):479-86. [pmid: 15943650].
98 Fleischhacker WW, Heikkinen ME, Olie JP, et al. Effects of adjunctive treatment with aripiprazole on body weight and clinical efficacy in schizophrenia patients treated with clozapine: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol. 2010;13(8):1115-25. [pmid: 20459883].
99 Gillhoff K, Gaab J, Emini L, et al. Effects of a multimodal lifestyle intervention on body mass index in patients with bipolar disorder: a randomized controlled trial. Prim Care Companion J Clin Psychiatry. 2010;12(5). [pmid: 21274359].
100 Graham KA, Gu H, Lieberman JA, et al. Double-blind, placebo-controlled investigation of amantadine for weight loss in subjects who gained weight with olanzapine. Am J Psychiatry. 2005;162(9):1744-6. [pmid: 16135638].
101 Hoffmann VP, Case M, Jacobson JG. Assessment of treatment algorithms including amantadine, metformin, and zonisamide for the prevention of weight gain with olanzapine: a randomized controlled open-label study. J Clin Psychiatry. 2012;73(2):216-23. [pmid: 21672497].
102 Karagianis J, Grossman L, Landry J, et al. A randomized controlled trial of the effect of sublingual orally disintegrating olanzapine versus oral olanzapine on body mass index: the PLATYPUS Study. Schizophr Res. 2009;113(1):41-8. [pmid: 19535229].
103 Kwon JS, Choi JS, Bahk WM, et al. Weight management program for treatment-emergent weight gain in olanzapine-treated patients with schizophrenia or schizoaffective disorder: A 12-week randomized controlled clinical trial. J Clin Psychiatry. 2006;67(4):547-53. [pmid: 16669719].
104 Littrell KH, Hilligoss NM, Kirshner CD, et al. The effects of an educational intervention on antipsychotic-induced weight gain. J Nurs Scholarsh. 2003;35(3):237-41. [pmid: 14562491].
105 McKibbin CL, Patterson TL, Norman G, et al. A lifestyle intervention for older schizophrenia patients with diabetes mellitus: a randomized controlled trial. Schizophr Res. 2006;86(1–3):36-44. [pmid: 16842977].
106 Newcomer JW, Campos JA, Marcus RN, et al. A multicenter, randomized, double-blind study of the effects of aripiprazole in overweight subjects with schizophrenia or schizoaffective disorder switched from olanzapine. J Clin Psychiatry. 2008;69(7):1046-56. [pmid: 18605811].
107 Wu RR, Zhao JP, Jin H, et al. Lifestyle intervention and metformin for treatment of antipsychotic-induced weight gain: a randomized controlled trial. JAMA. 2008;299(2):185-93. [pmid: 18182600].
108 McDonnell DP, Kryzhanovskaya LA, Zhao F, et al. Comparison of metabolic changes in patients with schizophrenia during randomized treatment with intramuscular olanzapine long-acting injection versus oral olanzapine. Hum Psychopharmacol. 2011;26(6):422-433. [pmid: 21823172].
109 Bustillo JR, Lauriello J, Parker K, et al. Treatment of weight gain with fluoxetine in olanzapine-treated schizophrenic outpatients. Neuropsychopharmacology. 2003;28(3):527-9. [pmid: 12629532].
110 Atmaca M, Kuloglu M, Tezcan E, et al. Nizatidine treatment and its relationship with leptin levels in patients with olanzapine-induced weight gain. Hum Psychopharmacol. 2003;18(6):457-61. [pmid: 12923824].
111 Cavazzoni P, Tanaka Y, Roychowdhury SM, et al. Nizatidine for prevention of weight gain with olanzapine: a double-blind placebo-controlled trial. Eur Neuropsychopharmacol. 2003;13(2):81-5. [pmid: 12650950].
112 Nickel MK, Nickel C, Muehlbacher M, et al. Influence of topiramate on olanzapine-related adiposity in women: a random, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2005;25(3):211-7. [pmid: 15876898].
113 Khazaal Y, Fresard E, Rabia S, et al. Cognitive behavioural therapy for weight gain associated with antipsychotic drugs. Schizophr Res. 2007;91(1–3):169-77. [pmid: 17306507].
114 Mauri M, Simoncini M, Castrogiovanni S, et al. A psychoeducational program for weight loss in patients who have experienced weight gain during antipsychotic treatment with olanzapine. Pharmacopsychiatry. 2008;41(1):17-23. [pmid: 18203047].
115 McElroy SL, Winstanley E, Mori N, et al. A randomized, placebo-controlled study of zonisamide to prevent olanzapine-associated weight gain. J Clin Psychopharmacol. 2012;32(2):165-72. [pmid: 22367654].
116 Carrizo E, Fernandez V, Connell L, et al. Extended release metformin for metabolic control assistance during prolonged clozapine administration: a 14 week, double-blind, parallel group, placebo-controlled study. Schizophr Res. 2009;113(1):19-26. [pmid: 19515536].
117 Wang M, Tong JH, Zhu G, et al. Metformin for treatment of antipsychotic-induced weight gain: a randomized, placebo-controlled study. Schizophr Res. 2012;138(1):54-7. [pmid: 22398127].
118 Wu RR, Jin H, Gao K, et al. Metformin for Treatment of Antipsychotic-Induced Amenorrhea and Weight Gain in Women With First-Episode Schizophrenia: A Double-Blind, Randomized, Placebo-Controlled Study. Am J Psychiatry. 2012;169(8):813-21. [pmid: 22711171].
119 Narula PK, Rehan HS, Unni KE, et al. Topiramate for prevention of olanzapine associated weight gain and metabolic dysfunction in schizophrenia: a double-blind, placebo-controlled trial. Schizophr Res. 2010;118(1–3):218-23. [pmid: 20207521].
120 Stroup TS, McEvoy JP, Ring KD, et al. A randomized trial examining the effectiveness of switching from olanzapine, quetiapine, or risperidone to aripiprazole to reduce metabolic risk: comparison of antipsychotics for metabolic problems (CAMP). Am J Psychiatry. 2011;168(9):947-56. [pmid: 21768610].
121 Forsberg KA, Bjorkman T, Sandman PO, et al. Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nord J Psychiatry. 2008;62(6):486-95. [pmid: 18843564].
122 Skrinar GS, Huxley NA, Hutchinson DS, et al. The role of a fitness intervention on people with serious psychiatric disabilities. Psychiatr Rehabil J. 2005;29(2):122-7. [pmid: 16268007].
123 Douketis JD, Macie C, Thabane L, et al. Systematic review of long-term weight loss studies in obese adults: clinical significance and applicability to clinical practice. Int J Obes (Lond). 2005;29(10):1153-67. [pmid: 15997250].
124 Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527].
125 Leblanc ES, O'Connor E, Whitlock EP, et al. Effectiveness of primary care-relevant treatments for obesity in adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;155(7):434-47. [pmid: 21969342].
126 Zaza S, Briss PA, Harris KW, et al. The guide to community preventive services: what works to promote health?. New York. Oxford University. 2005.
127 Lamanna C, Monami M, Marchionni N, et al. Effect of metformin on cardiovascular events and mortality: a meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2011;13(3):221-8. [pmid: 21205121].
128 Inzucchi SE, Bergenstal RM, Buse JB, et al. Management of hyperglycemia in type 2 diabetes: a patient-centered approach: position statement of the American Diabetes Association (ADA) and the European Association for the Study of Diabetes (EASD). Diabetes Care. 2012;35(6):1364-79. [pmid: 22517736].
129 UK Prospective Diabetes Study (UKPDS) Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. 1998;352(9131):837-53. [pmid: 9742976].
130 Turnbull FM, Abraira C, Anderson RJ, et al. Intensive glucose control and macrovascular outcomes in type 2 diabetes. Diabetologia. 2009;52(11):2288-98. [pmid: 19655124].
131 The Medical Letter. Drugs for Lipids. Treatment Guidelines from The Medical Letter. February. 2008;(66).
132 Thavendiranathan P, Bagai A, Brookhart MA, et al. Primary prevention of cardiovascular diseases with statin therapy: a meta-analysis of randomized controlled trials. Arch Intern Med. 2006;166(21):2307-13. [pmid: 17130382].
133 Evidence-based Practice Center Systematic Review Protocol. Project Title: Comparative Effectiveness of First and Second Generation Antipsychotics in the Adult Population. effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=583. Accessed June 22, 2012.
134 McDonagh M, Peterson K, Carson S, et al. Drug Effectiveness Review Project. Drug Class Review: Atypical Antipsychotic Drugs. Final Update 3. Oregon Evidence-based Practice Center. July. 2010. derp.ohsu.edu/about/final-document-display.cfm. Accessed June 15, 2012. [pmid: 21348048].
135 Cahill K, Stead LF, Lancaster T. Nicotine receptor partial agonists for smoking cessation. Cochrane Database of Systematic Reviews. 2011;(2). PMID: ISI:000288616600005.
136 Evidence-based Practice Center Systematic Review Protocol. Project Title: Comparative Effectiveness of Approaches to Weight Maintenance in Adults. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=824&pageaction=displayproduct. Accessed June 22, 2012.
137 Happell B, Davies C, Scott D. Health behaviour interventions to improve physical health in individuals diagnosed with a mental illness: a systematic review. Int J Ment Health Nurs. 2012;21(3):236-47. [pmid: 22533331].
138 Bartels S, Desilets R. Health Promotion Programs for People with Serious Mental Illness. (Prepared by the Dartmouth Health Promotion Research Team). Washington, D.C. SAMHSA-HRSA Center for Integrated Health Solutions. January. 2012. www.integration.samhsa.gov/Health_Promotion_White_Paper_Bartels_Final_Document.pdf. Accessed September 17, 2012.
139 Wildes JE, Marcus MD, Fagiolini A. Obesity in patients with bipolar disorder: a biopsychosocial-behavioral model. J Clin Psychiatry. 2006;67(6):904-15. [pmid: 16848650].
140 Edelman D, Oddone EZ, Liebowitz RS, et al. A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728-34. [pmid: 16808774].
141 U.S. Preventive Services Task Force. Screening for High Blood Pressure: U.S. Preventive Services Task Force Reaffirmation Recommendation Statement. AHRQ Publication No. 08-05105-EF-2. December. 2007. First published in Ann Intern Med 2007:147-783-786. www.uspreventiveservicestaskforce.org/uspstf07/hbp/hbprs.htm. Accessed June 15, 2012.
142 U.S. Preventive Services Task Force. Counseling to Prevent Tobacco Use and Tobacco-Caused Disease Recommendation Statement. www.uspreventiveservicestaskforce.org/3rduspstf/tobacccoun/tobcounrs.htm. Accessed June 15, 2012.
143 Norris SL, Kansagara D, Bougatsos C, et al. Screening for Type 2 Diabetes: Update of 2003 Systematic Evidence Review for the US Preventive Services Task Force. Evidence Synthesis No. 61. AHRQ Publication No. 08-05116-EF-1. Rockville, Maryland. Agency for Healthcare Research and Quality. June. 2008. www.ncbi.nlm.nih.gov/books/NBK33981/. Accessed June 15, 2012.
144 Helfand M, Carson S. Screening for Lipid Disorders in Adults: Selective Update of 2001 U.S Preventive Services Task Force Review. Evidence Synthesis No. 49. Rockville, MD. Agency for Healthcare Research and Quality. April. 2008. AHRQ Publication no 08-05114-EF-1 www.ncbi.nlm.nih.gov/books/NBK33494/. Accessed June 15, 2012.
145 American Diabetes Association. Consensus development conference on antipsychotic drugs and obesity and diabetes. Diabetes Care. 2004;27(2):596-601. PMID: ISI:000188739900043. [pmid: 14747245].
146 Standards of Medical Care in Diabetes-2012. Diabetes Care. 2012;35(1):S11-S63. PMID: ISI:000298772200002. [pmid: 22187469].
147 Salpeter S, Greyber E, Pasternak G, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006;(1):CD002967. [pmid: 16437448].
148 Kramer CK, Leitao CB, Pinto LC, et al. Efficacy and safety of topiramate on weight loss: a meta-analysis of randomized controlled trials. Obes Rev. 2011;12(5):e338-47. [pmid: 21438989].
149 Gierisch JM, Bastian LA, Calhoun PS, et al. Smoking cessation interventions for patients with depression: a systematic review and meta-analysis. J Gen Intern Med. 2012;27(3):351-60. [pmid: 22038468].
150 Gierisch JM, Bastian LA, Calhoun PS, et al. Comparative Effectiveness of Smoking Cessation Treatments for Patients With Depression: A Systematic Review and Meta-analysis of the Evidence. VA-ESP Project #09-010. 2010.
151 Bryant J, Bonevski B, Paul C, et al. A systematic review and meta-analysis of the effectiveness of behavioural smoking cessation interventions in selected disadvantaged groups. Addiction. 2011;106(9):1568-85. [pmid: 21489007].
152 Mitchell AJ, Delaffon V, Vancampfort D, et al. Guideline concordant monitoring of metabolic risk in people treated with antipsychotic medication: systematic review and meta-analysis of screening practices. Psychol Med. 2012;42(1):125-47. [pmid: 21846426].
153 Haupt DW, Rosenblatt LC, Kim E, et al. Prevalence and predictors of lipid and glucose monitoring in commercially insured patients treated with second-generation antipsychotic agents. Am J Psychiatry. 2009;166(3):345-53. [pmid: 19147694].
154 Morrato EH, Newcomer JW, Kamat S, et al. Metabolic screening after the American Diabetes Association’s consensus statement on antipsychotic drugs and diabetes. Diabetes Care. 2009;32(6):1037-42. [pmid: 19244091].
155 Morrato EH, Druss B, Hartung DM, et al. Metabolic testing rates in 3 state Medicaid programs after FDA warnings and ADA/APA recommendations for second-generation antipsychotic drugs. Arch Gen Psychiatry. 2010;67(1):17-24. [pmid: 20048219].
156 Morrato EH, Druss BG, Hartung DM, et al. Small area variation and geographic and patient-specific determinants of metabolic testing in antipsychotic users. Pharmacoepidemiol Drug Saf. 2011;20(1):66-75. [pmid: 21182154].
157 Williams JW, Jackson GL, Powers BJ, et al. Closing the Quality Gap Series: Revisiting the State of the Science. The Patient-Centered Medical Home. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I). Rockville, MD. Agency for Healthcare Research and Quality. [in press].
158 Hayward RA, Hofer TP, Vijan S. Narrative review: lack of evidence for recommended low-density lipoprotein treatment targets: a solvable problem. Ann Intern Med. 2006;145(7):520-30. [pmid: 17015870].
159 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I). AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed May 22, 2012.
160 Patient-Centered Outcomes Research Institute. Draft National Priorities for Research and Research Agenda Version 1. January. 23. 2012.
161 Myers E, McBroom AJ, Shen L, et al. Value-of-Information Analysis for Patient-Centered Outcomes Research Prioritization, Report prepared by the Duke Evidence-based Practice Center. Patient-Centered Outcomes Research Institute. March. 2012.
162 Jonas D Mansfield AJ Curtis PIdentifying Priorities for Patient-Centered Outcomes Research for Serious Mental IllnessResearch White Paper(Prepared by the RTI-UNC Institute Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 11-EHC066-EF Rockville, MD Agency for Healthcare Research and Quality September 2011 www.effectivehealthcare.ahrq.gov/reports/final.cfm
163 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342(25):1887-92. [pmid: 10861325].
164 Ioannidis JP, Haidich AB, Pappa M, et al. Comparison of evidence of treatment effects in randomized and nonrandomized studies. JAMA. 2001;286(7):821-30. [pmid: 11497536].
165 Sesso HD, Buring JE, Christen WG, et al. Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians’ Health Study II randomized controlled trial. JAMA. 2008;300(18):2123-33. [pmid: 18997197].
166 Lee IM, Cook NR, Gaziano JM, et al. Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women’s Health Study: a randomized controlled trial. JAMA. 2005;294(1):56-65. [pmid: 15998891].
167 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004;291(14):1701-12. [pmid: 15082697].