# Peer Reviewers

- Stephen J. Bartels, M.D., M.S.
  Professor of Psychiatry
  The Dartmouth Institute for Health Police & Clinical Research
  Lebanon, NH
- Amy N. Cohen, Ph.D.
  Professor of Psychology
  University of California, Los Angeles
  Los Angeles, CA
- Gerald Gartlehner, M.D., M.P.H.
  Department Head, Evidence-based Medicine and Clinical Epidemiology
  Danube University
  Krems, Austria
- Julie A. Kreyenbuhl, Pharm.D., Ph.D.
  Associate Professor of Psychiatry
  University of Maryland
  Baltimore, MD
- Paul Pirraglia, M.D.
  Assistant Professor of Medicine
  Brown University
  Providence, RI
- Andrew M. Pomerantz, Ph.D.
  Professor of Psychology
  Southern Illinois University
  Edwardsville, IL
- Martha Sajatovic, M.D.
  Professor of Psychiatry
  University Hospitals of Cleveland
  Cleveland, OH