# Technical Expert Panel

- Christine Collins, M.S.W.
  Deputy Director
  North Carolina Office of Rural Health and Community Care
  Raleigh, NC
- Lisa M. Dixon, M.D., M.P.H
  Director, Center for Practice Innovations
  New York State Psychiatric Institute
  New York, NY
- Benjamin G. Druss, M.D., M.P.H.
  Professor, Rollins School of Public Health
  Emory University
  Atlanta, GA
- Laura J. Fochtmann, M.D.
  Professor of Psychiatry
  Stony Brook University
  Stony Brook, NY
- Martha Gerrity, M.D., M.P.H. Ph.D.
  Clinical Evidence Specialty
  Oregon Health & Science University
  Portland, OR
- Louise M. Howard, Ph.D.
  Professor in Women’s Mental Health
  King’s College London
  London, UK
- Amy M. Kilbourne, Ph.D., M.P.H.
  Associate Professor of Psychiatry
  University of Michigan
  Ann Arbor, MI
- Anthony F. Lehman, M.D., M.S.P.H.
  Professor of Psychiatry
  University of Maryland
  Baltimore, MD
- T. Scott Stroup, M.D., M.P.H.
  Professor of Psychiatry
  Columbia University
  New York, NY
- Alexander S. Young, M.D., M.S.H.S
  Professor of Psychiatry
  University of California, Los Angeles
  Los Angeles, CA