# Key Informants

- Christine Collins, M.S.W.
  Deputy Director
  North Carolina Office of Rural Health and Community Care
  Raleigh, NC
- Benjamin G. Druss, M.D., M.P.H.
  Professor, Rollins School of Public Health
  Emory University
  Atlanta, GA
- Laura J. Fochtmann, M.D.
  Professor of Psychiatry
  Stony Brook University
  Stony Brook, NY
- Parinda Khatri, Ph.D.
  Clinical Psychologist
  Cherokee Health Systems
  Knoxville, TN
- Amy M. Kilbourne, Ph.D., M.P.H.
  Associate Professor of Psychiatry
  University of Michigan
  Ann Arbor, MI
- Michael Weaver, M.S.Ed.
  Executive Director
  Mental Health America of the Tar River Region
  Rocky Mount, NC
- Judy Zerzan, M.D., M.P.H.
  Colorado Medicaid Medical Director
  Colorado Department of Health Care Policy and Financing
  Denver, CO