# Discussion

## Key Findings and Strength of Evidence

We identified 35 trials that tested a wide array of pharmacological and behavioral interventions to address one or more CVD risk factors in adults with SMI who have elevated risk for CVD. Given that CVD is the most prevalent cause of death in this population, this is a surprisingly small number of studies. Further, we identified no peer and family support interventions to address elevated CVD risk, nor did we find any interventions designed specifically to address lipids. No interventions targeted individuals with psychotic depression specifically. Outcomes reported were primarily metabolic outcomes such as glucose control or weight; effects on physical function and overall CVD risk (e.g., Framingham Risk Score) were reported infrequently, and all-cause mortality was not reported.

Table 11 presents a brief overview of key findings by intervention as well as the strength of evidence (SOE) by KQ for major outcomes. The drug classes in our review sometimes included drugs with diverse mechanisms of action. When results varied by drug, we assigned separate SOE. Publication bias was difficult to assess because only a few comparisons had sufficient studies for statistical analysis. For adverse effects, we considered discontinuation due to adverse effects and worsening of psychiatric status as the key outcomes when rating SOE. When the majority of studies reported only one of these outcomes, we considered the evidence for adverse effects incomplete and rated the limited evidence as indirect. In brief, evidence was insufficient for most intervention strategies, and there were too few studies to conduct quantitative synthesis for all outcomes of interest, except for weight.

Table 11 Overview of treatment effects and SOE by intervention and major outcomes^a^

Intervention | KQ 1: Weight | KQ 2: Diabetes (HbA1c) | KQ 3: Lipids^b^ | Overall CVD Risk and Other Outcomes
Behavioral | Small benefit (−3.1 kg) Moderate SOE | Insufficient SOE | No important effect from weight control interventions Insufficient SOE | 1 study assessed health-related quality of life and found no differences Only 2 studies reported discontinuation due to adverse effects Insufficient SOE
Peer or family support | No studies Insufficient SOE | No studies Insufficient SOE | No studies Insufficient SOE | No studies Insufficient SOE
Metformin | Small benefit (−4.1 kg) Low SOE | Insufficient SOE | No studies Insufficient SOE | Insufficient SOE for CVD risk
Topiramate, zonisamide | Small to moderate benefit (−5.1 kg) Low SOE | Insufficient SOE | Possible benefit with topiramate Insufficient SOE | Insufficient SOE for CVD risk
Antihistamine | No benefit Low SOE | Insufficient SOE | Single study did not suggest benefit Insufficient SOE | Insufficient SOE for CVD risk
Other medications | Insufficient SOE | Insufficient SOE | No study suggested possible benefit Insufficient SOE | Insufficient SOE for CVD risk
Antipsychotic switching or adjunctive use | Low SOE for small benefit (−2 to −3 kg) with switching to aripiprazole or adjunctive aripiprazole Insufficient SOE from single studies that found no effect with switching to quetiapine or parenteral olanzapine | Insufficient SOE | Possible benefit with adjunctive or switching to aripiprazole Low SOE | Insufficient SOE for CVD risk Low SOE for possible higher rate of mental health worsening with switching
Multicomponent lifestyle | Insufficient SOE | Insufficient SOE | Insufficient SOE | 2 studies suggested benefit for health-related quality of life 1 study reported no benefit on CVD risk score Insufficient SOE

CVD = cardiovascular disease; HbA1c = hemoglobin A1c; KQ = Key Question; SOE = strength of evidence

a Shaded cells highlight SOE ratings that are above insufficient.

b No studies of lipid-focused interventions.

### Key Question 1 Weight Control

The largest number of studies (32 of 35) addressed weight control. We found moderate SOE that behavioral interventions are associated with small decreases in weight (about 3 kg) compared with controls (Table 12). We found low SOE that switching to or adding adjunctive aripiprazole, adding the anticonvulsant medications topiramate and zonisamide, or adding metformin yield small to moderate weight loss. Nizatidine, an antihistamine, did not show any consistent effect on weight (low SOE). The SOE was insufficient for all other interventions. To put these weight loss changes in context, clinically important change in weight of 5 to 10 percent of body mass significantly reduces diabetes risk factors and cardiovascular disease risk in patients who have higher risk.123,124 The strategies summarized in this report that found statically significant weight loss (i.e., behavioral interventions, adjunctive aripiprazole, anticonvulsants topiramate and zonisamide) yielded mean differences of 2 to 6 percent reductions in body weight over mean baseline weights.

Table 12 Summary SOE for KQ 1: Interventions for weight control

Outcome | Number of Studies (Subjects) | SOE Domains: ROB Consistency | SOE Domains: Directness Precision | SOE; Effect Estimate
Psychotropic Medications: Atomoxetine, Fluoxetine, Ramelteon, Adjunctive Aripiprazole
Weight | 4 (268) | Moderate NA^a^ | Direct Imprecise | Insufficient; single studies showing no effect for atomoxetine, fluoxetine, ramelteon; small effects for amantadine and adjunctive aripiprazole
Physical function/HRQOL | 1 (207) | Low NA | Direct Imprecise | Insufficient; 1 study showing no positive effect
Adverse effects | 1 (207) | Low NA | Direct Imprecise | Insufficient; 1 study reporting discontinuation due to adverse effects
Anticonvulsant Medications: Topiramate, Zonisamide
Weight | 3 (158) | Moderate Consistent | Direct Imprecise | Low; mean difference −5.1 kg (95% CI, −9.8 to −0.7)
Physical function/HRQOL | 1 (67) | Moderate NA | Direct Imprecise | Insufficient; positive effects on multiple scales for topiramate in a single study
Adverse effects | 1 (42) | Low NA | Indirect Imprecise | Insufficient; only reported discontinuation due to adverse effects
Metformin
Weight | 5 (531) | Moderate Inconsistent | Direct Imprecise | Low; mean difference −4.1 kg (95% CI, −6.6 to −1.7)
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 4 (475) | Low Consistent | Indirect Imprecise | Insufficient; inconsistent reporting of psychiatric adverse effects
Antihistamine: Nizatidine
Weight | 4 (286) | Moderate Inconsistent | Direct Precise | Low; mean difference −0.5 (95% CI, −1.3 to 0.3)
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 1 (54) | Low NA | Indirect Imprecise | Insufficient; inconsistent reporting of major adverse effect of interest
Antipsychotic Switching
Weight-aripiprazole | 1 (133) | Moderate NA | Direct Imprecise | Low; mean difference −3.1 kg
Weight-olanzapine, quetiapine | 3 (1203) | Moderate Consistent | Direct Imprecise | Insufficient for quetiapine, orally disintegrating and injectable olanzapine; single studies
Physical function/HRQOL-aripiprizole | 1 (133) | Moderate Inconsistent | Direct Imprecise | Insufficient
Physical function/HrQOL-olanzapine, quetipaine | 1 (149) | Low NA | Direct Imprecise | Insufficient; 1 study finding no difference with orally disintegrating olanzapine; no data for other drugs
Adverse effects-aripiprazole | 1 (133) | Moderate NA | Indirect Imprecise | Insufficient
Adverse effects-olanzapine, quetiapine | 3 (1203) | Moderate Consistent | Direct Imprecise | Insufficient; single studies for each drug
Behavioral Interventions
Weight | 11 (792) | Moderate Consistent | Direct Precise | Moderate Mean difference −3.1kg (−4.2 to −2.1)
Physical function/HRQOL | 1 (48) | High NA | Direct Imprecise | Insufficient
Adverse effects | 2 (199) | Moderate Consistent | Direct Imprecise | Insufficient
Peer or Family Support Interventions
All outcomes | No studies | NA | NA | Insufficient

CI = confidence interval; CVD = cardiovascular disease; HRQOL = health-related quality of life; kg = kilogram; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; ROB = risk of bias; SOE = strength of evidence

a Consistency rating does not apply where different drugs in the same general drug class are being summarized.

The findings we report here for behavioral interventions and metformin are consistent with a recent review that examined treatments for obesity relevant to primary care.125 Behaviorally based interventions resulted in a mean 3-kg greater weight loss than control over 12 to 18 months, with more treatment sessions associated with greater weight loss. In our review, no studies evaluated orlistat, an FDA-approved medication for the treatment of obesity that is also available without prescription at a lower dose. Orlistat is associated with approximately a 3-kilogram weight reduction over 12 to 18 months, but it must be used in conjunction with a low-fat diet.

### Key Question 2 Diabetes Control

We identified only seven trials that assessed the impact of behavioral and pharmacological interventions to address glucose control as measured by HbA1c in patients with SMI and elevated risk for CVD. Of these, only one study assessed patients with diabetes and glucose control directly;105 the other six studies assessed HbA1c as a secondary outcome. Overall, we found insufficient evidence for all interventions (Table 13). Among populations without SMI who have diabetes, disease management programs126 and metformin have been effective, as have lifestyle interventions for improving glucose control in people with diabetes or at risk of developing diabetes. Further, metformin is associated with decreased cardiovascular events compared with no treatment.127 To place these findings in context, prospective trials have documented reduced rates of microvascular complications in patients with type 2 diabetes who are treated to lower glycemic targets.128 In patients with newly diagnosed diabetes, these benefits were achieved with an average reduction in A1c of 0.9 percent.129 A meta-analysis of trials in patients with established diabetes suggested that every 1 percent reduction in A1c may be associated with a 15-percent relative risk reduction in nonfatal myocardial infarction.130 On average, oral hypoglycemic medications (e.g., metformin) are associated with approximately a one-percent decrease in HbA1c. These interventions may also translate to populations with SMI and warrant exploration.

Table 13 Summary SOE for KQ 2: Interventions for diabetes control (glucose)

Outcome | Number of Studies (Subjects) | SOE Domains: ROB Consistency | SOE Domains: Directness Precision | SOE; Effect Estimate
Psychotropic Medication: Ramelteon
A1c | 1 (20) | Moderate NA | Direct Imprecise | Insufficient; 1 small study showing small reduction in A1c
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 1 (20) | Moderate NA | Indirect Imprecise | Insufficient
Anticonvulsant Medications
All outcomes | No studies | NA | NA | Insufficient
Metformin
A1c | 2 (260) | High Inconsistent | Direct Imprecise | Insufficient; 2 studies, 1 using metformin with other medications in a treatment algorithm showing small reductions in A1c
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 2 (260) | High Consistent | Direct Imprecise | Insufficient
Antipsychotic Switching: Olanzapine to Quetiapine, Aripiprazole, or Orally Disintegrating Olanzapine
A1c | 3 (497) | Low Consistent | Direct Precise | Moderate; range of mean difference 0 to −0.1
Physical function/HRQOL | 1 (215) | Low NA | Direct Imprecise | Insufficient; 1 study showing improvements in physical functioning
Adverse effects | 3 (497) | Low Consistent | Direct Imprecise | Low; switching strategies had higher discontinuations, often due to psychiatric adverse effects
Behavioral Interventions
A1c | 2 (117) | Moderate Inconsistent | Direct Imprecise | Insufficient; range of mean difference −0.6 to 0
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 1 (64) | Moderate NA | Direct Imprecise | Insufficient
Peer or Family Support Interventions
All outcomes | No studies | NA | NA | Insufficient

CIb = confidence interval; CVD = cardiovascular disease; HRQOL = health-related quality of life; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; ROB = risk of bias; SOE = strength of evidence

### Key Question 3 Lipid Control

No studies evaluated an intervention specifically designed to target lipid levels in patients with SMI who have dyslipidemia or are at risk for dyslipidemia. Behavioral interventions focusing on weight loss or diabetes management have no substantial effects on lipids. Small benefits were seen when aripiprazole was used as an adjunct or as an antipsychotic-switching strategy (low SOE), and single studies suggested possible benefit with ramelteon or topiramate. However, SOE was insufficient for all other interventions (Table 14). In contrast, low to moderate doses of statins are associated with a 20 to 40 percent reduction in LDL cholesterol.131,132

Table 14 Summary SOE for KQ 3: Interventions for lipid control

Outcome | Number of Studies (Subjects) | SOE Domains: ROB Consistency | SOE Domains: Directness Precision | SOE; Effect Estimate
Psychotropic Medications: Atomoxetine, Ramelteon, Adjunctive Aripiprazole
Total cholesterol | 2 (232) | Moderate NA^a^ | Direct Imprecise | Insufficient; 1 study showing no effect on LDL cholesterol for atomoxetine, 1 study showing benefit on total cholesterol for ramelteon, 1 study showing benefit for adjunctive aripiprazole on total and LDL cholesterol
LDL cholesterol | 3 (269) | Moderate NA^a^ | Direct Imprecise
Physical function/HRQOL | 1 (207) | Low NA | NA | Insufficient; 1 study showing no benefit
Adverse effects | 2 (243) | Moderate NA^a^ | Direct Imprecise | Insufficient; 1 study showed better mental health but more serious adverse events with adjunctive aripiprazole
Anticonvulsant Medications: Topiramate, Zonisamide
Total cholesterol | 1 (42) | Low NA | Direct Imprecise | Insufficient; 1 study showing moderate benefit (mean difference, 10.2 mg%) with topiramate on LDL; 1 study showing no effect with zonisamide
LDL cholesterol | 2 (114) | Moderate Inconsistent | Direct Imprecise | Insufficient; 1 study showing moderate benefit (mean difference, 10.2 mg%) with topiramate on LDL; 1 study showing no effect with zonisamide
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | No studies | NA | NA | Insufficient
Other Medications: Amantadine, Nizatidine
Total cholesterol | 2 (75) | Low to High NA^a^ | Direct Imprecise | Insufficient; single studies for amantadine and nizatidine showing no effect
LDL cholesterol | 2 (75) | Low to High NA^a^ | Direct Imprecise | Insufficient; single studies for amantadine and nizatidine showing no effect
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 1 (54) | Low NA | Indirect Imprecise | Insufficient
Antipsychotic Switching
Total cholesterol | 4 (1376) | Moderate Inconsistent | Direct Imprecise | Low for aripiprazole, insufficient for other antipsychotics; results varied by switching strategy. Only a switch to aripiprazole improved lipid values; switching to injectable olanzapine increased lipid values.
LDL cholesterol | 4 (1376) | Moderate Inconsistent | Direct Imprecise
Physical function/HRQOL | 1 (149) | Low NA | Direct Imprecise | Insufficient
Adverse effects | 3 (1243) | Moderate Consistent | Indirect Imprecise | Low that moderate to large differences are not present for serious adverse events or discontinuations due to adverse events Insufficient for risk of psychiatric worsening
Behavioral Interventions
Total cholesterol | 2 (99) | Moderate Consistent | Direct Imprecise | Insufficient
LDL cholesterol | 3 (156) | Moderate Consistent | Indirect Imprecise | Insufficient; mean difference, 1.9 mg/dl (−6.1 to 9.9)
Physical function/HRQOL | No studies | NA | NA | Insufficient
Adverse effects | 1 (49) | High NA | Indirect Imprecise | Insufficient
Peer or family support interventions
All outcomes | No studies | NA | NA | Insufficient

CI = confidence interval; CVD = cardiovascular disease; HRQOL = health-related quality of life; LDL = low-density lipoprotein; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial; ROB = risk of bias; SOE = strength of evidence

a Consistency rating does not apply where different drugs in the same general drug class are being summarized.

### Key Question 4 Multicondition Lifestyle Interventions

Few studies evaluated multicondition interventions, and these studies evaluated only a limited number of components (Table 15). Two studies evaluated multicomponent lifestyle interventions alone, and one evaluated switching from one of three second-generation antipsychotic medications to aripiprazole in combination with a structured diet and exercise program. None of these studies evaluated lifestyle interventions in combination with medications that directly address weight (e.g., orlistat), glucose (e.g., metformin), or lipids (e.g., statins). Studies reported each outcome separately without reporting an overall CVD risk such as the Framingham Risk Score. As described above, when adding or switching to aripiprazole, there is low SOE for a small benefit on weight, but the evidence is insufficient for overall CVD risk. The two multicomponent behavioral interventions did not have a positive effect on the individual CVD risk factors, although one of the two studies showed a large positive effect on health-related quality of life.

Table 15 Summary SOE for KQ 4: Multicondition lifestyle interventions

Outcome | Number of Studies (Subjects) | SOE Domains: ROB Consistency | SOE Domains: Directness Precision | SOE; Effect Estimate
Multicondition Interventions
CVD risk | 1 (41) | Moderate NA | Direct Imprecise | Insufficient; 1 study showing no positive effects
Physical function/HRQOL | 2 (245) | Low Inconsistent | Direct Imprecise | Insufficient; 2 studies showing no effect of multicomponent behavioral intervention but positive effects with switching to aripiprazole plus behavioral intervention
Adverse effects | 1 (215) | Low NA | Direct Imprecise | Insufficient; greater discontinuation due to adverse effects and greater serious adverse effects in aripiprazole plus behavioral intervention

CVD = cardiovascular disease; HRQOL = health-related quality of life; NA = not applicable; ROB = risk of bias; SOE = strength of evidence

## Findings in Relation to What Is Already Known

A number of high-quality systematic reviews have evaluated the comparative benefits and harms of antipsychotic medications.133,134 However, these reviews focused on mental health outcomes and adverse effects, including adverse metabolic consequences, but not strategies for managing the adverse metabolic effects. Other reviews have identified effective treatments for CVD risk factors such as obesity, tobacco use, and hyperlipidemia in general populations or in adults at increased risk for CVD.125,135,136 We specifically excluded from our review evaluations of general health advice, smoking cessation interventions, and models that provide integrated mental health–general medical care because these topics had been the subject of recent high-quality reviews in patients with SMI.35–39 Tsoi et al.35,36 found that bupropion more than doubled the rate of smoking abstinence in smokers with schizophrenia without jeopardizing their mental state. There were few studies of other smoking cessation treatments (including nicotine replacement therapy) and no evidence of benefit for these other treatments. In contrast, Tosh et al.37 found a small number of RCTs evaluating general physical health advice for patients with SMI, and no clear benefit on health outcomes. Bradford et al.39 found moderately strong evidence that integrated mental health–general medical care improves preventive services, including cardiovascular screening, but limited and inconsistent effects on physical functioning and CVD risk factors.

Our results complement prior reports by examining a broad array of interventions for patients at increased risk for worsening health outcomes due to CVD risk factors such as obesity, hyperlipidemia, diabetes mellitus, or chronic administration of antipsychotic medication that negatively impacts metabolic parameters. Earlier narrative and systematic reviews have focused primarily on behavioral interventions for weight control in patients with schizophrenia or who were on antipsychotic medications.52,68,76,77,137–139 These reviews used differing eligibility criteria, with some including observational designs. Therefore, the number of studies included varied widely, ranging from 14 to 30. Despite the differences in methods, the conclusions of these reviews are largely consistent with our findings that behavioral interventions are associated with small improvements in weight. Some recent qualitative syntheses identified (1) interventions adapted to individuals with SMI, (2) durations of at least 3 months, and (3) incorporation of both education and activity-based approaches as associated with greater effects.52,138 These findings are tempered by the small number of studies and indirect comparisons. Our review builds on these findings by identifying clear omissions in treatments that are known to be effective in non-SMI populations, including guideline-concordant care, and promising treatment strategies such as aripiprazole, metformin, and topiramate, which deserve further investigation.

## Applicability

The positive effects of interventions do not always translate well to usual practice—where clinician training, clinical setting, system resources, and patient characteristics may vary importantly from trial conditions. In our review, only 15 of 35 trials were conducted in the United States, and most studies (n=21) were classified as efficacy studies and were relatively short in duration. Studies typically enrolled midlife adults; none specifically enrolled older adults. Women, as well as racial minorities, were well represented overall but underrepresented for some specific comparisons. Most studies were conducted in mental health outpatient settings, typical of the principal locus of medical care for patients with SMI; none were conducted in patient-centered medical homes or in settings that integrated mental health with general medical services. None were classified as effectiveness studies, but for many interventions, initial studies are justifiably designed to answer the question, Can it work under ideal conditions?—before moving to a test of effectiveness. Probably the most important constraint on applicability is the inconsistent reporting of the CVD-related outcomes of interest and the nearly total lack of reporting (only reported in one study) for overall CVD risk indices (e.g., Framingham Risk Score). Understanding intervention effects on overall CVD risk would, arguably, be reported as effects on CVD risk indices,140 cardiovascular events (e.g., stroke, myocardial infarction) or CVD-related mortality—all of which were missing from the included trials except for one that reported CVD risk indices.121

## Implications for Clinical and Policy Decisionmaking

The U.S. Preventive Services Task Force makes recommendations for CVD screening in adults, including blood pressure141 and tobacco use,142 screening for diabetes in patients with elevated blood pressure,143 and lipid screening in midlife adults or young adults at increased risk for CVD.144 Increasing guideline-concordant care for individuals with SMI—given the current lack of evidence for SMI-specific interventions—could be considered a starting point for minimizing CVD risk in patients with SMI. These guidelines for the general population should then be modified to consider the special risks for patients with SMI. In 2004, the American Diabetes Association and American Psychiatric Association issued consensus guidelines145 for screening and monitoring of patients taking antipsychotic drugs. These guidelines recommended baseline monitoring to include a family history, BMI, waist circumference, blood pressure, fasting plasma glucose, and fasting lipid profile as well as followup monitoring of weight, fasting glucose, lipid levels, and blood pressure. Diabetes screening guidelines have since been updated to include the HbA1c as an appropriate measure to screen for diabetes mellitus.146 Although screening and monitoring are addressed well by current guidelines, the American Psychiatric Association guidelines for schizophrenia provide only general advice for managing adverse effects of antipsychotic medication, such as helping the patient tolerate the adverse effect, treating the comorbid condition, or considering a change in the psychotropic medication to an alternative with less potential to induce side effects.

Our review, together with other reviews on interventions to decrease CVD risk in patients with or without SMI, suggests a few actionable strategies and others requiring further study. For weight control, moderate evidence supports behavioral interventions, and more limited evidence supports metformin, topiramate, or aripiprazole as an adjunctive or antipsychotic-switching strategy. All of these interventions yield small to moderate effects, and the benefits must be weighed against the potential harms. Because only limited data on harms were reported in the trials examined, data from non-SMI populations should be incorporated into decisionmaking. For example, metformin requires careful patient selection and monitoring of renal function due to the small risk of lactic acidosis.147 Topiramate has an increased risk of paraesthesia, taste impairment, and psychomotor disturbances.148 Data are much more limited for effects on average glucose control or lipid levels in patients at increased risk. The antihistamine nizatidine was not effective for any CVD risk factor and is unlikely to be a useful treatment. Other reviews identify bupropion as the best supported treatment for smoking cessation;35,36 nicotine replacement therapy is effective in non-SMI populations but has not been adequately studied in patients with schizophrenia, bipolar disorder or psychotic depression. Other reviews identified tailored mood management in patients with depressive symptoms149,150 and behavioral support interventions in individuals with mental illness as potentially effective.151 Although the evidence is limited, the meta-finding is that, of the interventions tested in SMI populations to date, effects on intermediate outcomes (e.g., weight) are similar to the effects found in the general population.

Physicians take an oath of primum non nocere: First do no harm. The American Psychiatric Association’s 2004 guidance follows this principle, recommending a response to adverse medication effects by considering a change in the psychotropic medication to an alternative with less potential to induce side effects. When treating emergent metabolic abnormalities that temporally follow medication treatment, this approach is rational, but existing data show only small improvements in the cardiovascular outcomes of interest. Other high-quality systematic reviews have addressed the comparative efficacy of antipsychotics and identified few differences in short-term efficacy between second-generation antipsychotics; clozapine reduced suicides and suicidal behavior, and clozapine and olanzapine had lower rates of discontinuation. Olanzapine resulted in greater weight gain and increased risk of new onset diabetes.134 In patients who have responded well to psychotropic medication, a change in treatment carries the risk of symptom-worsening, an outcome not consistently reported in the studies reviewed. Further, antipsychotic-switching strategies have not been tested directly against treatments that target the metabolic abnormality directly (e.g., statin for hyperlipidemia) or multimodal strategies that include medication switching and lifestyle interventions. For some medications, interactions with psychotropic medications (e.g., thiazide diuretics and lithium) may limit effectiveness. Despite this caution, and in the absence of direct evidence in patients with SMI, treatments established as effective in non-SMI populations are a logical choice to treat risk factors for CVD in SMI populations until better evidence is available.

Studies of guideline adherence show significant gaps between current practice and recommendations for CVD risk screening and followup.152 Studies show screening rates ranging from about 10 to 26 percent for lipids and 22 to 52 percent for glucose.153–156 Data on monitoring of these risk factors in patients treated with second-generation antipsychotics are more limited but also show gaps between guidelines and practice. Assessment and monitoring is only a first step. When abnormalities are detected, they must be addressed, either by the mental health professional or by a general medicine clinician. Integrated mental health–general medical care has shown promise as the optimal way to deliver this care, and the current move to medical homes has the potential to make this type of care more readily available. Unfortunately, few medical home models to date have explicitly included mental health care.157 Until integrated care is better established and more readily available, there are a number of implementation strategies to consider when a change to a metabolically more neutral antipsychotic is not sufficient to address elevated CVD risk factors. When patients have access to both mental health specialty care and general medical care, it is important that these clinicians coordinate care across issues that may impact both physical and mental health. For example, general medical providers may be aware of the adverse metabolic effects of some psychotropics but are appropriately hesitant to adjust these medications. Coordinating care with the mental health professional about roles and specific strategies for addressing CVD risk factors has the potential to improve care and clinical outcomes.

When general medical care is unavailable, one pragmatic strategy to consider is an expanded role for psychiatrists. Weight and blood pressure screening and monitoring are low-cost measures, requiring minimal time and office equipment. For patients without access to general medical care, psychiatrists could incorporate these activities into their usual clinical practice. Treating hyperlipidemia with statins is only slightly more difficult. The FDA and guidelines groups have recently revised recommendations; periodic transaminase monitoring is no longer recommended. In addition, some authors have made a strong case for fixed-dose statins that would further decrease the need for ongoing monitoring of lipid levels.158 Thus, psychiatrists would need only to follow NCEP-III guidelines for when to initiate treatment (and readily available Web and smartphone-based applications facilitate quick access to these guidelines) and consider potential drug-drug interactions, which are relatively few.

## Limitations of the Comparative Effectiveness Review Process

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, careful quality assessment, and rigorous synthesis methods. Our report, and the literature, also has limitations. There were substantial limitations in the literature. First, the number of studies is small, many had design limitations affecting the validity of findings, and the range of interventions evaluated was limited. Further, descriptions of the interventions were often inadequate to permit replication. Second, there were few studies in certain populations of high interest (e.g., depression with psychosis, bipolar disorder). Third, the range of outcomes was limited, including infrequent reporting of overall CVD risk, physical functioning, and outcomes related to worsening of psychiatric status. Limitations in the number and reporting of studies precluded any analyses of variability in treatment effects by patient characteristics.

Our review methods also had limitations. Our study was limited to English-language publications. However, the likelihood of identifying relevant data unavailable from English-language sources is low. Although the definition of SMI includes major depression with persistent impairment in multiple areas of functioning, this concept is not specified with search terms, and thus we used the operational definition of psychotic depression. Also, only one study was specifically designed to address diabetes, and no studies directly targeted dyslipidemia. Thus, results for those CVD risks were culled from secondary outcome assessments of primarily weight management interventions. If a trial provided information on weight, glucose, and lipid control, these results were organized for the outcomes across KQ 1 through KQ 3 to reduce redundancy of reporting. However, we reported on adverse events and health-related quality of life for each study or class of intervention in each chapter. We excluded studies whose primary goal was to control psychiatric symptoms, thus, potentially excluding some antipsychotic trials that had relevant outcomes information, particularly related to adverse events. However, the recent DERP report134 and AHRQ report133 on the comparative effectiveness of antipsychotics provide a robust review of these outcomes as they pertain to adverse events of these treatments. Although we attempted to evaluate the impact of effectiveness versus efficacy studies, the small number of studies overall and lack of effectiveness studies made this analysis unfeasible.

## Research Gaps

We used the framework recommended by Robinson et al.159 to identify gaps in evidence and classify why these gaps exist. This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies gaps as due to (1) insufficient or imprecise information, (2) biased information; (3) inconsistency or unknown consistency, and (4) not the right information. In addition, we considered studies in progress identified from ClinicalTrials.gov when making recommendations for future research. Gaps and recommendations are presented in Table 16.

Table 16 Evidence gaps and future research for adults with SMI

| Evidence Gap | Reason | Type of Studies to Consider
Patients | Limited data for patients with conditions other than schizophrenia | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Patients | No data in older adults who have more comorbid medical illness | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Patients | Few studies of ethnic and racial minorities | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Interventions | No interventions evaluating peer and family support interventions | Insufficient information | Single and multisite RCTs
Interventions | No studies on the effects of the most recently approved second-generation antipsychotics such as paliperidone, iloperidone, asenapine, and lurasidone | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Interventions | Limited evidence about the benefits and harms of switching from one antipsychotic to another on metabolic parameters | Insufficient information | Secondary analyses of existing studies such as the CATIE trial or large observational datasets
Interventions | No studies comparing optimized antipsychotic management (e.g., start with or switch to drugs with more favorable metabolic profiles) with continuing current antipsychotics in responders and treating adverse metabolic effects directly using treatments (e.g., statins) with known efficacy | Insufficient information | Single and multisite RCTs Quasi-experimental studies
Interventions | Few multimodal interventions (e.g., robust behavioral and pharmacological treatments) and few multicondition interventions (interventions that address multiple CVD risk factors) | Insufficient information | Single and multisite RCTs
Interventions | Few evaluations of smoking cessation interventions other than bupropion^a^ | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Interventions | Few studies evaluating integrated mental health and general medical care^a^ | Insufficient information | Single and multisite RCTs Quasi-experimental or clinical records-based observational studies
Interventions | Uncertainty about the key characteristics of successful behavioral interventions (e.g., tailoring, dose, duration, delivery mode, individual vs. group) | Insufficient information Not the right information | Improved intervention reporting Single and multisite RCTs Systematic reviews
Interventions | Uncertainty about the details of the intervention | Not the right information | Manuals provided to promote replication/implementation of successful interventions
Interventions | Interventions to improve guideline concordant care | Insufficient information | Single and multisite RCTs Quasi-experimental studies
Comparators | Few studies comparing two active interventions | Insufficient information | Single and multisite RCTs comparing effective treatments Quasi-experimental or clinical records-based observational studies
Outcomes | Uncertain effects on overall CVD risk or cardiovascular events | Insufficient information | Risk indices (e.g., Framingham Risk Score) and/or cardiovascular events used as outcome measures
Outcomes | Intervention adherence | Insufficient information | Improved study reporting
Outcomes | Uncertainty about adverse effects on mental health status and other serious adverse effects, specifically in individuals with SMI | Insufficient information | Studies that define and report the proportion of patients for whom mental health status worsens Improved reporting of adverse effects
Timing | Few studies with outcomes measured beyond 6 months | Insufficient information | RCTs with longer term followup Quasi-experimental or observational studies
Setting | Lack of studies designed to evaluate “real world” effects of the intervention (effectiveness studies) | Insufficient information | RCTs or quasi-experimental studies with broad inclusion criteria, conducted in community practices, with long-term followup and which include clinically important outcomes such as physical functioning, cardiovascular events, and adverse events Improved reporting of efficacy–effectiveness characteristics

CATIE = Clinical Antipsychotic Trials in Intervention Effectiveness; CVD = cardiovascular disease; RCT = randomized controlled trial; SMI = serious mental illness

a Research gaps from prior high-quality systematic reviews that were identified during the topic refinement phase of this review and are described briefly in this report.

The list of gaps in evidence is long and one might reasonably ask which gaps have the highest priority. A full discussion of methods to establish a prioritized research agenda is beyond the scope of this report, but we suggest some general principles as applied to the population of adults with SMI. Most groups160 advocate input from multiple stakeholders and consideration of issues such as the burden of disease (incorporating prevalence and impact on health), the availability of existing treatment options, the likelihood that the new intervention will substantially improve outcomes, practice variation and health disparities, and the feasibility of implementing effective interventions with existing resources. Specific research questions can be evaluated quantitatively, using value-of-information analysis, which employs Bayesian methods to estimate the potential benefits of gathering more information through research.161 A recent AHRQ white paper used a multiple-stakeholder consensus process to identify patient-centered outcomes research priorities for serious mental illness.162 This report identified 21 themes—ranging from retooling universities and education to specific treatment approaches. Conducting comparative effectiveness studies of interventions targeting modifiable risk factors such as tobacco abuse, physical exercise, and nutrition was identified as a research priority.

A second consideration in research prioritization is to identify research designs that are best suited to address the evidence gap. Randomized controlled trials are less susceptible to bias but are typically more expensive and slower to yield results than observational studies. Several studies163,164 have compared interventions evaluated in both observational and randomized trials, showing high levels of concordance—but there have been notable exceptions. For example, vitamin E and conjugated estrogens appeared cardioprotective in observational studies, but RCTs did not show benefit.165–167

We suggest that observational designs may be particularly appropriate for these applications: (1) evaluating interventions proven effective in non-SMI populations, (2) testing the effectiveness of interventions demonstrated efficacious in tightly controlled trials, and (3) formulating hypotheses to be tested in RCTs. RCTs may be particularly useful for interventions specifically tailored for SMI populations and for drugs, or drug strategies (e.g., antipsychotic switching), that are used primarily in this population. Although we recommend multicenter RCTs to address some evidence gaps, we are aware that there are particular challenges to conducting RCTs in this population. For example, individuals with SMI have been routinely excluded from large cardiovascular trials—limiting opportunities to participate in research. Also, behavioral interventions may be affected by limited access to healthy foods or opportunities for exercise because many individuals with SMI are in lower socioeconomic status groups. Symptoms of mental illness and effects on cognition may make it difficult for individuals with SMI to fully participate in planned interventions. Some important outcomes, such as cardiovascular events, may take large sample sizes and long followup periods to evaluate.

## Conclusions

In summary, individuals with SMI are at risk for increased CVD—in part due to health behaviors, direct effects of the illness, and adverse effects from some treatments. Prior reviews identified bupropion as effective for smoking cessation, and integrated general medical and mental health care as effective for cardiovascular screening. In our review, surprisingly few studies addressed one or more CVD risk factors in patients with SMI, and most studies were skewed toward efficacy trials. Behavioral interventions, switching to or adding adjunctive aripiprazole, adding anticonvulsant medications topiramate and zonisamide, or adding metformin yield small to moderate weight loss compared with controls. We found insufficient evidence to support any strategy to control glucose. We found limited support of behavioral interventions focusing on weight loss or diabetes management or lipid control; SOE was insufficient for all other interventions. We found no studies testing a number of important interventions (e.g., orlistat, statins) known to be effective in non-SMI populations. Comparative effectiveness trials are needed that test multimodal strategies, known effective agents in non-SMI population (e.g., statins), and antipsychotic management strategies. However, in the absence of evidence for SMI-specific interventions, guideline-concordant care for individuals with SMI may help mitigate the unequal burden of CVD that SMI populations sustain.